# Methods

The methods for this comparative effectiveness review (CER) follow those suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews.41 The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.42

## Topic Refinement and Review Protocol

The topic for this report was nominated by a health care professional using the Effective Health Care Web site (http://effectivehealthcare.ahrq.gov/). Working from the nomination, we drafted the initial Key Questions (KQs) and analytic framework and sought input from Key Informants representing family medicine, generalist and subspecialty obstetrics and gynecology, and midwifery. Key Informants uniformly stressed the importance of terminology and of establishing clear and distinct categories of women for whom the review is intended to apply and suggested framing the review from the vantage point of a primary care provider or specialist who is at the earliest stage of management of abnormal uterine bleeding (AUB), which is typically nonsurgical management. KQs were refined to reflect the feedback from Key Informants and address gaps in existing evidence reviews and knowledge base about management of AUB.

After review from AHRQ, the KQs and analytic framework were posted online for public comment. We received no comments during the public posting phase. We prepared final KQs and resubmitted them to AHRQ for review. We identified Technical Experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP) included individuals with expertise in bleeding abnormalities, nomenclature and classification of AUB, and lead authors of ongoing reviews of surgical interventions. The TEP included five members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to review and provide comments as our work progressed. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and KQs;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Provide input on the information and domains included in evidence tables;

## Literature Search Strategy

### Search Strategy

#### Databases

We searched the following databases: MEDLINE^®^ (PubMed interface), the Cumulative Index of Nursing and Allied Health Literature (CINAHL^®^), and Embase. All search results were limited to English language. Searches were further restricted from 1980 forward in order to ensure literature was relevant to current secular trends in practice as well as available treatment strategies. We carried out hand searches of the reference lists of recent systematic reviews related to management of AUB and the reference lists of included publications. Searches were executed between September 2011 and June 2012.

#### Search Terms

Each search strategy used a combination of subject headings (i.e., controlled vocabulary) and keywords appropriate for each database (Appendix A). The search strategies included terms related to AUB, along with drug and therapy terms relevant to the topic and focus of Key Question 1A (KQ1A) and Key Question 1B (KQ1B). For Key Question 2 (KQ2), we conducted a second, separate search in MEDLINE (PubMed interface), using controlled vocabulary and keywords focusing on adverse effects and harms associated with those drugs and treatments from our KQ1A and KQ1B included studies. We also employed a combination of subject headings and keywords to narrow retrieval to desired study types; for KQ1A and KQ1B, this included terms related to randomized controlled trials (RCTs), and for KQ2, terms geared toward also retrieving cohort and postmarketing surveillance studies.

### Supplementary Information for KQ2

To further assess KQ2, we searched Internet resources to identify current research and regulatory information related to adverse effects and harms specific to those drugs and therapies from KQ1A and KQ1B included publications, with the term harm referring to any negative psychological, physical, or health system consequence associated with the intervention being studied. These searches were executed between January and March 2012. The Scientific Resource Center invited manufacturers of drugs from our included studies to provide Scientific Information Packets.

For each included intervention, we conducted searches of the Food and Drug Administration (FDA) database of approved drugs (Drugs@FDA) and DailyMed to locate the most recent label information, determine the approval date, ascertain therapeutically equivalent drugs, and find other relevant information related to harms. For those drugs no longer marketed or unavailable in the United States, label information (including indications and usage, and harms) was also retrieved from the regulatory agencies of other countries where the drug is approved (e.g., HealthCanada's Drug Product Database), drug information databases (e.g., Micromedex^®^ and LexiComp^®^), and manufacturer or pharmaceutical company Web sites. Additionally, we searched the FDA's safety information and adverse reporting Web site (MedWatch) to verify the most recent changes to label information were included in our harms data.

To supplement the harms data extracted from package inserts and relevant studies, we adapted our primary PubMed search strategy to identify systematic reviews and meta analyses examining the therapeutic agents identified in our analysis of the literature for KQ1, limiting to items published since 2005.

To ascertain current and ongoing research, we searched clinicaltrials.gov with topic keywords (e.g., “abnormal uterine bleeding”, “menorrhagia”, “heavy menstrual bleeding”), looked at both recruiting and completed studies, and again focused on those drugs and therapies from KQ1A and KQ1B included publications.

## Inclusion and Exclusion Criteria

To be considered for inclusion, studies had to explicitly define and describe the study population, the interventions, and outcomes.

For this CER, the population of interest included women with symptomatic cyclic or irregular uterine bleeding (Table 2). We excluded studies of women with AUB caused by coagulation defects, systemic disease (e.g., thyroid disease), structural abnormalities (e.g., fibroids, polyps), cancer, or medication side effects. Studies that included patients with AUB of mixed or ill-defined etiologies were reviewed for evaluable data from patients meeting the description of the population of interest. For KQ1A we included studies of women with polycystic ovarian syndrome (PCOS) if the patient baseline and outcome data included information on cycle regularity. We excluded studies of women with infertility if the primary treatment goal was conception.

Table 2 Definitions of eligible patient populations

Patient group | Description
Irregular uterine bleeding | Problem bleeding (frequent or infrequent) of 3 months or greater duration, excluding regular cyclic/menstrual patterns of bleeding, fibroids, polyps, adenomyosis, cancers, medication side effects, coagulation defects, and related systemic disease.
Abnormal cyclic uterine bleeding | Problem bleeding of 3 months or greater duration, excluding irregular and unpredictable patterns of bleeding, fibroids, polyps, adenomyosis, cancers, medication side effects, coagulation defects, and related systemic disease.

To be considered for inclusion, clinical research studies had to evaluate a nonsurgical intervention. For KQ1 and KQ2 we included data from controlled clinical trials (e.g., RCTs) designed to evaluate an intervention or treatment strategy for individuals from the population of interest. For KQ2, we also included data from uncontrolled observational studies, namely high-quality, large cohort studies, postmarketing surveillance studies, and registries/databases, with a population of 1,600 or more patients or records to capture information on adverse events or other harms.43 We determined that a minimum sample size of 1,600 was needed in order to reliably detect harms with an estimated prevalence of 1 percent. We did not specify a minimal population size for KQ1. Several factors, including varying prevalence of cyclic and irregular patterns of bleeding and the large number of interventions under consideration for this review, make it difficult to reliably establish a minimum sample size for evaluating treatment effectiveness.

To balance resources and focus on literature of most immediate relevance to primary care practice in the United States, we excluded papers that were not published in English.44

## Study Selection

We developed individual abstract and full-text screening forms for KQ1 and KQ2 (Appendixes B, C, D and E). We revised the forms following testing by the team. The forms were adapted for use in the Web-based systematic review product, DistillerSR (Evidence Partners, Ottawa, Canada).

We conducted screening in two phases: abstract and full-text screening. Publications were promoted to full-text review when one reviewer indicated that the publication met all inclusion criteria or when the title and abstract did not provide adequate information to make a determination. Two reviewers independently reviewed each publication at the full-text screening phase. Discordant classifications were resolved in team meetings including senior investigators.

## Quality (Risk of Bias) Assessment of Individual Studies

Two senior team members independently assessed quality of the included studies; disagreements were resolved through discussion or third party adjudication as needed. We recorded quality assessments in tables, summarizing each study.

We used the Methods Guide for Effectiveness and Comparative Effectiveness Reviews41 and the Cochrane Risk of Bias Tool45 (Appendix F), an existing tool with established validity and reliability, to assess methodological quality of included studies. This tool includes criteria for judging risk of bias for specific elements from five fundamental domains: sequence generation, allocation concealment, blinding, outcome data, and selective reporting (Appendix G) in RCTs. From these domains an overall assessment of risk of bias was calculated based on prespecified thresholds for modified quality assessment criteria from the Cochrane Risk of Bias (RoB) Tool (Appendix H). The overall risk of bias assessment was then expressed as one of three final study quality ratings: studies assessed as having a high risk of bias were categorized as “poor” quality studies; studies having a medium risk of bias were categorized as “fair” quality studies; and studies assessed as low risk of bias were categorized as “good” quality studies.

We assessed quality for the included studies that addressed KQ1 only. For KQ2, we sought evidence from varied sources; it was not possible to systematically assess the quality of the evidence related to harms. A summary of all component items and overall risk of bias/quality score for each included study is provided in Appendix I.

## Data Extraction

We created uniform evidence tables to extract data and facilitate data synthesis. We collected those data related to population characteristics, type of abnormal bleeding, intervention characteristics, and outcomes including harms.

We evaluated the ability to capture data across publications about candidate effect modifiers and confounders of treatment response and uniformly extracted information about candidates including age, body mass index, parity, and smoking status. When available we also collected current and prior contraception, perimenopausal status, fibroid status, and comorbidities including diabetes and PCOS. The final evidence tables are provided in Appendix J.

## Data Synthesis

A meta-analysis was not feasible for this review. Few studies had comparable treatment doses, interval, length of treatment, or duration of followup. Among those that did, the ability to aggregate data was limited by differences in outcomes measures which included measures of blood loss from sanitary product collection, and self-report using scoring systems including standardized pictorial systems.

For regularity of bleeding no two measures of outcome were the same. We provide a narrative synthesis of the available data from original research studies of acceptable quality for nonsurgical treatment of AUB.46 We group findings and summary tables by KQ, intervention, and outcomes.

## Strength of the Body of Evidence

The strength of evidence evaluation is stipulated in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.41,47 The guide emphasizes the following four major domains: risk of bias (low, medium, high); consistency (inconsistency not present, inconsistency present, unknown or not applicable); directness (direct, indirect); and precision (precise, imprecise) of the evidence. Risk of bias was derived from the quality assessment of the individual studies that addressed the KQ and specific outcomes under consideration.

We used explicit criteria for rating the overall strength of the evidence on each intervention into qualitative categories (e.g., low, moderate, high, and insufficient). We used established concepts of the quantity of evidence (e.g., numbers of studies, aggregate ending-sample sizes), the quality of evidence (i.e., from the quality ratings on individual articles), directness of the outcomes for informing the KQs, and the coherence or consistency of findings across similar and dissimilar studies and in comparison to known or theoretically sound ideas of clinical or behavioral knowledge. For this CER, overall strength of evidence for each intervention was made based upon a qualitative consideration of the assessment for each domain.

We assessed the overall strength of evidence rating based on the assessments for the individual domains for cycle regularity (KQ1A) and menstrual blood loss (MBL) reduction KQ1B. Data from studies that were considered to be fair or good quality were included in the assessments. Poor quality studies were identified but not included in the assessment of strength of evidence. For KQ2, we did not rate of strength of evidence because a fully inclusive assessment of harms could not be completed for each of the 12 interventions that have been widely studied in populations that lack direct applicability to this report.

The overall strength of evidence was graded as “high”, “moderate”, “low”, or “insufficient” (Table 3).47 When no studies were available for an outcome or comparison of interest, or if the available evidence was weak (i.e. from studies with high risk of bias) we graded the evidence as insufficient.

Table 3 Strength of evidence grades and definitions

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment.

Two senior investigators independently graded the body of evidence and final assignment was reviewed with the project team. We achieved alignment through group discussion with careful attention to application of consistent standards across each area item being graded.

## Applicability

We assessed applicability of the results gathered from the literature to the population of women with abnormal cyclic and irregular uterine bleeding according to EPC methods guidance.48 Assessments of applicability were done to account for any factors limiting the ability to apply interventions to other populations or other settings, such as inadequate description of the intervention or failure to report followup data.

Using the patient, intervention, comparator, outcome, timing, and setting (PICOTS) framework, we identified factors that may limit the applicability of individual research studies. We summarized the applicability of the body of evidence and described key elements from the PICOTS framework that characterize the applicability of a body of studies.

## Peer Review and Public Commentary

Experts in reproductive endocrinology and primary care treatment of women were invited to provide external peer review. The draft report was posted for 4 weeks to elicit public comment. We addressed all reviewer comments by revising the text as appropriate. Responses to peer and public review comments will be listed in the disposition of comments report. This report will be available on the AHRQ Web site 3 months after the posting of this final CER.