# Peer Reviewers

Peer reviewer comments on a preliminary draft of this report were considered by the EPC in preparation of this final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Jeffrey Jensen, M.D., M.P.H.
  Oregon Health & Science University
  Portland, OR
- Annekathryn Goodman, M.D.
  Gillette Center for Women's Cancer
  Boston, MA
- Jonathan Klein, M.D., M.P.H.
  University of Rochester
  Rochester, NY
- Patricia Langenberg, M.A., Ph.D.
  University of Maryland, Baltimore
  Baltimore, MD
- Anita Nelson, M.D.
  University of California, Los Angeles
  Los Angeles, CA
- Lee A. Learman, M.D., Ph.D.
  Indiana University
  Indianapolis, IN
- Malcolm Munro, M.D.
  University of California, Los Angeles
  Los Angeles, CA