# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives are sought. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design and/or methodologic approaches do not necessarily represent the views of individual technical and content experts.

- Andrea S. Lukes, M.D.
  Duke University
  Durham, NC
- Kristen A. Matteson, M.D., M.P.H.
  Women and Infants' Hospital
  Providence, RI
- Malcolm G. Munro, M.D.
  University of California, Los Angeles
  Los Angeles, CA
- Anita L. Nelson, M.D.
  University of California, Los Angeles
  Los Angeles, CA