# Key Informants

- Janet R. Albers, M.D.
  SIU Center for Family Medicine
  Springfield, IL
- Barbara S. Apgar, M.D.
  University of Michigan
  Ann Arbor, MI
- Marc A. Fritz, M.D.
  UNC Fertility Preservation Program
  Chapel Hill, NC
- Kristen A. Matteson, M.D., M.P.H.
  Women and Infants' Hospital
  Providence, RI
- Malcolm G. Munro, M.D.
  University of California, Los Angeles
  Los Angeles, CA