# Acknowledgments

We are indebted to an exceptional group of colleagues who made this report possible. Each step of a systematic review draws on the skills and attention of an entire team. The authors gratefully acknowledge the following individuals for their contributions to this project:

Dr. Mamata Raj was instrumental in extracting data and completing tables. Dedicated staff members Ms. Kathy Lee, Ms. Sanura Latham, and Mr. Ross Brown assisted with formatting, data entry, and article retrieval. Ms. J. Nikki McKoy and Ms. Nila Sathe provided guidance on logistics of the review process and organization of the report. Dr. Melissa McPheeters offered key input and feedback on the protocol, conceptual framework for the report, and methodological issues.