# Discussion

## Key Findings

### State of the Literature

We identified 1,775 nonduplicate publications through the search process, with 219 proceeding to full-text review (Figure 2). We included 41 publications that reported on 39 separate randomized controlled trials (RCTs) and 12 types of interventions. These studies evaluated the levonorgestrel-releasing intrauterine system (LNG-IUS; 7 studies),59-65 the contraceptive vaginal ring (1 study),84 nonsteroidal anti-inflammatory drugs (NSAIDs; 13 studies),67-70,72-76 tranexamic acid (TXA; 7 studies),66,71,77-81 combined oral contraceptives (COCs; 6 studies),50,59,61,68,82,83 metformin (4 studies),51-54 exenatide (1 study),53 progestogens (1 study),49 cabergoline (1 study),55 acupuncture (2 studies),57,58 lifestyle/behavioral changes (1 study),56 and patient decision aids (3 studies)86,87,177 using at least one comparator or placebo arm.

A number of these studies compared the intervention of primary interest to a progestogen, such as medroxyprogesterone (MPA).49,60,62,64,70,74,79,80 These studies were not considered important contributions to evidence about the effectiveness of progestogens for treatment since in each case the hypothesis was that the progestogen would be inferior or equivalent to the intervention being studied. Though we report the outcomes for progestogen comparisons to other interventions we have not separately summarized the effectiveness of progestogens. One trial evaluated two routes of progestogen and was treated as a study evaluating progestogen for symptom management.49

The quality of the included studies tended to be fair (10 studies)51,58,60,64,67,75,76,80,81,84 or poor (23 studies).49,52-54,56,57,59,61-63,65,66,68-71,73,74,77,79,86,87,177 In part, this followed from the difficulty of blinding participants to intervention status. For instance, no LNG-IUS studies included sham insertion or a sham LNG-IUS string placement in the endocervical canal along with placebo medication in both groups, though this would be required to achieve complete masking of intervention groups. Likewise it can be challenging to mask outcome assessors to group status when women and providers assess outcomes. An unmasked participant is counted in the scoring as an unmasked assessor when the outcome is self-reported or self-collected. While this is rigorous and appropriate in the evaluation of risk of bias in RCTs, it may be an inappropriately strict criterion to apply for studies in which menstrual products are collected for measurement of blood loss or in which biological markers such as hemoglobin or hematocrit levels are also assessed. Understanding this context can inform interpretation of the literature.

### Effectiveness of Interventions for Abnormal Bleeding

#### Key Question 1A (KQ1A) Management of Irregular Uterine Bleeding

A number of available interventions suitable for use in primary care have preliminary evidence of effectiveness for improving the regularity of menses. Only metformin has demonstrated effectiveness in more than one RCT with a total of 175 women with polycystic ovaries participating in each of three studies. One study suggests adding exenatide to metformin treatment can enhance effectiveness. No head-to-head comparison trials are available to inform choices among medication types for management of irregular uterine bleeding.

##### Progestogens

Vaginal micronized progesterone (8% gel) and oral dydrogesterone were studied in a single trial among women clinically classified as having dysfunctional uterine bleeding.49 In this RCT, both vaginal and oral administration improved cycle regularity with 92 percent and 85 percent of participants, respectively, achieving regular bleeding by the third cycle of use. Effects were comparable, but the trial was not powered to show equivalence or noninferiority.

##### COCs

A triphasic oral contraceptive was also studied in a single RCT among women with irregular uterine bleeding.50 This trial included women with both short and long intervals between bleeding episodes and with both heavy and normal amounts of bleeding. The outcomes are provided in aggregate and not presented by initial bleeding characteristics. Overall, 68 percent of women taking the COC achieved excellent or good cycle control compared with 26 percent of those receiving a placebo.

##### Metformin and Exenatide

Metformin was an active treatment arm in four RCTs conducted among women with polycystic ovarian syndrome (PCOS), two comparing outcomes to a placebo group,51,52 one comparing metformin with N-acetyl-cysteine,54 and one comparing metformin only, exenatide only, and both.53 In each case, metformin was effective for improving the regularity of bleeding over a number of months compared with baseline or placebo. When combined with exenatide the effect was greater than either alone in the study of 60 women with PCOS that compared all three approaches.53

##### Cabergoline

In a very preliminary investigation of this drug indicated for treatment of prolactinomas, cabergoline was associated with return of regular menses in three of eight women in the treated group compared with none of the six receiving placebo.55 All women in the study had PCOS and normal prolactin levels.

##### Behavioral and Lifestyle Interventions

Among adolescents with PCOS, both a low-fat, calorie-restricted diet and a carbohydrate-restricted diet in conjunction with 30 minutes of aerobic activity 3 days a week resulted in more regular menses among those who lost weight.56 This single small study did not present outcomes by the diet group to which participants were randomized. Presumably, there was not a clear difference, meaning there is no evidence to guide choice of dietary intervention. A single trial of acupuncture also included an exercise control group at the same intensity as the diet and exercise trial.57 This group experienced a 42-percent improvement in regularity of menses. We did not find evidence comparing diet to exercise directly.

##### Complementary and Alternative Medicine

Two studies of acupuncture with different underlying hypotheses and different methods (conventional acupuncture and low-frequency electroacupuncture) found benefit for a specific style of acupuncture when compared with no intervention or alternate placement of acupuncture needles.57,58 By 32 weeks in the trial of electroacupuncture for PCOS, women who received acupuncture had a 121-percent improvement in cycle regularity while those who exercised only had a 42-percent improvement which was statistically comparable in this small trial.57 Both acupuncture and exercise were superior to placebo in this trial. In the trial of two differing placements of needles, women who received treatment for “mind tranquilizing and menstruation promotion” had greater improvements (no treatment failures among 21 women) compared with those receiving traditional placement (n=16) for “delayed menses” among whom 19 percent did not have improvements.58

#### KQ1B Management of Abnormal Cyclic Bleeding

The LNG-IUS, various NSAIDs, TXA, and COCs are effective for reducing the amount of menstrual bleeding and in some instances have been shown to have additional benefits. Each category of intervention is described below.

##### LNG-IUS

All seven studies of the LNG-IUS demonstrated that the intervention effectively reduced heavy menstrual bleeding.59-65 Evidence suggests the device reduces the volume and duration of bleeding, improves iron status, and is an acceptable alternative to hysterectomy for some women. In direct comparisons, the LNG-IUS was superior to COCs and NSAIDs at reducing menstrual blood loss (MBL). We did not find any studies that compared the LNG-IUS to TXA.

Our analysis of LNG-IUS is consistent with prior systematic reviews. A 2001 systematic review of five RCTs reported mean MBL reductions were between 71 and 96 percent.178 A 2005 systematic review identified 10 RCTs comparing LNG-IUS with surgery or pharmaceutical treatments.157 The odds ratio for the proportion unwilling to continue with treatment was 0.27 (95% CI, 0.10 to 0.67) in favor of LNG-IUS. The odds ratio for proportion of women satisfied with treatment was 2.13 (95% CI, 0.62 to 7.33).157

##### Contraceptive Vaginal Ring

One study investigated the contraceptive vaginal ring finding that it was similar in effectiveness to norethisterone when taken orally three times a day for 21 days of each cycle. Overall more women were satisfied with the contraceptive vaginal ring and chose to continue use compared with women taking oral norethisterone.

##### NSAIDs

In a total of 13 studies, NSAIDs including mefenamic acid, naproxen, meclofenamate, and flurbiprofen, given at the onset of menses for up to 5 days reduce MBL by 20 to 49 percent.63,66-77 Studies have evaluated use over one to six menstrual cycles. Our analysis of NSAIDs is consistent with a prior 2007 systematic review; NSAIDs were more effective than placebo at reducing bleeding, but less effective than TXA or LNG-IUS.34 There were no differences in reductions between NSAIDs and oral progestogens, COC, and an older progesterone-impregnated intrauterine system (Progestasert^®^). There were no differences seen between individual types of NSAIDs, specifically mefenamic acid and naproxen. The most recent study found similar reductions in pictorial blood loss assessment chart scores when NSAIDs were combined with TXA compared with TXA alone. NSAIDs reduce MBL, but do not consistently reduce MBL to clinically meaningful levels (i.e., less than 80 ml) in all patients. There was considerable variability in response. Some patients had an increase in blood loss during treatment. NSAIDs do not regulate the pattern of menstruation nor provide contraception. NSAIDs do provide relief of dysmenorrhea. Therefore, for patients who desire both reduced MBL and relief from dysmenorrhea, but not contraception, and who do not have contraindications, NSAIDs can be considered for up to five days during menses.

##### TXA

All seven RCTs of TXA demonstrate effectiveness of improving heavy bleeding.66,71,77-81 TXA at a dose of 1.95 to 4.5 grams per day for 4 to 5 days from onset of bleeding meaningfully reduces MBL by 40 to 60 percent in studies lasting up to 1 year. Both biologic and self-reported symptoms of bleeding severity are improved. Our analysis of TXA is consistent with prior systematic reviews of another formulation of TXA. A 1995 systematic review pooled results from seven trials and found a reduction in MBL of 46.7 percent (95% CI, 47.9% to 51.6%) with TXA.179 A 2004 systematic review and meta-analysis of two RCTs of TXA versus placebo reported a mean MBL difference of −93.96 ml (95% CI, −151.43 ml to −36.49 ml) in favor of TXA treatment.174

##### COCs

Though the volume of RCT literature examining use of COCs in women with abnormal uterine bleeding (AUB) is somewhat small relative to the frequency with which these agents are used as a first-line therapy in women presenting with AUB symptoms, our analysis indicates these agents are associated with decreases in AUB among treated women. All five RCTs of COCs for the indication of heavy cyclic menstrual bleeding found benefit for reducing volume of menstrual bleeding. 59,61,68,82,83 Two studies also identified improvements in related laboratory values such as hematocrit and ferritin, 82,83 and one study also found significant improvement in patient rating of overall health.59 These findings are consistent with the 2010 American Congress of Obstetrics and Gynecology recommendations, which note that combined hormonal contraceptives are a “reasonable option for initial management of menorrhagia.”21 In the two head-to-head comparisons between COCs and LNG-IUS,59,61 reductions in heavy menstrual bleeding were documented in both treatment groups, with a somewhat greater benefit for LNG-IUS users.

##### Decision Aids

Three studies investigated decisions aids to assist women seeking treatment for heavy cyclic bleeding in making informed decisions about care.86,87,177 The study results suggest that decision aids increase patient knowledge and enhance satisfaction with care but do not affect disease symptoms in directly measureable ways. One study found fewer women who received the decision aid ultimately chose surgical referral and hysterectomy.86 However this decision cannot be linked to improvement in bleeding symptoms. Since there are no known harms associated with using decision aids, they may help patients evaluate treatment options and feel secure in their choices.

### Applicability

Applicability describes the extent to which results observed in published studies from this this review are likely to reflect the expected outcomes when an intervention is applied to broader populations in real-world conditions. Studies for this review were intended to provide information to inform primary care management of AUB, whether irregular or cyclic. In shaping the methods for this review, we have engineered the report so that the included research is applicable to primary care of women in the United States. Our stricter criteria, narrowing findings to only symptomatic populations of reproductive-age women with chronic complaints of abnormal bleeding, comes at the cost of fewer studies being addressed. However, it assures that those studies that are included were explicitly designed to examine the effectiveness of the treatments for improving the outcomes of interest in the populations of interest. Applicability of the findings is therefore high.

For each intervention, it is important to note the following provisions. The results of this review apply for women:

- Who are reproductive age and state they have an irregular pattern of menstrual bleeding or heavy cyclic menstrual bleeding.
- Without abnormal findings on pelvic exam or on ultrasound report (fibroids, polyps).
- Without an intrauterine device (IUD) in place, and who are not pregnant or lactating,
- Who are healthy, and without renal impairment, hepatic impairment, intestinal disease, thyroid disease, abnormal cervical cytology, noncyclic bleeding, history or presence of significant medical problems (e.g., thromboembolic disease, coagulopathy, subarachnoid hemorrhage, endocrine disorders, or eye disease).
- For whom any additional clinically determined diagnostic and screening tests have be completed to rule out these and other causes of abnormal bleeding.
- Does not have any of the contraindications found in the Food and Drug Administration sources discussed in the main document and do not have risks of drug-drug interactions if they take multiple prescription medications.

Our review was not designed to guide evaluation of women with abnormal bleeding, rather to address what treatments have evidence of effectiveness once the diagnosis is established and primary care management is to be initiated.

#### Applicability of Literature About Interventions for Irregular Uterine Bleeding (KQ1A)

The literature about management of irregular uterine bleeding applies to women in primary care settings in the United States. Ten RCTs, three conducted in the United States, two in Italy, two in Turkey, and one each in China, Sweden, and the United Kingdom provide evidence about seven types of intervention. Enrolled populations were narrowly defined and had either a clinical diagnosis of irregular uterine bleeding, or met research criteria for PCOS. As a result the findings are strictly applicable only to these groups of women. We describe the agents study within the two populations in which the research was conducted.

##### Use for Irregular Uterine Bleeding (KQ1A)

###### Progestogens

The study comparing vaginal micronized progesterone (8% gel) with oral dydrogesterone for a 10-day time period is applicable to primary care in the United States, as both routes are used in standard care in the United States to provide progesterone in order to organize a withdrawal bleed that will typically occur within days of completing the progestogen. The oral agent in this trial, dydrogesterone, is not available in the United States. This study is therefore a surrogate for oral versus vaginal administration of similar progestogen formulations such as MPA that are widely used in the United States for this purpose; however it does not provide direct evidence to support use of other agents. The outcome of interest for this review was regularity of bleeding after treatment which was provided for three menstrual cycles. Both groups had improvement however applicability for chronic use is unclear as no long-term followup of symptom control is available. Progesterone is often used in management of specific causes of abnormal bleeding such as PCOS however this study does not directly apply because the population was not addressed in this study. Progesterone can be used by women who wish to conceive.

###### COCs

The single study, conducted in the United States, is directly applicable to primary care in the United States. The study population of 201 women is representative of the spectrum of complaints that may accompany chronic irregular uterine bleeding including menses that are widely separated in time whether light, normal, or heavy with regard to heaviness of bleeding, and includes women with closely space and unpredictable bleeding also without restriction on heaviness of bleeding. The intervention is a common version of triphasic COC (Ortho Tri-Cyclen^®^) that provides direct evidence for its effectiveness and indirect evidence for other triphasic pills with similar dosing profiles. The evidence is less direct but likely applicable to monophasic pills of similar estrogen and progestogen content. It does not apply to progestogen-only formulations or to pills with estrogen doses lower than 0.035 mcg as used in this study. Comparison to placebo provides definitive evidence of benefit but does not provide information about how COCs compare to other strategies that might be used such as LNG-IUS or progestogens. The outcomes included those that are a priority of women seeking treatment for uterine bleeding and included cycle regularity, incidence of excessive bleeding, and overall rating of symptom improvement.50 Harms and contraindications, as discussed in KQ2, are well-known to care providers and often to women themselves, and COCs are not applicable as a long-term strategy for women who wish to conceive.

##### Management of PCOS (KQ1A)

###### Metformin and Exenatide

The four trials that investigated use of metformin are applicable to care in the United States and were conducted in the United States, Turkey, Italy, and the United Kingdom. The study in the United States compared metformin, to exenatide or both. These studies enrolled women with PCOS and fewer than expected normal menses. They investigated doses of metformin that are available in the United States (500 mg and 850 mg, administered by mouth twice daily). None of the studies used an extended-release form which is now available so evidence related to that formulation is indirect. The outcome of interest for this review was menstrual frequency which was improved compared with placebo in 2 trials. One head-to-head comparison was metformin compared with exenatide or both. Both were superior to either alone for cycle control. Another trial compared metformin to N-acetyl-cysteine. The most common side effect which is gastrointestinal symptoms was identified in these studies and thus would be expected to apply to this typically younger group of women who do not have diabetes. Metformin can be used by women who wish to conceive and is safe for use in pregnancy. Based on other literature, it may enhance fertility. Little is known about exenatide and fertility and safety in pregnancy, however it does not have contraceptive effects.

###### Diet and Exercise

The applicability of the single trial of diet and exercise is limited. It enrolled 24 adolescents with PCOS, 16 of whom completed the study and evaluated a low-fat, calorie-restricted diet or a carbohydrate-restricted diet along with 30 minutes of anaerobic exercise 3 days a week. The trial did not provide an intention to treat analysis, comparing arms but did report that weight loss in either group improved cycle regularity. Behavioral changes can be applied in many populations and would be expected to have benefits. Thus evidence is insufficient to advise which dietary pattern is superior. Another arm of a single study found exercise 30 minutes each day, 3 days a week, was more effective than no intervention and as effective as acupuncture in improving cycle regularity.

###### Acupuncture

Two trials, one conducted in Sweden and one in China, assessed acupuncture. Depending on the availability and the skill of acupuncturists available in communities, this intervention may not be broadly applicable in the United States. Both tradition acupuncture and electroacupuncture improved cycle regularity but this was assessed in essentially unblended trials. The outcomes examined were relevant to patient symptoms however were very poorly-described in one study in which the investigators applied categories like “cured” without clear definitions. Overall, literature is absent to inform choice of any of these modalities over another.

#### Applicability of Literature to Management of Abnormal Cyclic Bleeding (KQ1B)

Twenty-nine studies contributed evidence about interventions for management of abnormal cyclic bleeding focused predominantly on effectiveness for reducing the amount of bleeding among women with heavy menstrual bleeding. Overall these RCTs are applicable to primary care in the United States. Five were conducted in the United States (including two multi-country trials), eight studies were conducted in the United Kingdom, four studies were conducted in Canada (including two multicenter studies), three studies were conducted in Australia (including one multicenter trial), and two each were conducted in Finland, Egypt, and India. A single study was conducted in each of the following countries: Netherlands, Sweden, and Turkey.

##### LNG-IUS

Overall, the study findings for LNG-IUS from this review apply to women in the primary care settings in the United States. One trial was conducted in three countries (United States, Canada, and Brazil), two trials were conducted in the United Kingdom, and the others were conducted in Egypt, Canada, Turkey, and Finland. The settings are not substantially different from a primary care setting in the United States. However, a limitation is that adolescent women and women with obesity were not included in the RCTs populations, so direct applicability to their care is lacking. Enrolled populations met our inclusion criteria and like others used direct measures of volume of bleeding that would be replaced in clinical care with patient self-report.

The LNG-IUS is available in the United States. The intervention dosage was the same for all seven trials and is that currently marketed (52 mg levonorgestrel, initial release rate 20 mcg per 24 hours). The LNG-IUS must be inserted by a provider. The details of the insertion procedure must be understood and practiced to safely provide this treatment in a primary care setting. The comparator differed among the seven trials; two trials compared LNG-IUS to a COC, three trials compared LNG-IUS to a progestogen (oral or intramuscular route), one trial used an NSAID as a comparator, and one trial assigned the patients in the control group to continue with their existing medical treatment for excessive uterine bleeding or symptoms of dysmenorrhea, or both. None of the trials compared LNG-IUS with TXA.

The primary outcome of the trials was change in blood loss which directly addresses the primary symptom for which women typically seek treatment. One study used the proportion of women who cancelled their prior decision to undergo hysterectomy as the primary outcome measure. Timing of assessment of outcome varied among the trials: one trial reported after 1 menstrual cycle, three trials reported after 3 menstrual cycles, four trials reported after 6 menstrual cycles, and two trials reported after 12 months. The latter are more informative for a device intended to be in place for 5 years.

##### Contraceptive Vaginal Ring

The contraceptive vaginal ring is available in the United States, and the group of women enrolled in the only study available is comparable in symptom profile to those in other studies in this CER. MBL reduction between the contraceptive vaginal ring users and the comparison group receiving norethisterone 3 times daily was similar. Women in the contraceptive vaginal ring group were more satisfied with treatment, however, it is important to note that comparison of the ring to an agent dosed 3 times each day may not be applicable to typical practice patterns in the United States when selecting a progestogen to prescribe for AUB.

##### NSAIDs

The 13 RCTs examining NSAIDs and included in this review are applicable to United States populations. The studies were conducted in seven countries including Australia (2 studies), Canada (1 study), India (2 studies), the Netherlands (1 study), Sweden (1 study), the United Kingdom (5 studies), and the United States (1 study). In some trials, women were excluded who were on hormonal medications, had menorrhagia related to an IUD, or who were taking NSAIDs or steroids. Therefore, results of these studies are applicable to women with no contraindications to NSAIDs including underlying hepatic, renal, or thyroid disease, stomach ulcers, or asthma, and no drug sensitivity.

The specific NSAID administered to participants varied and included mefenamic acid (11 trials), naproxen (2 trials), flurbiprofen (1 trial), and meclofenamate (1 trial). One trial evaluated mefenamic acid in conjunction with TXA. For each NSAID, dose and duration did not vary greatly, with usually up to 5 days duration of use. The most commonly used dose of mefenamic acid was 500 mg 3 times a day starting at the onset of menses. One trial initiated mefenamic acid 5 days prior to onset of menses through cessation of bleeding. Another trial used 500 mg at onset of menses followed by 250 mg every 6 hours for 3 to 5 days. Mefenamic acid at a dose of 250 mg 3 times a day from onset menses for 5 days was used when combined with TXA in one trial. Naproxen was evaluated with initial loading doses of 500 to 550 mg then 250 to 275 mg every 6 hours for 5 days or until 24 hours after cessation of heavy bleeding. Meclofenamate was studied at a dose of 100 mg 3 times a day from onset of menses for duration of 6 days or until cessation. Flurbiprofen was studied at a dose of 100 mg twice a day from onset of menses for duration of 5 days. Each of these doses is available for prescription in the United States. Notably, the literature lacks RCTs about ibuprofen which is likely the most common prescription and over-the-counter NSAID used for heavy bleeding and dysmenorrhea.

Outcomes for the trials in this review included documentation of objective blood loss. This is not applicable in routine clinical care and subjective assessment of MBL is nearly always used as the criteria for initiating and determining success with NSAIDs. NSAIDs are also effective in reducing dysmenorrhea, and therefore patients with both heavy cyclic menstrual bleeding and dysmenorrhea or headaches may desire NSAIDs.

##### TXA

The literature about TXA for management of abnormal cyclic bleeding applies well to women in primary care settings in the United States. Two trials were conducted in the United States, three were conducted in Europe, and one took place in India. Enrolled populations met inclusion criteria and reviewed studies implemented exclusion of participants as described in the methods for this review. Because women with comorbidities are systematically excluded from these trials, we must note the studies apply to healthy women with heavy cyclic menstrual bleeding. While studies quantified the amount of bleeding at baseline, this is typically not feasible in clinical populations and the patient's statement that menstrual bleeding is heavy would be more likely to be used as a criterion for consideration of this therapy.

The formulation of TXA (Lysteda^®^) used in the included studies is the same that is currently available in the United States. The intervention dosage differed among the five trials but was in the range of 1.95 to 4.5 grams per day for 4 to 5 days. Treatments compared with TXA in these trials did not include LNG-IUS or COC regimens. This modestly limits applicability since these would be among the usual interventions considered in real-world clinical settings.

The primary outcome of the TXA trials was change in blood loss which is typically the most pertinent symptom for women. The timing of assessments of outcomes varied among the trials but was generally short: two trials reported after two menstrual cycles, four trials reported after three menstrual cycles, one trial reported after six menstrual cycles. No trials reported outcomes for use of TXA for 1 year or more of therapy. This limits understanding of applicability for long-term use of this agent. Reporting of adverse events was not adequate for an assessment of harms and in the context of short followup in trials, this prevents consideration of risks.

##### COCs

The findings of this review are applicable to women visiting a primary care setting for management of heavy, cyclic uterine bleeding. The included RCTs were conducted in the United States (1 study), Canada (2 studies), Australia (1 study), multiple sites in Europe (1 study), and Egypt (1 study) in outpatient clinical care settings. Known contraindications to use of COCs and abnormal findings during diagnostic work-up (e.g., fibroids or other endometrial pathology) were commonly employed as exclusion criteria in the identified studies and these diagnostic exclusions are applicable in the general primary care setting as well. Study participants were all older than 18, and had normal range body weights so no evidence directly informs symptom management or safety in younger adolescents or obese patients. COCs were compared with placebo in three studies and with LNG-IUS in two studies. Both participants in the COC group and LNG-IUS had improvements from baseline, but the LNG-IUS was superior to COC. In comparison to mefenamic acid, COCs were superior. The outcomes assessed were those of high relevance to patients and included MBL, blood counts and iron reserves, and participant and clinician assessment of symptoms.

##### Decision Aids

Use of decision aids is increasingly common and promoted in U.S. health care settings especially in clinical contexts in which patient preference plays a strong role in selection of the treatment and prioritization of outcomes. Three studies of decision aids are included in this review. Two were conducted in the United Kingdom and one in Finland. They are somewhat applicable to care in the United States but may not directly apply given differences in payment structures for care and prescriptions as well as potential differences in clinical care norms. All three studies used information booklets mailed to patients prior to their appointments and one added a computerized decision tool. The studies assessed outcomes like general health status, quality of life, and decisional conflict, as well as secondary outcomes like anxiety. Study populations included women older than 30 and 35 respectively in the two that reported, so findings do not generalize to younger women. None found benefit which may or may not reflect how similar approaches would be received in a U.S. health care context or across a broader age span of women.

#### Final Comments on Applicability

Overall applicability of this literature to providing care was high. However, often women who are in trials do not reflect the full range of those with abnormal bleeding seen in primary care and, as we have noted, groupings of participants do not correspond directly to newer classifications of sub-types of AUB.9 Study participants were more likely to be normal weight, nonsmokers, with few, if any concomitant conditions. The interventions (except in the case of specific comparators as noted) are available in the same doses and formulation in the United States. Outcomes such as measured blood loss, self-reported symptom severity and days of bleeding are of direct relevance to women with abnormal bleeding. Our findings are sparse for outcomes which can be considered essential for a condition like AUB that are defined by symptoms. Important outcomes include satisfaction with response to treatment, definitive assessments of whether or not the women considered their complaint resolved, and whether they wished to continue the same treatment or add additional treatments. Followup in general was brief, so they findings may not apply well to management of a chronic condition like abnormal bleedings. This makes findings about assessments of harms challenging since use of interventions over extended periods may have different risk profiles from short timeframes like one to six cycles.

## Summary of Strength of Evidence and Findings

Overall the evidence to answer KQs about the management of AUB, did not reach standards for high strength of evidence for any intervention. This was particularly true in the literature relevant to treatment of women with irregular uterine bleeding. Combined oral contraceptives, as represented in a single good quality placebo controlled trial with a total of 201 participants, documented effectiveness. The treatment effect was large with improvement in bleeding patterns reported for more than 80 percent of women taking COC compared with 45 percent for the placebo group. Combined, these factors provided moderate evidence of benefit. Use of metformin is supported by low strength of evidence predominantly related to small trials with somewhat limited quality. For the remainder of the interventions investigated for management of irregular uterine bleeding, there is insufficient evidence that follows from single or lower quality studies, or both.

The strength of evidence tables (Table 22 and Table 23) that follow summarize the total number of studies and within those studies the number of women who received the specific intervention. The tables also provide the assessment of the risk of bias, consistency of findings across trials, directness of the evidence that treatment improves the symptom, and precision of the estimated provided by the literature. The complete scoring is found in the Appendix J. For KQ1B, risk of bias associated with blinding of patients, personnel and outcome assessment was most likely to compromise overall assessment of study quality. For KQ1A, risk of bias associated with blinding of patients and personnel and incomplete outcome data was most likely to compromise overall study quality.

Table 22 Strength of evidence for improving menstrual regularity (KQ1A)

Intervention Quality: Studies (Subjects Assigned to Intervention) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence^a^ | Findings Comparisons
Progestogen^b^ Poor: 1(69)49 | High | NA | Direct | Imprecise | Insufficient | Not analyzed by arm
COC^c^ Good: 1(101)50 | Low | NA | Direct | Precise | Moderate | Cycle control improved:^d^ 87% COC vs. PBO, p<0.001^50^
Metformin^e^ Poor: 3(81)52,53,54 Fair: 1(45)51 | Medium | NA | Direct | Imprecise | Low | Delay to first ovulation:^f^ 24 days MET vs. PBO, p=0.02^51^
Exenatide^g^ Poor: 1(20)53 | High | NA | Direct | Imprecise | Insufficient | Small, poor quality trial
Cabergoline^h^ Good: 1(8)55 | Low | NA | Direct | Imprecise | Insufficient | Cycle control improved:^i^ 100% CBG vs. PBO, p=NR55
Diet^j^ Poor: 1(24)56 | High | NA | Direct | Imprecise | Insufficient | Not analyzed by arm
Exercise^k^ Poor: 1(34)57 | High | NA | Direct | Imprecise | Insufficient | Not analyzed by arm
Acupuncture^l^ Poor: 1(33)57 Fair: 1(23)58 | High | NA | Direct | Imprecise | Insufficient | Menstrual regulation:^m^ 86% MP-ACU > R-ACU, p<0.05^58^

CBG = cabergoline; COC = combined oral contraceptive; MET = metformin; MR-ACU = menstruation-promoting acupuncture; NR = not reported; PBO = placebo; R-ACU = routine acupuncture

a Overall strength of evidence assessment based on good and fair quality studies only.

b Oral dydrogesterone (n=35) vs. 8% vaginal micronized progesterone (n=34).

c Triphasic norgestimate-ethinyl estradiol vs. placebo (n=100).

d Subject assessment.

e Poor quality studies: metformin vs. N-acetyl cysteine (n=50), exenatide (n=20), or placebo (n=12); Fair quality study: metformin vs. placebo (n=47).

f Mean days to ovulation.

g Compared with metformin (n=20) or metformin plus exenatide (n=20).

h Compared with placebo (n=6).

i Menstrual cyclicity restoration in oligomenorrhea or spontaneous menses in amenorrhea.

j Low-fat diet (n=12) vs. low-carbohydrate diet (n=12).

k Compared with acupuncture (n=33) or no intervention (n=17).

l Poor quality study: acupuncture vs. exercise (n=34) or no intervention (n=17); Fair quality study: mind tranquilizing acupuncture vs. routine acupuncture (n=17).

m Patients cured or markedly relieved.

Table 23 Strength of evidence for improving heavy menstrual bleeding (KQ1B)

Intervention Quality: Studies (Subjects Assigned to Intervention) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence^a^ | Findings^b^ Comparisons
LNG-IUS Poor: 5(173)59,61-63,65 Fair: 2(104)60,64 | Medium | Consistent | Direct | Precise | Moderate | 71% and 94% reduction in MBL in 2 head-to-head studies LNG-IUS > MPA, p<0.001^60^ LNG-IUS vs. NOR, p=NS64
NSAID Poor: 9(192)63,66,68-71,73,74,77 Fair: 3(113)67,75,76,93 Good: 1(32)72 | Medium | Consistent | Direct | Imprecise | Moderate | 28% to 49% reduction in MBL in 3 placebo controlled trials; 46% and 47% reduction in MBL in 1 head-to-head study (2 NSAID arms) MFA vs. PBO, p=NR67 p<0.001^76,72^ MFA vs. NPX, p=NS75
TXA Poor: 4(202)66,71,77,79 Fair: 2(260)80,81 Good: 1(123)78 | Medium | Consistent | Direct | Precise | Moderate | 26% and 40% reduction in MBL in 2 placebo controlled trials; 45% reduction in MBL in 1 head-to-head study TXA vs. PBO, p<0.001^81,78^ TXA > NOR, p<0.001^80^
COC^c^ Poor: 3(90)59,61,68 Good: 2(269)82,83 | Low | Consistent | Direct | Precise | High | 64% and 69% reduction in MBL in 2 placebo controlled trials COC vs. PBO, p<0.001^83,82^
Progestogen^d^ Poor: 4(161)79,62,70,74 Fair: 4(173)60,64,80,84 | Medium | Inconsistent | Direct | Imprecise | Insufficient | 20% increase to 87% reduction in MBL in 4 head-to-head studies MPA < LNG-IUS, p<0.001^60^ NOR < LNG-IUS, p=NS64 NOR < TXA, p<0.0001^80^ NOR vs. CVR, p=NS84,e
CVR Fair: 1(48)84 | Medium | NA | Direct | Imprecise | Insufficient | 67% reduction in MBL^e^ in 1 head-to-head study CVR vs. NOR, p=NS84

COC = combined oral contraceptive; CVR = contraceptive vaginal ring; LNG-IUS = levonorgestrel-releasing intrauterine system; MBL = menstrual blood loss; MCF = meclofenamate; MFA = mefenamic acid; MPA = medroxyprogesterone; NA = not applicable; NOR = norethisterone; NPX = naproxen; NR = not reported; NS = not significant; NSAID = nonsteroidal anti-inflammatory drug; PBO = placebo; TXA = tranexamic acid

a Overall strength of evidence assessment based on good and fair quality studies only.

b Change in menstrual blood loss from baseline measured by the alkaline hematin method (unless otherwise noted) from good and fair quality studies.

c thinyl estradiol and levonorgestrel (n=71) or norethindrone and ethinyl estradiol (n=19) or estradiol valerate and dienogest (n=269).

d Medroxyprogesterone (n=177) or oral norethisterone (n=113) or depot medroxyprogesterone (n=44).

e Percent change in menstrual blood loss measured by the pictorial blood loss assessment chart.

For management of heavy cyclic bleeding the literature was more robust. Combined oral contraceptives are supported by high strength of evidence for the purpose of decreasing MBL. The LNG-IUS, various NSAIDs, and TXA are also effective for reducing the amount of measured menstrual bleeding and are each supported by moderate strength of evidence. Of note, in head-to-head comparisons with statistically significant differences, the LNG-IUS has one trial each showing superiority to NSAIDs, two showing superiority to COCs, and two showing superiority to progestogens. COCs were superior in one trial compared with an NSAID. TXA was also superior to an NSAID, and when combined with an NSAID was superior to TXA alone. Most of these interventions have been shown to have additional positive effects, typically including shorter duration of bleeding and improvement is symptoms when participants used standardized scoring systems to report on treatment response.

## Implications for Clinical and Policy Decisionmaking

This review highlights the variety of options that can be effective for management of abnormal bleeding. We hope it serves to encourage care providers and women to consider the full range of potentially helpful interventions. This review may help to underscore the fact that contraceptive options like LNG-IUS and COCs are a proven option, while widening consideration to include agents like metformin for women with PCOS and TXA for those with heavy bleeding. Clinicians may be also be alerted to the some of the constraints of the literature for these specific populations and proceed with more information to guide decisions and to discuss likely side effects and potential harms.

Since these conditions are not typically life-threatening but are chronic, problematic, and can be embarrassing and costly in terms of lost productivity, the primary health system and policy challenge is to recognize that failure to address AUB is unnecessarily diminishing women's quality of life and function.1,8 Cost differences are unlikely to drive choices among many of these interventions, though initial costs of long term treatments like the IUS can be disincentives if up-front or maintenance costs to the patient are high.180-183 Likewise for newer drugs, like TXA, decisions about eligibility and copays could influence uptake and continued utilization of an effective medication. All the interventions described, with the exception of exenatide, cabergoline, and acupuncture, are likely to be covered by most payors for these indications. For the treatments noted that have not yet proven effectiveness in large well-conducted studies this will need to be addressed with high quality research before policy decisions can be recommended.

## Limitations of This CER

In this review we focused tightly on primary care interventions for two specific patterns of abnormal bleeding (irregular and cyclic). While this approach was identified by our team, Key Informants, and the Technical Expert Panel (TEP) as an area of the literature that would benefit from evidence synthesis, our focus does prevent comparison to second line therapies that may be used by subspecialists for women who have failed primary care treatment and prevents examination of how these medications fare when compared with surgical options. The latter category of study is fairly small, and for broader perspective, there are a number of reviews within the last 5 to 10 years that provide more sweeping information about these interventions. For the reader's convenience, Appendix M lists these reviews and related practice guidelines and summarizes the conclusions that are relevant to the focus of this review.

Existing literature cannot uniformly be related to more recent updates in classification of AUB that have potential to drive greater uniformity in research and greater thoroughness in clinical evaluation. At present the inclusion and exclusion criteria of trials, the operational definitions of the condition under study and the level of screening of participants to document conformity with the FIGO 2011 classifications is lacking. As a result this literature synthesis is constrained to groupings that are less specific. Nonetheless we have organized the findings into groupings that are clinically recognized presentations and this evidence does apply for the scenarios described.

We restricted this review to publications in English. Based on review of abstracts (generally available in English) and on the expertise of our team and TEP, we do not feel that this biases the review for assessment of the LNG-IUS and medications because few studies were omitted, and larger, higher quality trials are typically published in the English language literature. The sole domain that may be fundamentally under-represented because of this strategy is complementary and alternative medicine which includes interventions such as herbal remedies, acupuncture, and massage therapy. We also restricted interventions to those that had been studied in randomized trials. This limits the degree of context that we can provide from observational studies about factors such as predictors of treatment success or effect modifiers. However, it is uncommon for observational studies to meet criteria sufficient to influence the assessment of strength of evidence when there are trials available, so this restriction is unlikely to have influenced the overall findings of this review.

## Limitations of the Evidence Base

Throughout the report we endeavored to point out limitations specific to the included populations, comparisons, and quality of the literature. Recent improvements in unifying nomenclature and formalizing consensus definitions for the clinical groupings of bleeding abnormalities9 will likely continue to have a positive influence on the ability to properly interpret the findings of individual studies, to identify groups of studies with comparable methods and to aggregate results. Though we did not systematically review literature about pathophysiology, normative patterns for bleeding, natural history of AUB subtypes, or health systems influences, we comment here beyond the need for specific trials in order to encompass other forms of research that could enhance the design and conduct of effectiveness studies as well as filling important gaps in knowledge that hinder research.

### Methodologic Limitations

Recurring methodologic recommendations include a need for:

- Larger RCTs, appropriately powered for direct head-to-head comparisons of treatment options in which loss of participants is minimized and intention-to-treat analyses are uniformly conducted.
- Detailed attention to operational criteria for defining the bleeding pattern under study and for methods used to define inclusion and exclusion. Conformity with FIGO PALM-COIEN sub-types may be desirable.
- Study of the validity and reproducibility of classification of women presenting with problem irregular and cyclic bleeding using the PALM-COIEN groupings or other approaches is needed to understand the diagnostic properties of clinical classification systems.
- Clear and definitive operational definitions of outcomes that include, indeed prioritize, patient-reported, condition-specific quality of life and satisfaction measures over durations of time compatible with treatment of a chronic condition. This should include assessments of whether the woman herself considers her bleeding problem resolved.
- Study populations that match the characteristics of those who present with AUB in primary care settings. This includes teens, perimenopausal women, heavier women, and women with common comorbidities such as diabetes and hypertension.
- More effective mechanisms of masking participants, researchers, and providers to intervention status. This may include need to develop sham procedures to mimic IUD insertion and to provide a sham “string” to confirm placement should a patient or provider check status. (Of note the IUD is effective without a string and string-less insertion is also an option for research where placement can be confirmed by ultrasound.)
- Studies designed to assess treatment trajectory and cost. Such studies could randomize women to distinct treatment pathways and track the rate of conversion from one treatment to another for inadequate symptom control or sequence addition of measures, so that the effectiveness of combining multiple intervention methods can be assessed.
- An overall shift towards effectiveness from efficacy, moving beyond the level of proof of concept that is required for drug and device approval to a deeper level that can better inform care, cost considerations, and policy.

## Ongoing Research

We identified four ongoing studies that may add to our understanding of the relative safety and efficacy of different regimens for treatment of AUB (additional details provided in Appendix P). Two currently funded trials are exploring the effect of a pretreatment regimen, one employing misoprostol and one using norethindrone acetate, on short and long term bleeding outcomes among women undergoing placement of an LNG-IUS for treatment of heavy menstrual bleeding. A large postmarketing surveillance study of the Mirena^®^ LNG-IUS is also underway in Kazakhstan, with a planned enrollment of 1,700 participants, potentially contributing additional safety information to this body of literature. The utility and safety of new investigational agent, a selective progesterone receptor modulator (CDB-2914) that has shown promise for reducing bleeding in studies involving women with fibroids, is also currently being assessed in a study involving women with AUB.

## Future Research Needs

While the number of informative studies that could be designed is likely limitless, we list examples, grouped by indication and intervention, of types of studies that could resolve current and pressing gaps in knowledge.

### Irregular Uterine Bleeding

- Development of a body of literature that examines benefits of exercise and weight loss focused on improving bleeding patterns in women with irregular bleeding that results from failed, mistimed, or poor-quality ovulation.
- Continued investigation of the role that insulin sensitizing and glycemic control agents like metformin and exenatide have on improving irregular bleeding patterns.
- Carefully controlled trials of complementary and alternative medicine interventions like acupuncture for improving menstrual regularity.
- RCTs specifically designed to assess both the heaviness and the interval of bleeding in women with irregular bleeding, which could include approaches shown to have benefit for heavy cyclic bleeding.

### Abnormal Cyclic Uterine Bleeding

- Investigate the epidemiology and natural history of heavy menstrual bleeding in representative primary care populations in order to better understand the boundaries of what constitutes normal bleeding patterns and to document the trajectory of AUB. This would for instance, contribute data about what factors predict severity and whether a proportion of cases are self-limited.
- Determine whether harms reported to be associated with treatments for heavy bleeding result because a causal contributor to the heavy bleeding is also related to the harm. For instance abnormalities in coagulation may enhance risk of DVT and be associated with heavy menses. Analyses for such confounding by indication may better assess risk of harms and predictors of response.
- Across specific interventions, additional research and analysis is needed to determine which individuals are most likely to respond to which interventions. This could develop from personalized medicine approaches, from better understanding of the mechanisms underpinning AUB, or from predictive modeling in large datasets.
- Assess the acceptability and cost-effectiveness of various treatments in the primary care setting in the United States including LNG-IUS, NSAID, COCs and TXA.
- Determine the most valid and accurate indirect measures of MBL that can be used in primary care settings and that correlate with objective direct measures.

#### Progesterone Containing IUDs Including the LNG-IUS

- Establish a registry of LNG-IUS users in the United States for extended followup of potential harms and preventive effects (e.g., reduced risk of endometrial cancer, anemia).
- Extend postmarketing surveillance to assure safety when used in teens and nulliparous patients.
- Examine costs in light of whether the treatment simultaneously resolves bleeding complaints and provides contraception.

#### NSAIDs

- Directly compare classes of NSAIDs including commonly available over-the-counter preparations.
- Conduct long-term effectiveness studies to determine if treatment effects are durable or wane over time.
- Model the costs of treatment with varied NSAID dosing strategies.
- Determine if “pre-loading” in the days before onset of menses significantly reduces menstrual bleeding alone and in combination with NSAIDs after onset of menstrual bleeding.

#### COCs

- Conduct direct comparisons of COCs with other AUB management strategies to better understand the relative merits of treatment options.
- Examine costs in light of whether the treatment simultaneously treats complaints and provides contraception.

#### TXA

- Establish a registry of TXA users and exploit existing large payer datasets to examine long-term followup for both effectiveness beyond 6 months and incidence of rare/uncommon adverse effects.

## Conclusions

Women who have problematic irregular or heavy cyclic menstrual bleeding have a number of treatment options available that are supported by systematic review of the research literature. These include high strength of evidence that COCs can improve menstrual regularity for women with irregular bleeding patterns. Metformin is supported by moderate strength of evidence for improving cycle regularity especially among women with PCOS. This provides both a contraceptive and a noncontraceptive option for irregular menses. Other interventions like progestogens are associated with statistically and clinically meaningful improvements from baseline patterns, however the overall evidence is insufficient from well-designed, larger studies with ability to directly compare treatment arms rather than only pre-post measures within groups.

Multiple interventions for heavy cyclic bleeding are supported by evidence that they reduce MBL. These include strong evidence that COCs are effective and moderate strength of evidence that LNG-IUS, NSAIDs, and TXA reduce bleeding relative to baseline, decrease total volume of bleeding when comparisons are made across treatment groups, and when measured, decrease days of bleeding. In direct comparisons, LNG-IUS is superior to NSAIDs. TXA is superior to NSAIDs and TXA combined with an NSAID was superior to TXA alone. Results from COC and NSAID comparisons suggest comparable effectiveness. Not all women who are treated with any of these interventions that can be effective will improve. Across agents data are sparse to evaluate long-term improvements and risk of harms.

Limitations include a predominance of small, short trials lacking standard terminology and diagnostic criteria for identifying and including women with AUB. Tools for collecting outcome data are crude (collection of sanitary products) and may contribute to a high rate of attrition. Biologic outcomes, like measured blood loss and hemoglobin or hematocrit levels, may neglect the importance of patient-reported outcomes that assess whether symptoms are considered resolved by women themselves. Nevertheless, the variety of effective options suggests many women can achieve symptom relief and will have available to them choices that address both symptoms and contraceptive or fertility desires, as well as potentially improving other symptoms like menstrual cramping.