# Ongoing Studies

Study Name Study Status Location Trial Identifier | Inclusion / Exclusion Criteria | Interventions / Groups | Sponsor | Start Date Anticipated Completion Date | Estimated Enrollment
Pretreatment With Norethindrone Acetate Prior to Levonorgestrel IUS Insertion for Heavy Menstrual Bleeding Currently recruiting United States NCT01391052 | Inclusion Criteria: Women aged 18-45 years old with heavy periods US Exclusion Criteria: Pregnant Currently using hormonal contraception or hormonal therapy History of pelvic inflammatory disease Infected abortion within the last three months Abnormal or cancerous cells of the cervix or uterus Active infection of genital organs Known or suspected breast cancer Active liver disease or tumors Allergy to levonorgestrel or norethindrone Deep vein thrombosis, pulmonary embolism, or history of arterial thromboembolic disease | Drug: Norethindrone acetate (Aygestin) pretreatment 5 mg tablets, three times a day for 21 days for 2 menstrual cycles. Other: No pretreatment. LNG-IUS is placed without norethindrone acetate pretreatment. | Scott and White Hospital & Clinic | January 2011 January 2013 | 80
Mirena Observational Program Currently recruiting Kazakhstan NCT00883662 | Inclusion Criteria: Older than 18 years with previously taken decision of their gynecologist to insert Mirena according to registered indications Exclusion Criteria: Contraindications to Mirena insertion, according to approved prescribing information. | Drug: Levonorgestrel releasing intrauterine device (Mirena, BAY86-5028) | Bayer | June 2009 April 2014 | 7500
Multicenter Study to Investigate the Bleeding Profile and the Insertion Easiness in Women Inserted With a Second Consecutive MIRENA for Contraception or Menorrhagia Ongoing but not recruiting Finland, France, Ireland, Sweden NCT00393198 | Inclusion Criteria: Woman currently using MIRENA for contraception or menorrhagia with duration use between 4 years 3 months and 4 years 9 months and willingness to continue with the method. Normal size uterus at insertion (6-10 cm) Clinically normal cervical smear result within 12 preceding months or at screening. Clinically normal breast examination findings. Exclusion Criteria: Menopausal symptoms impairing patient's quality of life or current estrogen therapy for menopausal symptoms. Known or suspected pregnancy. Any distortion of the uterine cavity, including congenital or acquired uterine anomalies and fibroids Current or recurrent pelvic inflammatory disease. Abnormal uterine bleeding of unknown origin. Acute cervicitis or vaginitis not responding to treatment. History of, diagnosed or suspected genital or other malignancy (excluding treated squamous cell carcinoma of the skin), and untreated cervical dysplasia. Any active acute liver disease or liver tumor. Publications: Heikinheimo O, Inki P, Kunz M, Parmhed S, Anttila AM, Olsson SE, Hurskainen R, Gemzell-Danielsson K. Double-blind, randomized, placebo-controlled study on the effect of misoprostol on ease of consecutive insertion of the levonorgestrel-releasing intrauterine system. Contraception. 2010 Jun;81(6):481-6. Epub 2010 Mar 1. Gemzell-Danielsson K, Inki P, Boubli L, O'Flynn M, Kunz M, Heikinheimo O. Bleeding pattern and safety of consecutive use of the levonorgestrel-releasing intrauterine system (LNG-IUS)--a multicentre prospective study. Hum Reprod. 2010 Feb;25(2):354-9. Epub 2009 Dec 1. | Drug: Mirena (BAY86-5028) Removal of first MIRENA and insertion of the second MIRENA at entry visit. Removal of MIRENA (in vitro release rate 20 μg/24 h) at year 5 visit. Drug: Cytotec, single, sublingual dose of 400 μg, 3 hours prior to the MIRENA removal and insertion procedure at entry visit Drug: Placebo - single, sublingual dose, 3 hours prior to the MIRENA removal and insertion procedure at entry visit | Bayer | October 2006 September 2012 | 204
Evaluation of Whether the Selective Progesterone Receptor Modulator CDB-2914 Can Reduce Bleeding in Premenopausal Women With Abnormal Uterine Bleeding: A Pilot Study Not yet recruiting United States NCT01493791 | Inclusion Criteria: Women aged 25-40 years in good health History of abnormal uterine bleeding (anovulatory and ovulatory) documented by menorrhagia impact questionnaire (MIQ) and menstrual calendar Ovulatory women will be defined as those who have menstrual cycles of 24 - 35 days and a progesterone value > 3.0 pg/mL between 5 and 9 days after in-home documentation of an LH surge Anovulatory women will be defined as those without an in-house LH surge in whom progesterone values 3 and 4 weeks after menses are < 3.0 ng/mL Hemoglobin > 10 g/dL (for those wishing surgery) Willing and able to comply with study requirements Using mechanical (condoms, diaphragms), sterilization or abstinence methods of contraception for the duration of the study Negative urine pregnancy test BMI less than or equal to 33, if a surgical candidate or less than or equal to 35, if not a surgical candidate. Creatinine less than 1.3 mg/dL Liver function tests within 130 percent of upper limit Women who elect surgery must state that they do not desire further fertility. Endometrial biopsy without endometrial hyperplasia or neoplasia Normal cervical cytology screening within the last 12 months Exclusion Criteria: Significant abnormalities in the history, physical or laboratory examination Pregnancy or lactation Use of oral, injectable or inhaled glucocorticoids or megesterol within the last year History of malignancy within the past 5 years Vaginal bleeding in context of anatomic abnormality, endometrial neoplasia or hyperplasia, cervical, vaginal, or vulvar neoplasia or preneoplastic pathology Use of estrogen or progesterone-containing compounds Current use of agents known to induce hepatic P450 enzymes Use of imidazoles Current use of GnRH analogs or other compounds that affect menstrual cyclicity Use of herbal medication having estrogenic or antiestrogenic effects within the past 3 months Untreated cervical dysplasia Need for interval use of narcotics Abnormal adnexal/ovarian mass Contradiction to anesthesia, for women planning surgery Leiomyomata, polyps or other anatomic causes of vaginal bleeding Previous participation in the study Thrombocytopenia defined as platelets < 150,000 Publications: Batista MC, Cartledge TP, Zellmer AW, Merino MJ, Axiotis C, Loriaux DL, Nieman LK. Delayed endometrial maturation induced by daily administration of the antiprogestin RU 486: a potential new contraceptive strategy. Am J Obstet Gynecol. 1992 Jul;167(1):60-5. Bushnell DM, Martin ML, Moore KA, Richter HE, Rubin A, Patrick DL. Menorrhagia Impact Questionnaire: assessing the influence of heavy menstrual bleeding on quality of life. Curr Med Res Opin. 2010 Dec;26(12):2745-55. Epub 2010 Nov 3. Cadepond F, Ulmann A, Baulieu EE. RU486 (mifepristone): mechanisms of action and clinical uses. Annu Rev Med. 1997;48:129-56. Review. | Drug: CDB-2914 | Bayer | November 2011 August 2014 | 50

DNG = dienogest; EV = estradiol valerate; GnRH: gonadotropin-releasing hormone; LNG-IUS = levonorgestrel-releasing intrauterine system; TXA = tranexamic acid. MPA: medroxyprogesterone; DMPA: depot medroxyprogesterone