# Labeled Indications for Drugs Included in Review

Generic Name, Route of Administration | Brand Name(s) (approval date)^1^ | Labeled Indications^1^
Intrauterine Device
Levonorgestrel-releasing intrauterine system (52 mg, releasing ∼0.02 mg/day) (LNG-IUS; intrauterine device) | Mirena®^2^ (December 6, 2000) | - Intrauterine contraception for up to 5 years.; - Treatment of heavy menstrual bleeding for women who choose to use intrauterine contraception as their method of contraception.; Mirena [package insert]. Wayne, NJ: Bayer HealthCare Pharmaceuticals; 2009. Daily Med (Mirena) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=92231d6f-f4d8-43b0-aa95-f7cec1cc18c5
Contraceptive vaginal ring (etonogestrel/ethinyl estradiol vaginal ring, delivers 0.120 mg/0.015 mg per day) | NuvaRing®^2^ (October 3, 2001) | - Prevention of pregnancy.; NuvaRing [package insert]. Whitehouse Station, NJ: Merck & Co; 2012. DailyMed (NuvaRing) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=017343fb-86c4-45ab-9c47-52cc5b9f3a02
Antifibrinolytic Agents
Tranexamic acid (650 mg) (oral) | Lysteda®^2^ (November 13, 2009) | - Treatment of cyclic heavy menstrual bleeding.; Lysteda [package insert]. Parsippany, NJ: Ferring Pharmaceutical; 2011. DailyMed (Lysteda)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=84a65305-65d7-e7fd-66f3-dda8d8f920b1
Combined Oral Contraceptive Agents (COCs)
Estradiol valerate and dienogest (oral) 28 tablets in the following order: 2 tablets of 3 mg EV; 5 tablets of 2 mg EV and 2 mg D; 17 tablets of 2 mg EV and 3 mg D; 2 tablets of 1 mg EV; and 2 inert tablets. | Natazia®^2^ (May 6, 2010) | - Prevent pregnancy.; - Treatment of heavy menstrual bleeding in women without organic pathology who choose to use an oral contraceptive as their method of contraception.; Natazia [package insert]. Wayne, NJ: Bayer HealthCare Pharmaceuticals; 2012. DailyMed (Natazia)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=02c91fba-9c47-43ef-ac78-e82369798834
Ethinyl estradiol (0.03 mg) and levonorgestrel (0.15 mg) (oral) 28 tablets: 21 tablets of 0.030 mg EE and 0.15 mg L; and 7 inert tablets. | Nordette-28®^2^ (July 21, 1982) Levora®^3^ (December 13, 1993) Portia-28®^3^ (May 23, 2002) Altavera®^3^ (August 2, 2010) Marlissa®^3^ (February 29, 2012) | - Prevention of pregnancy.; Nordette [package insert]. Sellersville, PA: Teva Pharmaceuticals; 2010. DailyMed (Nordette)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=ef68258d-9d09-43c9-af87-bfa4b3b0ee01
Ethinyl estradiol (0.020 mg) and norethindrone acetate (1 mg) (oral) 21 tablets of 0.020 mg EE and 1 mg N. Also available as 28-day regimen with additional 7 tablets containing 75 mg ferrous fumarate (Loestrin Fe 1/20). | Loestrin 21 1/20®^3^ (October 1, 1976) Microgestin 1/20®^3^ (February 5, 2001) Junel 1/20®^3^ (May 30, 2003) Minestrin 1/20®^4^ | Loestrin:; - For the prevention of pregnancy in women who elect to use oral contraceptives as a method of contraception.; Minestrin:; - For the control of contraception.; Loestrin [package insert]. Pomona, NY: Barr harmaceuticals; 2009. DailyMed (Loestrin) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=f40605cf-9933-40d9-915a-ea6dbc0f169f Minestrin 1/20 [package insert]. Fajardo, Puerto Rico: Warner Chilcott; 2006.
Norgestimate ethinyl estradiol, triphasic (oral) 28 tablets: 7 tablets of 0.180 mg N and 0.035 mg EE; 7 tablets of 0.215 mg N and 0.035 mg EE; 7 tablets of 0.250 mg N and 0.035 mg EE; and 7 inert tablets. | Ortho Tri-Cyclen®^2^ (July 3, 1992) Tri-Sprintec®^3^ (December 29, 2003) Tri-Previfem®^3^ (March 26, 2004) LexiComp^5^ lists additional brand names. Only those detailed here are listed by the FDA as therapeutic equivalents. TriNessa is not listed in Drugs@FDA, but it does appear to be available in the US (drugstore.com). | Ortho Tri-Cyclen^2^ and Tri-Previfem^3^:; - Prevention of pregnancy in women who elect to use oral contraceptives as a method of contraception.; - Treatment of moderate acne vulgaris in females at least 15 years of age, who have no known contraindications to oral contraceptive therapy and have achieved menarche. [The drug] should be used for the treatment of acne only if the patient desires an oral contraceptive for birth control.; Tri-Sprintec^3^ labeling differs slightly on second indication:; - Treatment of moderate acne vulgaris in females, ≥15 years of age, who have no known contraindications to oral contraceptive therapy, desire contraception, have achieved menarche and are unresponsive to topical anti-acne medications.; Ortho Tri-Cyclen [package insert]. Raritan, NJ: Ortho-McNeil-Janssen Pharmaceuticals; 2010. DailyMed (Ortho Tri-Cyclen)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=384e7a40-dcbd-4908-bf5e-65abc9932973 Tri-Sprintec [package insert]. Pomona, NY: Barr Laboratories; 2009. DailyMed (Tri-Sprintec)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=843cbef6-cbfb-4a44-bb80-22930753e4c0 Tri-Previfem [package insert]. Huntsville, AL: Qualitest Pharmaceuticals; 2011. DailyMed (Tri-Previfem)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=dd15dbd7-75b7-416e-af55-1e90c2bab051
Progestogens
Dydrogesterone (10 mg) (oral) | Gynorest International brand names^5^: Dabroston; Dufaston; Duphaston; Terolut NOTE: Dydrogesterone is not currently available in the United States; the FDA lists the marketing status of dydrogesterone (Gynorest) as discontinued. The drug is available in other countries. | Reported use^5^: Treatment of progesterone deficiencies; counteract unopposed estrogen in hormone replacement therapy.
Medroxyprogesterone acetate (400 mg/mL) (injectable suspension) | Depo-Provera CI®^2^(October 29, 1992) Depo-subQ Provera 104®^2^ (December 17, 2004) | Depo-Provera CI:; - Prevention of pregnancy.; Depo-subQ Provera 104:; - Prevention of pregnancy in women of child bearing potential.; - Management of endometriosis-associated pain.; Depo-Provera CI [package insert]. New York City, NY: Parmacia and Upjohn; 2011. DailyMed (Depo-Provera)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=199cf13e-0859-4a73-9b45-e700d0cd1049 Depo-subQ Provera 104 [package insert]. New York City, NY: Pharmacia and Upjohn; 2011. DailyMed (Depo-subQ Provera)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=390087a6-f3c3-4f0b-a930-79acf412f153
Medroxyprogesterone acetate (2.5 mg, 5 mg, or 10 mg) (oral) | Provera®^2^ (June 18, 1959) | - Treatment of secondary amenorrhea and abnormal uterine bleeding due to hormonal imbalance in the absence of organic pathology, such as fibroids or uterine cancer.; - Reduce the incidence of endometrial hyperplasia in nonhysterectomized postmenopausal women receiving daily oral conjugated estrogens 0.625 mg tablets.; Provera [package insert]. New York City, NY: Pharmacia and Upjohn; 2009. DailyMed (Provera)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=a586be28-96af-4fed-a13f-9b94fd4c7405
Norethisterone [norethindrone] (5 mg) (oral) | Aygestin®^2^ (April 21, 1982) | - Treatment of secondary amenorrhea, endometriosis, and abnormal uterine bleeding due to hormonal imbalance in the absence of organic pathology, such as submucous fibroids or uterine cancer.; Aygestin [package insert]. Pomona, NY: Duramed Pharmaceuticals; 2010. DailyMed (Aygestin)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=69f5bc4b-758d-471b-ad8d-17c94f8e0963
Progesterone (4% [45 mg] or 8% [90 mg]) (vaginal gel) | Crinone®^2^ (July 31, 1997) | - Progesterone supplementation or replacement as part of an Assisted Reproductive Technology (“ART”) treatment for infertile women with progesterone deficiency.; - Secondary amenorrhea.; Crinone [package insert]. Morristown, NJ: Watson Pharma; 2011. DailyMed (Crinone)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=2c8ffbd2-6b7a-42c7-b29e-e4de69dad9e6
Progesterone (0.065 mg/day, according to multiple sources) (coil/intrauterine insert) | Progestasert (February 4, 1976) NOTE: The FDA lists the marketing status of Progestasert as discontinued as of June 1, 2001. | - Prevention of pregnancy.
Nonsteroidal Anti-inflammatory Drugs (NSAIDs)
Flurbiprofen (50 mg or 100 mg) (oral) | Ansaid®^2^ (October 31, 1988) | - For relief of the signs and symptoms of rheumatoid arthritis.; - For relief of the signs and symptoms of osteoarthritis.; Ansaid [package insert]. New York City, NY: Pfizer / Pharmacia & Upjohn Co.; 2010. DailyMed (flurbiprofen)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=f56be63c-88e4-4b78-b12d-d80e3e8b3893
Meclofenamate sodium (50 mg or 100 mg) (oral) | Meclomen (June 25, 1980) NOTE: The FDA lists the marketing status of Meclomen as discontinued. The drug is available in the US as generic. | - For the relief of mild to moderate pain.; - For the treatment of primary dysmenorrhea and for the treatment of idiopathic heavy menstrual blood loss.; - For relief of the signs and symptoms of acute and chronic rheumatoid arthritis and osteoarthritis.; Meclofenamate sodium [package insert]. Morgantown, WV: Mylan Pharmaceuticals; 2006. DailyMed (meclofenamate sodium)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=96f19af4-de8f-4fd7-90d8-55fe6ebdd81d
Mefenamic acid (250 mg) (oral) | Ponstel®^2^ (March 28, 1967) | - For relief of mild to moderate pain in patients ≥14 years of age, when therapy will not exceed one week (7 days).; - For treatment of primary dysmenorrhea.; Ponstel [package insert]. Atlanta, GA: Sciele Pharma; 2008. DailyMed (Ponstel)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=d77e13db-d1b1-4dbf-9de8-80827018cf43
Naproxen sodium (oral) Naprosyn as 250 mg, 375 mg, or 500 mg tablets; Anaprox as 275 mg tablets; Anaprox DS as 550 mg tablets; others available. | Naprosyn®^2^ (March 11, 1976) Anaprox DS®^2^ (September 4, 1980) Anaprox®^3^ (September 4, 1980) Naprosyn Suspension®^2^ (March 23, 1987) EC-Naprosyn®^2^ (October 14, 1994) Also various OTC brands | Naprosyn, EC-Naprosyn, Anaprox, Anaprox DS, and Naprosyn Suspension is indicated:; - For the relief of the signs and symptoms of rheumatoid arthritis.; - For the relief of the signs and symptoms of osteoarthritis.; - For the relief of the signs and symptoms of ankylosing spondylitis.; - For the relief of the signs and symptoms of juvenile arthritis.; Naprosyn, Anaprox, Anaprox DS, and Naprosyn Suspension is also indicated:; - For relief of the signs and symptoms of tendonitis.; - For relief of the signs and symptoms of bursitis.; - For relief of the signs and symptoms of acute gout.; - For the management of pain.; - For the management of primary dysmenorrheal.; EC-Naprosyn / Naprosyn / Anaprox / Anaprox DS / Naprosyn [package insert]. Nutley, NJ: Roche Pharmaceuticals; 1999-200X. DailyMed (Naprosyn)http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=68848217-03c9-4377-9be6-6f567e629129
Other Drugs
Cabergoline (0.5 mg) (oral) | Dostinex (December 23, 1996) NOTE: The FDA lists the marketing status of Dostinex as discontinued. The drug is available in the US as generic. | - Treatment of hyperprolactinemic disorders, either idiopathic or due to pituitary adenomas.; Cabergoline [package insert]. Sellersville, PA: Teva Pharmaceuticals; 2011. DailyMed (cabergoline) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=e497366b-a124-4d7f-bd45-a883c392d4bb
Etamsylate [ethamsylate] (250 mg or 500 mg) (oral) | International brand names^5^: Altodor; Dicinone; Dicynene; Dicynone; Eselin; Ethamsyl; Hemo 141; Hemoced; Impedil NOTE: Etamsylate is not currently available in the United States. The drug is available in other countries. | Reported use^5^: Prevention and treatment of capillary hemorrhages; treatment of menorrhagia or metrorrhagia.
Exenatide (0.25 mg/mL as either 0.005 mg or 0.01 mg per dose) (injection) | Byetta®^2^ (April 28, 2005) | - As an adjunct to diet and exercise to improve glycemic control in adults with type 2 diabetes mellitus.; Byetta [package insert]. San Diego, CA: Amylin Pharmaceuticals; 2011. DailyMed (Byetta) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=751747da-7c1f-41ad-b1a6-a6d920f70599
Metformin hydrochloride (oral) Glucophage as 500 mg, 850 mg, or 1000 mg tablets; Glucophage XR as 500 mg or 750 mg tablets; Fortamet and Glumetza as 500 mg or 1000 mg tablets. | Glucophage®^2^ (March 3, 1995) Glucophage XR®^2^ (October 13, 2000) Fortamet®^2^ (April 28, 2004) Glumetza®^2^ (June 3, 2005) | - As an adjunct to diet and exercise to improve glycemic control in adults and children with type 2 diabetes mellitus.; Glucophage [package insert]. Princeton, NJ: Bristol-Myers Squibb; 2009. DailyMed (Glucophage) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=4a0166c7-7097-4e4a-9036-6c9a60d08fc6
N-acetyl-cysteine (oral; also available as solution for inhalation, IV injection, or ocular solution) | Mucomyst (September 14, 1963; marketing discontinued) Acetadote®^2^ (injectable, IV) (January 23, 2004) Acetylcysteine is also available in tablet form as a dietary supplement under various brand names. | - Prevent or lessen hepatic injury after ingestion of acetaminophen (acute poisoning or repeated supratherapeutic ingestion).; - Adjuvant therapy for patients with abnormal, viscid, or inspissated mucous secretions in conditions such as: chronic broncopulmonary disease; acute bronchopulmonary disease; pulmonary complications of cystic fibrosis; tracheostomy care; pulmonary complications associated with surgery; during anesthesia, post-traumatic chest conditions; atelectasis due to mucous obstruction; and diagnostic bronchial studies.; Acetadote [package insert]. Nashville, TN: Cumberland Pharmaceuticals; 2011. Acetylcysteine solution [package insert]. Lake Forest, IL: Hospira, Inc.; 2004. DailyMed (Acetadote) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=472f158a-5ab9-4308-8e49-1116e6ea3d39 DailyMed (acetylcysteine solution) http://dailymed.nlm.nih.gov/dailymed/lookup.cfm?setid=5558a5f5-e821-473b-7d8a-5d33d09f0586

Notes:

1 US-based information; brand names, therapeutic equivalency, dates of approval, and indications per FDA website (Drugs@FDA) and individual package inserts, unless otherwise noted; last accessed September 4, 2012.

2 Listed by FDA as the Reference Listed Drug (RLD): an approved drug product to which new generic versions are compared to show that they are bioequivalent.

3 Listed by FDA as therapeutic equivalent to RLD.

4 Canadian brand name and approval information.

5 Lexi-Comp OnlineTM, Lexi-Drugs International OnlineTM, Hudson, Ohio: Lexi-Comp, Inc.; September 4, 2012.