# Reasons for Exclusion (KQ2)

Exclusion code | Exclusion reason | Count
X-1 | Not original research (e.g. review articles, systematic reviews, editorials, commentaries, letters to editor, etc.). | 104
X-2 | Does not include data from a population of 1600 or more. | 1916
X-3 | Reporting of harms is from a general population or reporting of harms is not an objective of the paper/study. | 913
X-4 | Does not report harms data for a selected intervention included in KQ1 (i.e., LNG-IUS; progestogen; tranexamic acid; cabergoline; ethamsylate; exenatide; metformin). | 2044
X-5 | Study is basic science, anatomy, imaging, prevalence, physiology, diagnostic, biomarker, or biological mechanism study only. | 4
X-6 | Study of men only. | 17
X-7 | Study population consists of post-menopausal women or a population aged over 65 years. | 101
X-8 | Other | 26
X-11 | Unable to obtain | 4
X-12 | Duplicate | 0

## References

1 Tranexamic acid. Med Lett Drugs Ther. Sep. 25. 1987;29(749):89-90. X-1. [pmid: 3626975].
2 Epithelial ovarian cancer and combined oral contraceptives. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Epidemiol. Sep. 1989;18(3):538-45. X-4. [pmid: 2807655].
3 Breast cancer and combined oral contraceptives: results from a multinational study. The WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Br J Cancer. Jan. 1990;61(1):110-9. X-4. [pmid: 2404507].
4 Single dose cabergoline versus bromocriptine in inhibition of puerperal lactation: randomised, double blind, multicentre study European Multicentre Study Group for Cabergoline in Lactation Inhibition. BMJ. Jun. 8. 1991;302(6789):1367-71. X-2. [pmid: 1676318].
5 Comparison of two androgens plus depot-medroxyprogesterone acetate for suppression to azoospermia in indonesian men. World Health Organization. Task Force on Methods for the Regulation of Male Fertility. Fertil Steril. Dec. 1993;60(6):1062-8. X-2, X-3, X-4. [pmid: 8243687].
6 History of long-term use of depot-medroxyprogesterone acetate in patients with cervical dysplasia; case-control analysis nested in a cohort study. The New Zealand Contraception and Health Study Group. Contraception. Nov. 1994;50(5):443-9. X-8. [pmid: 7859453].
7 Effect of different progestagens in low oestrogen oral contraceptives on venous thromboembolic disease. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. Dec. 16. 1995;346(8990):1582-8. X-4. [pmid: 7500749].
8 Haemorrhagic stroke, overall stroke risk, and combined oral contraceptives: results of an international, multicentre, case-control study. WHO Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Lancet. Aug. 24. 1996;348(9026):505-10. X-4. [pmid: 8757152].
9 Long-term reversible contraception. Twelve years of experience with the TCu380A and TCu220C. Contraception. Dec. 1997;56(6):341-52. X-2, X-4. [pmid: 9494767].
10 Premature closure of the fetal ductus arteriosus after maternal use of non-steroidal anti-inflammatory drugs. Adverse Drug Reactions Advisory Committee. Med J Aust. Sep. 7. 1998;169(5):270-1. X-2. [pmid: 9762067].
11 Are adult drugs cool for kids?. Diabetes Obes Metab. Oct. 2001;3(5):383. X-1. [pmid: 11710340].
12 Venous thrombosis with cyproterone. Prescrire Int. Aug. 2002;11(60):116. X-1. [pmid: 12199266].
13 Coxibs: no better than other NSAIDS. Prescrire Int. Dec. 2004;13(74):226. X-1. [pmid: 15612145].
14 Analysis and recommendations for agency action regarding nonsteroidal antiinflammatory drugs and cardiovascular risk. J Pain Palliat Care Pharmacother. 2005;19(4):83-97. X-1. [pmid: 16431839].
15 Drug-induced male infertility. Prescrire Int. Feb. 2007;16(87):22. X-4, X-6. [pmid: 17323530].
16 Drospirenone: high risk of venous thrombosis. Prescrire Int. Feb. 2011;20(113):43-5. X-1. [pmid: 21488592].
17 Aabakken L, Weberg R, Lygren I, et al. Gastrointestinal bleeding: dyspeptic symptoms and clinical course in relation to use of non-steroidal antiinflammatory drugs. Scand J Rheumatol. 1991;20(5):366-9. X-2. [pmid: 1947900].
18 Aabakken L, Weberg R, Lygren I, et al. Gastrointestinal bleeding associated with the use of non-steroidal, anti-inflammatory drugs--symptomatology and clinical course. Agents Actions. 1992;(Spec No):C86-7. X-2, X-4. [pmid: 1442342].
19 Aalykke C, Lauritsen JM, Hallas J, et al. Helicobacter pylori and risk of ulcer bleeding among users of nonsteroidal anti-inflammatory drugs: a case-control study. Gastroenterology. Jun. 1999;116(6):1305-9. X-2, X-3, X-4. [pmid: 10348813].
20 Aarsand AK, Carlsen SM. Folate administration reduces circulating homocysteine levels in NIDDM patients on long-term metformin treatment. J Intern Med. Aug. 1998;244(2):169-74. X-2, X-3, X-4. [pmid: 10095804].
21 Abbasi AA, Kasmikha R, Sotingeanu DG. Metformin-induced lacticacidemia in patients with type 2 diabetes mellitus. Endocr Pract. Nov-Dec. 2000;6(6):442-6. X-2. [pmid: 11155215].
22 Abbasi S, Gerdes JS, Sehdev HM, et al. Neonatal outcome after exposure to indomethacin in utero: a retrospective case cohort study. Am J Obstet Gynecol. Sep. 2003;189(3):782-5. X-2, X-4. [pmid: 14526313].
23 Abdala C. Effects of aspirin on distortion product otoacoustic emission suppression in human adults: a comparison with neonatal data. J Acoust Soc Am. Sep. 2005;118(3 Pt 1):1566-75. X-4. [pmid: 16240817].
24 Abid S, Mumtaz K, Jafri W, et al. Pill-induced esophageal injury: endoscopic features and clinical outcomes. Endoscopy. Aug. 2005;37(8):740-4. X-2. [pmid: 16032493].
25 Abraham NS, Castillo DL, Hartman C. National mortality following upper gastrointestinal or cardiovascular events in older veterans with recent nonsteroidal anti-inflammatory drug use. Aliment Pharmacol Ther. Jul. 2008;28(1):97-106. X-4, X-7. [pmid: 18397385].
26 Abraham NS, Cohen DC, Rivers B, et al. Validation of administrative data used for the diagnosis of upper gastrointestinal events following nonsteroidal anti-inflammatory drug prescription. Aliment Pharmacol Ther. Jul. 15. 2006;24(2):299-306. X-2, X-3, X-4. [pmid: 16842456].
27 Abraham NS, Hartman C, Hasche J. Reduced hospitalization cost for upper gastrointestinal events that occur among elderly veterans who are gastroprotected. Clin Gastroenterol Hepatol. Apr. 2010;8(4):350-6. quiz e45. X-4, X-7. [pmid: 20096378].
28 Abraham S, Luscombe G, Soo I. Oral contraception and cyclic changes in premenstrual and menstrual experiences. J Psychosom Obstet Gynaecol. Sep. 2003;24(3):185-93. X-2, X-3, X-4. [pmid: 14584305].
29 Abramov Y, Borik S, Yahalom C, et al. Does postmenopausal hormone replacement therapy affect intraocular pressure?. J Glaucoma. Aug. 2005;14(4):271-5. X-2, X-4. [pmid: 15990606].
30 Abs R, Verhelst J, Maiter D, et al. Cabergoline in the treatment of acromegaly: a study in 64 patients. J Clin Endocrinol Metab. Feb. 1998;83(2):374-8. X-2. [pmid: 9467544].
31 Acharya M, Dunning J. Does the use of non-steroidal anti-inflammatory drugs after cardiac surgery increase the risk of renal failure?. Interact Cardiovasc Thorac Surg. Oct. 2010;11(4):461-7. X-2, X-4. [pmid: 20639308].
32 Achkar JP, Al-Haddad M, Lashner B, et al. Differentiating risk factors for acute and chronic pouchitis. Clin Gastroenterol Hepatol. Jan. 2005;3(1):60-6. X-2, X-3. [pmid: 15645406].
33 Adams HP Jr., Nibbelink DW, Torner JC, et al. Antifibrinolytic therapy in patients with aneurysmal subarachnoid hemorrhage. A report of the cooperative aneurysm study. Arch Neurol. Jan. 1981;38(1):25-9. X-2, X-3, X-4. [pmid: 7458720].
34 Adeyemi AS, Adekanle DA. Progestogen-only injectable contraceptive: experience of women in Osogbo, southwestern Nigeria. Ann Afr Med. Jan-Mar. 2012;11(1):27-31. X-2. [pmid: 22199044].
35 Adhiyaman V, Asghar M, Oke A, et al. Nephrotoxicity in the elderly due to co-prescription of angiotensin converting enzyme inhibitors and nonsteroidal anti-inflammatory drugs. J R Soc Med. Oct. 2001;94(10):512-4. X-2. [pmid: 11581344].
36 Affandi B, Santoso SS, Djajadilaga, et al. Five-year experience with Norplant. Contraception. Oct. 1987;36(4):417-28. X-2, X-3, X-4. [pmid: 3127111].
37 Agrawal A, Gerson CR, Seligman I, et al. Postoperative hemorrhage after tonsillectomy: use of ketorolac tromethamine. Otolaryngol Head Neck Surg. Mar. 1999;120(3):335-9. X-2, X-4. [pmid: 10064634].
38 Agrawal NM, Patel R, Mahatma M, et al. Nonsteroidal anti-inflammatory drugs and acute upper gastrointestinal bleeding: a prospective study. J Assoc Acad Minor Phys. 1991;2(2):64-6. X-2. [pmid: 1810582].
39 Agrawal NM, Roth S, Graham DY, et al. Misoprostol compared with sucralfate in the prevention of nonsteroidal anti-inflammatory drug-induced gastric ulcer. A randomized, controlled trial. Ann Intern Med. Aug. 1. 1991;115(3):195-200. X-2, X-3, X-4. [pmid: 1905501].
40 Aguas M, Pons M, Barrera N, et al. Prevention of non-steroidal antiinflammatory drugs-induced gastropathy: follow up of protocol adherence. Rev Esp Enferm Dig. Nov. 2002;94(11):679-86. X-2. [pmid: 12690991].
41 Aguilar C, Reza A, Garcia JE, et al. Biguanide related lactic acidosis: incidence and risk factors. Arch Med Res. Spring. 1992;23(1):19-24. X-2, X-4. [pmid: 1308787].
42 Ahmed YI, Azeem S, Khan O, et al. Stevens Johnson syndrome in Pakistan: a ten-year survey. J Pak Med Assoc. Jun. 2004;54(6):312-5. X-2, X-4. [pmid: 15366796].
43 Ahsberg K, Hoglund P, Kim WH, et al. Impact of aspirin, NSAIDs, warfarin, corticosteroids and SSRIs on the site and outcome of non-variceal upper and lower gastrointestinal bleeding. Scand J Gastroenterol. Dec. 2010;45(12):1404-15. X-2, X-4. [pmid: 20695720].
44 Ahsberg K, Hoglund P, Stael von Holstein C. Mortality from peptic ulcer bleeding: the impact of comorbidity and the use of drugs that promote bleeding. Aliment Pharmacol Ther. Sep. 2010;32(6):801-10. X-2, X-4. [pmid: 20653635].
45 AinMelk Y. Comparison of two continuous combined estrogen progestogen regimens in postmenopausal women: a randomized trial. Fertil Steril. Dec. 1996;66(6):962-8. X-2, X-4. [pmid: 8941062].
46 Aisien AO. Intrauterine contraceptive device (IUCD): acceptability and effectiveness in a tertiary institution. Afr J Med Med Sci. Sep. 2007;36(3):193-200. X-4. [pmid: 18390056].
47 Aisien AO, Enosolease ME. Haemostatic function in Norplant (levonorgestrel) users: a 3-year prospective experience in Benin-City, Nigeria. Niger Postgrad Med J. Jun. 2009;16(2):126-31. X-2. [pmid: 19606192].
48 Aisien AO, Enosolease ME, Shobowale MO. Evaluation of haemostatic function in Nigerian Norplant acceptors after 12 months of use. J Obstet Gynaecol. May. 2005;25(4):377-81. X-2, X-3, X-4. [pmid: 16091325].
49 Aisien AO, Sagay AS, Imade GE, et al. Changes in menstrual and haematological indices among Norplant acceptors. Contraception. Apr. 2000;61(4):283-6. X-4. [pmid: 10899486].
50 Aithal PG, Day CP. The natural history of histologically proved drug induced liver disease. Gut. May. 1999;44(5):731-5. X-2, X-3, X-4. [pmid: 10205214].
51 Aizen E, Kagan G, Assy B, et al. Effect of non-steroidal anti-inflammatory drugs on natural killer cell activity in patients with dementia. Isr Med Assoc J. Feb. 2005;7(2):78-81. X-2, X-3, X-4. [pmid: 15729955].
52 Akhtar AJ, Shaheen M. Upper gastrointestinal toxicity of nonsteroidal anti-inflammatory drugs in African-American and Hispanic elderly patients. Ethn Dis. Fall. 2003;13(4):528-33. X-2. [pmid: 14632273].
53 Akhtar AJ, Shaheen MA. For the patient. Treating pain without causing complications. Ethn Dis. Fall. 2003;13(4):550. X-1. [pmid: 14632282].
54 Akima S, Kent A, Reynolds GJ, et al. Indomethacin and renal impairment in neonates. Pediatr Nephrol. May. 2004;19(5):490-3. X-4. [pmid: 15007713].
55 Akre K, Ekstrom AM, Signorello LB, et al. Aspirin and risk for gastric cancer: a population-based case-control study in Sweden. Br J Cancer. Apr. 6. 2001;84(7):965-8. X-4. [pmid: 11286478].
56 Akyol-Salman I, Lece-Sertoz D, Baykal O. Topical pranoprofen 0.1% is as effective anti-inflammatory and analgesic agent as diclofenac sodium 0.1% after strabismus surgery. J Ocul Pharmacol Ther. Jun. 2007;23(3):280-3. X-2, X-3, X-4. [pmid: 17593012].
57 al-Alaiyan S, Seshia MM, Casiro OG. Neurodevelopmental outcome of infants exposed to indomethacin antenatally. J Perinat Med. 1996;24(4):405-11. X-2, X-4. [pmid: 8880639].
58 Alam S, Purdie DM, Johnson AG. Evaluation of the potential interaction between NaCl and prostaglandin inhibition in elderly individuals with isolated systolic hypertension. J Hypertens. Aug. 1999;17(8):1195-202. X-2, X-3, X-4. [pmid: 10466476].
59 Al-Amro SA, Al-Kharfi TM, Thabit AA, et al. Risk factors for acute retinopathy of prematurity. Ann Ophthalmol (Skokie). Spring. 2007;39(2):107-11. X-2, X-4. [pmid: 17984498].
60 al-Assi MT, Genta RM, Karttunen TJ, et al. Ulcer site and complications: relation to Helicobacter pylori infection and NSAID use. Endoscopy. Feb. 1996;28(2):229-33. X-2. [pmid: 8739738].
61 Al-Azzam SI, AlMahasneh F, Mhaidat N, et al. Prophylactic use of aspirin does not induce anaemia among adults. J Clin Pharm Ther. Aug. 2010;35(4):415-9. X-4. [pmid: 20853549].
62 Albengres E. Features of the French postmarketing drug surveillance system. Application to cutaneous effects of nonsteroidal antiinflammatory drugs. J Rheumatol Suppl. Oct. 1988;17:20-3. X-1, X-2, X-3, X-4. [pmid: 3204616].
63 Albu S, Tomescu E, Mexca Z, et al. Recurrence rates in endonasal surgery for polyposis. Acta Otorhinolaryngol Belg. 2004;58(1):79-86. X-2. [pmid: 15517841].
64 Aldoori WH, Giovannucci EL, Rimm EB, et al. Use of acetaminophen and nonsteroidal anti-inflammatory drugs: a prospective study and the risk of symptomatic diverticular disease in men. Arch Fam Med. May-Jun. 1998;7(3):255-60. X-6. [pmid: 9596460].
65 Aldrete JA. Epidural injections of indomethacin for postlaminectomy syndrome: a preliminary report. Anesth Analg. Feb. 2003;96(2):463-8. table of contents. X-2, X-4. [pmid: 12538197].
66 Aldrink JH, Ma M, Wang W, et al. Safety of ketorolac in surgical neonates and infants 0 to 3 months old. J Pediatr Surg. Jun. 2011;46(6):1081-5. X-2, X-4. [pmid: 21683202].
67 Alexandersen P, Byrjalsen I, Christiansen C. Piperazine oestrone sulphate and interrupted norethisterone in postmenopausal women: effects on bone mass, lipoprotein metabolism, climacteric symptoms, and adverse effects. BJOG. Mar. 2000;107(3):356-64. X-2, X-4. [pmid: 10740332].
68 Alexandersen P, Haarbo J, Christiansen C. Impact of combined hormone replacement therapy on serum lipid metabolism: new aspects. Gynecol Endocrinol. Aug. 1997;11(4):281-8. X-2, X-4. [pmid: 9272426].
69 Alexandersen P, Riis BJ, Christiansen C. Monofluorophosphate combined with hormone replacement therapy induces a synergistic effect on bone mass by dissociating bone formation and resorption in postmenopausal women: a randomized study. J Clin Endocrinol Metab. Sep. 1999;84(9):3013-20. X-2, X-3, X-4. [pmid: 10487657].
70 Alexopoulou A, Dourakis SP, Mantzoukis D, et al. Adverse drug reactions as a cause of hospital admissions: a 6-month experience in a single center in Greece. Eur J Intern Med. Nov. 2008;19(7):505-10. X-2. [pmid: 19013378].
71 Aljadhey H, Tu W, Hansen RA, et al. Risk of hyperkalemia associated with selective COX-2 inhibitors. Pharmacoepidemiol Drug Saf. Nov. 2010;19(11):1194-8. X-2, X-4. [pmid: 20842761].
72 Allen B, Edwards IR. A safety profile of controlled release naproxen tablets. N Z Med J. Jun. 28. 1989;102(870):310-2. X-2, X-4. [pmid: 2662065].
73 Allen LaPointe NM, Kramer JM, DeLong ER, et al. Patient-reported frequency of taking aspirin in a population with coronary artery disease. Am J Cardiol. May. 1. 2002;89(9):1042-6. X-3, X-4. [pmid: 11988192].
74 Allonen H, Luukkainen T, Nielsen NC, et al. Factors affecting the clinical performance of Nova T and Copper T 200. Obstet Gynecol. Oct. 1984;64(4):524-9. X-3, X-4. [pmid: 6384847].
75 Allred J, Wong W, Kafetz K. Elderly people taking non-steroidal anti-inflammatory drugs are unlikely to have excess renal impairment. Postgrad Med J. Oct. 1989;65(768):735-7. X-2, X-4. [pmid: 2616399].
76 al-Momen AK, al-Meshari A, al-Nuaim L, et al. Intravenous iron sucrose complex in the treatment of iron deficiency anemia during pregnancy. Eur J Obstet Gynecol Reprod Biol. Nov. 1996;69(2):121-4. X-2, X-4. [pmid: 8902444].
77 Alobid I, Benitez P, Bernal-Sprekelsen M, et al. The impact of asthma and aspirin sensitivity on quality of life of patients with nasal polyposis. Qual Life Res. Apr. 2005;14(3):789-93. X-2, X-3, X-4. [pmid: 16022071].
78 Alsheikh-Ali AA, Abourjaily HM, Karas RH. Risk of adverse events with concomitant use of atorvastatin or simvastatin and glucose-lowering drugs (thiazolidinediones, metformin, sulfonylurea, insulin, and acarbose). Am J Cardiol. Jun. 1. 2002;89(11):1308-10. X-4. [pmid: 12031736].
79 Alvares JF, Kulkarni SG, Bhatia SJ, et al. Prospective evaluation of medication-induced esophageal injury and its relation to esophageal function. Indian J Gastroenterol. Jul-Sep. 1999;18(3):115-7. X-2, X-4. [pmid: 10407565].
80 Alvarez C, Marti-Bonmati L, Novella-Maestre E, et al. Dopamine agonist cabergoline reduces hemoconcentration and ascites in hyperstimulated women undergoing assisted reproduction. J Clin Endocrinol Metab. Aug. 2007;92(8):2931-7. X-2. [pmid: 17456571].
81 Alvarez F, Brache V, Tejada AS, et al. Sex hormone binding globulin and free levonorgestrel index in the first week after insertion of Norplant implants. Contraception. Oct. 1998;58(4):211-4. X-2, X-3, X-4. [pmid: 9866001].
82 Alvarez-Sanchez F, Brache V, Thevenin F, et al. Hormonal treatment for bleeding irregularities in Norplant implant users. Am J Obstet Gynecol. Mar. 1996;174(3):919-22. X-2, X-3, X-4. [pmid: 8633669].
83 Amar YG, Frenkiel S, Sobol SE. Outcome analysis of endoscopic sinus surgery for chronic sinusitis in patients having Samter's triad. J Otolaryngol. Feb. 2000;29(1):7-12. X-2, X-3, X-4. [pmid: 10709165].
84 Ambegaonkar A, Livengood K, Craig T, et al. Predicting the risk for gastrointestinal toxicity in patients taking NSAIDs: the Gastrointestinal Toxicity Survey. Adv Ther. Sep-Oct. 2004;21(5):288-300. X-2. [pmid: 15727398].
85 Amin SB, Kamaluddeen M, Sangem M. Neurodevelopmental outcome of premature infants after exposure to antenatal indomethacin. Am J Obstet Gynecol. Jul. 2008;199(1):41 e1-8. X-2, X-4. [pmid: 18455131].
86 Andersch B, Milsom I, Rybo G. An objective evaluation of flurbiprofen and tranexamic acid in the treatment of idiopathic menorrhagia. Acta Obstet Gynecol Scand. 1988;67(7):645-8. X-2. [pmid: 3073625].
87 Andersen H, Jacobsen BB, Kastrup KW, et al. Treatment of girls with excessive height prediction. Follow-up of forty girls treated with intramuscular estradiol and progesterone. Acta Paediatr Scand. May. 1980;69(3):293-7. X-2, X-3, X-4. [pmid: 7376855].
88 Andersen V, Ostergaard M, Christensen J, et al. Polymorphisms in the xenobiotic transporter Multidrug Resistance 1 (MDR1) and interaction with meat intake in relation to risk of colorectal cancer in a Danish prospective case-cohort study. BMC Cancer. 2009;9:407. X-2, X-3. [pmid: 19930591].
89 Andersohn F, Schade R, Suissa S, et al. Cyclooxygenase-2 selective nonsteroidal anti-inflammatory drugs and the risk of ischemic stroke: a nested case-control study. Stroke. Jul. 2006;37(7):1725-30. X-4. [pmid: 16728684].
90 Andersohn F, Suissa S, Garbe E. Use of first- and second-generation cyclooxygenase-2-selective nonsteroidal antiinflammatory drugs and risk of acute myocardial infarction. Circulation. Apr. 25. 2006;113(16):1950-7. X-4. [pmid: 16618816].
91 Anderson GL, Chlebowski RT, Rossouw JE, et al. Prior hormone therapy and breast cancer risk in the Women's Health Initiative randomized trial of estrogen plus progestin. Maturitas. Sep. 20. 2006;55(2):103-15. X-7. [pmid: 16815651].
92 Anderson M, Bedi SS, Boston PF, et al. A long-term study of flurbiprofen sustained-release. Br J Clin Pract. Jan. 1988;42(1 Suppl):15-8. X-2. [pmid: 3196643].
93 Andersson K, Batar I, Rybo G. Return to fertility after removal of a levonorgestrel-releasing intrauterine device and Nova-T. Contraception. Dec. 1992;46(6):575-84. X-2, X-4. [pmid: 1493717].
94 Andolsek KM, Burkman RT Jr., Kafrissen ME, et al. Metabolic effects and efficacy of a triphasic oral contraceptive (norgestimate/ethinyl estradiol). Int J Fertil Menopausal Stud. Suppl 3. 1993;38:122-5. X-11. [pmid: 8260970].
95 Andolsek L, Kovacic J, Kozuh M, et al. Influence of oral contraceptives on the incidence of premalignant and malignant lesions of the cervix. Contraception. Dec. 1983;28(6):505-19. X-4. [pmid: 6673904].
96 Andrade P, Brinca A, Goncalo M. Patch testing in fixed drug eruptions--a 20-year review. Contact Dermatitis. Oct. 2011;65(4):195-201. X-2. [pmid: 21702758].
97 Andriessen P, Struis NC, Niemarkt H, et al. Furosemide in preterm infants treated with indomethacin for patent ductus arteriosus. Acta Paediatr. May. 2009;98(5):797-803. X-2, X-3, X-4. [pmid: 19187396].
98 Anker SD, Comin Colet J, Filippatos G, et al. Ferric carboxymaltose in patients with heart failure and iron deficiency. N Engl J Med. Dec. 17. 2009;361(25):2436-48. X-2, X-3, X-4. [pmid: 19920054].
99 Anstee P, Kovacs GT. A prospective randomized study comparing the clinical effects of a norethisterone and a levonorgestrel containing low dose oestrogen oral contraceptive pills. Aust N Z J Obstet Gynaecol. Feb. 1993;33(1):81-3. X-2. [pmid: 8498949].
100 Anthuber S, Schramm GA, Heskamp ML. Six-month evaluation of the benefits of the low-dose combined oral contraceptive chlormadinone acetate 2 mg/ethinylestradiol 0.03 mg in young women: results of the prospective, observational, non-interventional, multicentre TeeNIS study. Clin Drug Investig. 2010;30(4):211-20. X-4. [pmid: 20225905].
101 Antonucci R, Cuzzolin L, Arceri A, et al. Changes in urinary PGE2 after ibuprofen treatment in preterm infants with patent ductus arteriosus. Eur J Clin Pharmacol. Mar. 2009;65(3):223-30. X-2, X-4. [pmid: 19048246].
102 Anwar M. An evaluation of IUD insertion by a non-clinical delivery system. Adv Contracept. Dec. 1992;8(4):303-12. X-2. [pmid: 1290332].
103 Araujo E Jr., Bernardini L, Frederick JL, et al. Prospective randomized comparison of human chorionic gonadotropin versus intramuscular progesterone for luteal-phase support in assisted reproduction. J Assist Reprod Genet. Feb. 1994;11(2):74-8. X-2, X-4. [pmid: 7819706].
104 Arboleya LR, de la Figuera E, Soledad Garcia M, et al. Experience of rofecoxib in patients with osteoarthritis previously treated with traditional non-steroidal anti-inflammatory drugs in Spain: results of phase 2 of the VICOXX study. Curr Med Res Opin. 2003;19(4):288-97. X-2, X-3, X-4. [pmid: 12841921].
105 Archer DF, Dorin M, Lewis V, et al. Effects of lower doses of conjugated equine estrogens and medroxyprogesterone acetate on endometrial bleeding. Fertil Steril. Jun. 2001;75(6):1080-7. X-7. [pmid: 11384630].
106 Archer DF, Dorin MH, Heine W, et al. Uterine bleeding in postmenopausal women on continuous therapy with estradiol and norethindrone acetate. Endometrium Study Group. Obstet Gynecol. Sep. 1999;94(3):323-9. X-2, X-4. [pmid: 10472853].
107 Archer DF, Furst K, Tipping D, et al. A randomized comparison of continuous combined transdermal delivery of estradiol-norethindrone acetate and estradiol alone for menopause. CombiPatch Study Group. Obstet Gynecol. Oct. 1999;94(4):498-503. X-2, X-4. [pmid: 10511348].
108 Archer DF, Philput CA, Weber ME. Management of irregular uterine bleeding and spotting associated with Norplant. Hum Reprod. Oct. Suppl 2. 1996;11:24-30. X-2, X-4. [pmid: 8982742].
109 Archer DF, Pickar JH. Hormone replacement therapy: effect of progestin dose and time since menopause on endometrial bleeding. Obstet Gynecol. Dec. 2000;96(6):899-905. X-4, X-7. [pmid: 11084175].
110 Archer DF, Pickar JH, Bottiglioni F. Bleeding patterns in postmenopausal women taking continuous combined or sequential regimens of conjugated estrogens with medroxyprogesterone acetate. Menopause Study Group. Obstet Gynecol. May. 1994;83(5 Pt 1):686-92. X-7. [pmid: 8164926].
111 Archimandritis A, Tzivras M, Sougioultzis S, et al. Rapid urease test is less sensitive than histology in diagnosing Helicobacter pylori infection in patients with non-variceal upper gastrointestinal bleeding. J Gastroenterol Hepatol. Apr. 2000;15(4):369-73. X-2, X-3, X-4. [pmid: 10824879].
112 Ardizzone S, Maconi G, Russo A, et al. Randomised controlled trial of azathioprine and 5-aminosalicylic acid for treatment of steroid dependent ulcerative colitis. Gut. Jan. 2006;55(1):47-53. X-2, X-3, X-4. [pmid: 15972298].
113 Arellano FM, Yood MU, Wentworth CE, et al. Use of cyclo-oxygenase 2 inhibitors (COX-2) and prescription non-steroidal anti-inflammatory drugs (NSAIDS) in UK and USA populations. Implications for COX-2 cardiovascular profile. Pharmacoepidemiol Drug Saf. Dec. 2006;15(12):861-72. X-4. [pmid: 17086563].
114 Argina H, Lukman HY. Norplant implants in Ethiopia. East Afr Med J. Apr. 1997;74(4):258-62. X-2, X-3, X-4. [pmid: 9299831].
115 Armero C, Garcia-Donato G, Lopez-Quilez A. Bayesian methods in cost-effectiveness studies: objectivity, computation and other relevant aspects. Health Econ. Jun. 2010;19(6):629-43. X-1, X-2. [pmid: 19424994].
116 Armstrong D, Arnold R, Classen M, et al. Prospective multicentre study of risk factors associated with delayed healing of recurrent duodenal ulcers (RUDER). RUDER Study Group. Gut. Oct. 1993;34(10):1319-26. X-4. [pmid: 8244095].
117 Armstrong D, Blum AL, Arnold R, et al. RUDER: interim evaluation of a 2-year, multicentre study of risk factors for duodenal ulcer relapse. Z Gastroenterol Verh. Mar. 1991;26:171-2. X-4. [pmid: 1714137].
118 Arnolds S, Dellweg S, Clair J, et al. Further improvement in postprandial glucose control with addition of exenatide or sitagliptin to combination therapy with insulin glargine and metformin: a proof-of-concept study. Diabetes Care. Jul. 2010;33(7):1509-15. X-2, X-3, X-4. [pmid: 20357372].
119 Arowojolu AO, Ladipo OA. Nonmenstrual adverse events associated with subdermal contraceptive implants containing normegestrel and levonorgestrel. Afr J Med Med Sci. Mar. 2003;32(1):27-31. X-2, X-4. [pmid: 15030062].
120 Arowojolu AO, Okewole IA. Vaginal bleeding following the use of a single dose of 1.5mg levonorgestrel (LNG) for emergency contraception. West Afr J Med. Jul-Sep. 2004;23(3):191-3. X-2, X-3, X-4. [pmid: 15587826].
121 Arowojolu AO, Otolorin EO, Ladipo OA. Serum copper levels in users of multiload intra-uterine contraceptive devices. Afr J Med Med Sci. Dec. 1989;18(4):295-9. X-2, X-4. [pmid: 2558561].
122 Arowojolu AO, Otolorin EO, Ladipo OA. Performances of copper T 380A and multiload copper 375/250 intrauterine contraceptive devices in a comparative clinical trial. Afr J Med Med Sci. Mar. 1995;24(1):59-65. X-3, X-4. [pmid: 7495202].
123 Arvanitakis Z, Grodstein F, Bienias JL, et al. Relation of NSAIDs to incident AD change in cognitive function, and AD pathology. Neurology. Jun. 3. 2008;70(23):2219-25. X-2, X-4. [pmid: 18519870].
124 Asche CV, McAdam-Marx C, Shane-McWhorter L, et al. Evaluation of adverse events of oral antihyperglycemic monotherapy experienced by a geriatric population in a real-world setting: a retrospective cohort analysis. Drugs Aging. 2008;25(7):611-22. X-7. [pmid: 18582148].
125 Ashorn M, Verronen P, Ruuska T, et al. Upper endoscopic findings in children with active juvenile chronic arthritis. Acta Paediatr. May. 2003;92(5):558-61. X-2. [pmid: 12839284].
126 Ashworth NL, Peloso PM, Muhajarine N, et al. A population based historical cohort study of the mortality associated with nabumetone, Arthrotec, diclofenac, and naproxen. J Rheumatol. May. 2004;31(5):951-6. X-4. [pmid: 15124256].
127 Ashworth NL, Peloso PM, Muhajarine N, et al. Risk of hospitalization with peptic ulcer disease or gastrointestinal hemorrhage associated with nabumetone, Arthrotec, diclofenac, and naproxen in a population based cohort study. J Rheumatol. Nov. 2005;32(11):2212-7. X-4. [pmid: 16265705].
128 Aslam N, Blunt S, Latthe P. Effectiveness and tolerability of levonorgestrel intrauterine system in adolescents. J Obstet Gynaecol. 2010;30(5):489-91. X-2, X-4. [pmid: 20604653].
129 Asscheman H, Giltay EJ, Megens JA, et al. A long-term follow-up study of mortality in transsexuals receiving treatment with cross-sex hormones. Eur J Endocrinol. Apr. 2011;164(4):635-42. X-2. [pmid: 21266549].
130 Attanasio R, Baldelli R, Pivonello R, et al. Lanreotide 60 mg, a new long-acting formulation: effectiveness in the chronic treatment of acromegaly. J Clin Endocrinol Metab. Nov. 2003;88(11):5258-65. X-2, X-3, X-4. [pmid: 14602759].
131 Atteritano M, Marini H, Minutoli L, et al. Effects of the phytoestrogen genistein on some predictors of cardiovascular risk in osteopenic, postmenopausal women: a two-year randomized, double-blind, placebo-controlled study. J Clin Endocrinol Metab. Aug. 2007;92(8):3068-75. X-2, X-3, X-4. [pmid: 17682090].
132 Attridge JT, Clark R, Gordon PV. New insights into spontaneous intestinal perforation using a national data set (3): antenatal steroids have no adverse association with spontaneous intestinal perforation. J Perinatol. Nov. 2006;26(11):667-70. X-2, X-4. [pmid: 17024144].
133 Attridge JT, Clark R, Walker MW, et al. New insights into spontaneous intestinal perforation using a national data set: (2) two populations of patients with perforations. J Perinatol. Mar. 2006;26(3):185-8. X-2, X-3, X-4. [pmid: 16493433].
134 Aun MV, Bisaccioni C, Garro LS, et al. Outcomes and safety of drug provocation tests. Allergy Asthma Proc. Jul-Aug. 2011;32(4):301-6. X-2, X-4. [pmid: 21781406].
135 Avidan B, Sonnenberg A, Schnell TG, et al. Risk factors of oesophagitis in arthritic patients. Eur J Gastroenterol Hepatol. Sep. 2001;13(9):1095-9. X-2. [pmid: 11564962].
136 Avidan B, Sonnenberg A, Schnell TG, et al. Risk factors for erosive reflux esophagitis: a case-control study. Am J Gastroenterol. Jan. 2001;96(1):41-6. X-4. [pmid: 11197285].
137 Awad JN, Kebaish KM, Donigan J, et al. Analysis of the risk factors for the development of post-operative spinal epidural haematoma. J Bone Joint Surg Br. Sep. 2005;87(9):1248-52. X-3, X-4. [pmid: 16129751].
138 Awad OG, Fasano MB, Lee JH, et al. Asthma outcomes after endoscopic sinus surgery in aspirin-tolerant versus aspirin-induced asthmatic patients. Am J Rhinol. Mar-Apr. 2008;22(2):197-203. X-2, X-3, X-4. [pmid: 18416980].
139 Axelrod D, Preston S. Comparison of parenteral adrenocorticotropic hormone with oral indomethacin in the treatment of acute gout. Arthritis Rheum. Jun. 1988;31(6):803-5. X-2, X-3, X-4. [pmid: 2454635].
140 Aydinli B, Yilmaz O, Ozturk G, et al. Is perforated marginal ulcer after the surgery of gastroduodenal ulcer associated with inadequate treatment for Helicobacter pylori eradication?. Langenbecks Arch Surg. Sep. 2007;392(5):593-9. X-2. [pmid: 17370084].
141 Ayral X, Mackillop N, Genant HK, et al. Arthroscopic evaluation of potential structure-modifying drug in osteoarthritis of the knee. A multicenter, randomized, double-blind comparison of tenidap sodium vs piroxicam. Osteoarthritis Cartilage. Mar. 2003;11(3):198-207. X-2, X-3, X-4. [pmid: 12623291].
142 Azoulay L, Schneider-Lindner V, Dell'aniello S, et al. Combination therapy with sulfonylureas and metformin and the prevention of death in type 2 diabetes: a nested case-control study. Pharmacoepidemiol Drug Saf. Apr. 2010;19(4):335-42. X-8. [pmid: 20052677].
143 Azuma A, Nukiwa T, Tsuboi E, et al. Double-blind, placebo-controlled trial of pirfenidone in patients with idiopathic pulmonary fibrosis. Am J Respir Crit Care Med. May. 1. 2005;171(9):1040-7. X-2, X-4. [pmid: 15665326].
144 Ba MG, Moreau JC, Sokal D, et al. A 5-year clinical evaluation of Norplant implants in Senegal. Contraception. Jun. 1999;59(6):377-81. X-2, X-4. [pmid: 10518232].
145 Backstrom M, Hagg S, Mjorndal T, et al. Utilization pattern of metamizole in northern Sweden and risk estimates of agranulocytosis. Pharmacoepidemiol Drug Saf. Apr-May. 2002;11(3):239-45. X-4. [pmid: 12051124].
146 Bacq Y, Sapey T, Brechot MC, et al. Intrahepatic cholestasis of pregnancy: a French prospective study. Hepatology. Aug. 1997;26(2):358-64. X-2. [pmid: 9252146].
147 Bae SC, Corzillius M, Kuntz KM, et al. Cost-effectiveness of low dose corticosteroids versus non-steroidal anti-inflammatory drugs and COX-2 specific inhibitors in the long-term treatment of rheumatoid arthritis. Rheumatology (Oxford). Jan. 2003;42(1):46-53. X-4. [pmid: 12509612].
148 Baenkler HW. Functional-eicosanoid-test (FET) and disease. J Physiol Pharmacol. Dec. Suppl 12. 2006;57:65-72. X-2, X-3, X-4. [pmid: 17244955].
149 Baenziger O, Waldvogel K, Ghelfi D, et al. Can dopamine prevent the renal side effects of indomethacin? A prospective randomized clinical study. Klin Padiatr. Nov-Dec. 1999;211(6):438-41. X-2, X-3, X-4. [pmid: 10592922].
150 Baeten JM, Nyange PM, Richardson BA, et al. Hormonal contraception and risk of sexually transmitted disease acquisition: results from a prospective study. Am J Obstet Gynecol. Aug. 2001;185(2):380-5. X-2. [pmid: 11518896].
151 Baeyertz JD, Hartfield VJ. The Nova-T 200 intrauterine contraceptive device: a 12 year study. N Z Med J. May. 9. 1997;110(1043):169-71. X-2, X-4. [pmid: 9196502].
152 Bagshaw SN, Edwards D, Tucker AK. Ethinyl oestradiol and D-norgestrel is an effective emergency postcoital contraceptive: a report of its use in 1,200 patients in a family planning clinic. Aust N Z J Obstet Gynaecol. May. 1988;28(2):137-40. X-2, X-3, X-4. [pmid: 3228408].
153 Bahamondes L, Hidalgo M, Petta CA, et al. Enlarged ovarian follicles in users of a levonorgestrel-releasing intrauterine system and contraceptive implant. J Reprod Med. Aug. 2003;48(8):637-40. X-2. [pmid: 12971147].
154 Bahamondes MV, Monteiro I, Canteiro R, et al. Length of the endometrial cavity and intrauterine contraceptive device expulsion. Int J Gynaecol Obstet. Apr. 2011;113(1):50-3. X-2. [pmid: 21272883].
155 Bahamondes MV, Monteiro I, Castro S, et al. Prospective study of the forearm bone mineral density of long-term users of the levonorgestrel-releasing intrauterine system. Hum Reprod. May. 2010;25(5):1158-64. X-2. [pmid: 20185512].
156 Bahrami H, Daryani NE, Haghpanah B, et al. Effects of indomethacin on viral replication markers in asymptomatic carriers of hepatitis B: a randomized, placebo-controlled trial. Am J Gastroenterol. Apr. 2005;100(4):856-61. X-2, X-3, X-4. [pmid: 15784032].
157 Bailey R, Sinha C, Burgess LP. Ketorolac tromethamine and hemorrhage in tonsillectomy: a prospective, randomized, double-blind study. Laryngoscope. Feb. 1997;107(2):166-9. X-2, X-4. [pmid: 9023238].
158 Bailie R, Katzenellenbogen J, Hoffman M, et al. A case control study of breast cancer risk and exposure to injectable progestogen contraceptives. Methods and patterns of use among controls. S Afr Med J. Mar. 1997;87(3):302-5. X-2, X-4. [pmid: 9137342].
159 Baiza-Duran LM, Quintana-Hau J, Tornero-Montano R, et al. Comparison of the efficacy and safety of a novel meloxicam ophthalmic formulation with a reference diclofenac solution in cataract surgery. Int J Clin Pharmacol Ther. Feb. 2009;47(2):89-95. X-4. [pmid: 19203564].
160 Bak S, Andersen M, Tsiropoulos I, et al. Risk of stroke associated with nonsteroidal anti-inflammatory drugs: a nested case-control study. Stroke. Feb. 2003;34(2):379-86. X-4. [pmid: 12574546].
161 Bakhru A, Stanwood N. Performance of contraceptive patch compared with oral contraceptive pill in a high-risk population. Obstet Gynecol. Aug. 2006;108(2):378-86. X-2, X-3, X-4. [pmid: 16880309].
162 Bakke OM, Manocchia M, de Abajo F, et al. Drug safety discontinuations in the United Kingdom, the United States, and Spain from 1974 through 1993: a regulatory perspective. Clin Pharmacol Ther. Jul. 1995;58(1):108-17. X-1, X-2, X-3, X-4. [pmid: 7628177].
163 Bakowsky VS, Hanly JG. Complications of nonsteroidal antiiflammatory drug gastropathy and use of gastric cytoprotection: experience at a tertiary care health center. J Rheumatol. Jul. 1999;26(7):1557-63. X-2. [pmid: 10405945].
164 Balali-Mood M, Critchley JA, Proudfoot AT, et al. Mefenamic acid overdosage. Lancet. Jun. 20. 1981;1(8234):1354-6. X-2, X-4. [pmid: 6113321].
165 Baldaszti E, Wimmer-Puchinger B, Loschke K. Acceptability of the long-term contraceptive levonorgestrel-releasing intrauterine system (Mirena): a 3-year follow-up study. Contraception. Feb. 2003;67(2):87-91. X-2, X-3, X-4. [pmid: 12586318].
166 Balle C, Schollmeyer P. Morbidity of patients with analgesic-associated nephropathy on regular dialysis treatment and after renal transplantation. Klin Wochenschr. Jan. 4. 1990;68(1):38-42. X-2, X-4. [pmid: 2106598].
167 Balogh A. Clinical and endocrine effects of long-term hormonal contraception. Acta Med Hung. 1986;43(2):97-102. X-2, X-4. [pmid: 3588164].
168 Balogun OR, Raji HO. Clinical experience with injectable progestogen- only contraceptives at University of Ilorin teaching hospital: a five year review. Niger Postgrad Med J. Dec. 2009;16(4):260-3. X-2, X-3, X-4. [pmid: 20037621].
169 Banerji MA, Purkayastha D, Francis BH. Safety and tolerability of vildagliptin vs. thiazolidinedione as add-on to metformin in type 2 diabetic patients with and without mild renal impairment: a retrospective analysis of the GALIANT study. Diabetes Res Clin Pract. Nov. 2010;90(2):182-90. X-8. [pmid: 20655609].
170 Banhidy F, Acs N, Puho E, et al. A population-based case-control teratologic study of oral dipyrone treatment during pregnancy. Drug Saf. 2007;30(1):59-70. X-4. [pmid: 17194171].
171 Bank S, Greenberg RE, Magier D, et al. The efficacy and tolerability of famotidine and ranitidine on the healing of active duodenal ulcer and during six-month maintenance treatment, with special reference to NSAID/aspirin-related ulcers. Clin Ther. Mar-Apr. 1991;13(2):304-18. X-2, X-3, X-4. [pmid: 1863945].
172 Bannwarth B, Dorval E, Caekaert A, et al. Influence of Helicobacter pylori eradication therapy on the occurrence of gastrointestinal events in patients treated with conventional nonsteroidal antiinflammatory drugs combined with omeprazole. J Rheumatol. Sep. 2002;29(9):1975-80. X-2, X-3, X-4. [pmid: 12233895].
173 Baraldi A, Ballestri M, Rapana R, et al. Acute renal failure of medical type in an elderly population. Nephrol Dial Transplant. Suppl 7. 1998;13:25-9. X-2. [pmid: 9870433].
174 Barbosa IC, Filho CI, Faggion D Jr., et al. Prospective, open-label, noncomparative study to assess cycle control, safety and acceptability of a new oral contraceptive containing gestodene 60 microg and ethinylestradiol 15 microg (Minesse). Contraception. Jan. 2006;73(1):30-3. X-2, X-4. [pmid: 16371291].
175 Bardia A, Olson JE, Vachon CM, et al. Effect of aspirin and other NSAIDs on postmenopausal breast cancer incidence by hormone receptor status: results from a prospective cohort study. Breast Cancer Res Treat. Feb. 2011;126(1):149-55. X-4, X-7. [pmid: 20669045].
176 Barkin JS, Ross BS. Medical therapy for chronic gastrointestinal bleeding of obscure origin. Am J Gastroenterol. Aug. 1998;93(8):1250-4. X-2, X-4. [pmid: 9707046].
177 Barletta GM, Smoyer WE, Bunchman TE, et al. Use of mycophenolate mofetil in steroid-dependent and - resistant nephrotic syndrome. Pediatr Nephrol. Aug. 2003;18(8):833-7. X-2, X-4. [pmid: 12774223].
178 Barnabei VM, Cochrane BB, Aragaki AK, et al. Menopausal symptoms and treatment-related effects of estrogen and progestin in the Women's Health Initiative. Obstet Gynecol. May. 2005;105(5 Pt 1):1063-73. X-4, X-7. [pmid: 15863546].
179 Barnard L, Lavoie D, Lajeunesse N. Increase in nonfatal digestive perforations and haemorrhages following introduction of selective NSAIDs: a public health concern. Drug Saf. 2006;29(7):613-20. X-4. [pmid: 16808553].
180 Barnum JL, Sistino JJ. Renal dysfunction in cardiac surgery: identifying potential risk factors. Perfusion. Mar. 2009;24(2):139-42. X-2. [pmid: 19654159].
181 Baron JA, Cole BF, Sandler RS, et al. A randomized trial of aspirin to prevent colorectal adenomas. N Engl J Med. Mar. 6. 2003;348(10):891-9. X-2, X-3, X-4. [pmid: 12621133].
182 Barreiros FA, Guazzelli CA, Barbosa R, et al. Extended regimens of the contraceptive vaginal ring: evaluation of clinical aspects. Contraception. Mar. 2010;81(3):223-5. X-2, X-4. [pmid: 20159178].
183 Bartle WR, Gupta AK, Lazor J. Nonsteroidal anti-inflammatory drugs and gastrointestinal bleeding. A case-control study. Arch Intern Med. Dec. 1986;146(12):2365-7. X-2, X-4. [pmid: 3490836].
184 Bas M, Greve J, Stelter K, et al. Therapeutic efficacy of icatibant in angioedema induced by angiotensin-converting enzyme inhibitors: a case series. Ann Emerg Med. Sep. 2010;56(3):278-82. X-2, X-3, X-4. [pmid: 20447725].
185 Basnayake S, Higgins JE, Miller PC, et al. Early symptoms and discontinuation among users of oral contraceptives in Sri Lanka. Stud Fam Plann. Nov-Dec. 1984;15(6 Pt 1):285-90. X-2. [pmid: 6393460].
186 Bassol S, Alvarado G, Arreola RG, et al. A 13-month multicenter clinical experience of a low-dose monophasic oral contraceptive containing 20 microg ethinylestradiol and 75 microg gestodene in Latin American women. Contraception. May. 2003;67(5):367-72. X-2, X-4. [pmid: 12742559].
187 Bassol S, Carranza-Lira S, Celis-Gonzalez C, et al. The impact of a monophasic continuous estro-progestogenic treatment on Latin American menopausal women. Maturitas. Mar. 14. 2005;50(3):189-95. X-2. [pmid: 15734600].
188 Bastuji-Garin S, Zahedi M, Guillaume JC, et al. Toxic epidermal necrolysis (Lyell syndrome) in 77 elderly patients. Age Ageing. Nov. 1993;22(6):450-6. X-2, X-7. [pmid: 8310891].
189 Batar I. One-year clinical experience with FlexiGard. Contraception. Oct. 1992;46(4):307-12. X-2, X-3, X-4. [pmid: 1486769].
190 Batar I, Lampe LG, Allonen H. Clinical experience with intrauterine contraceptive devices (IUDs) inserted with and without tail. Acta Chir Hung. 1988;29(4):385-93. X-2, X-4. [pmid: 3239338].
191 Batar I, Lampe LG, Allonen H. Clinical experiences with intrauterine devices inserted with and without tail. Int J Gynaecol Obstet. Oct. 1991;36(2):137-40. X-4. [pmid: 1683316].
192 Battaglia C, Cianciosi A, Mancini F, et al. Angeliq versus Activelle in normotensive postmenopausal women: a prospective, randomized pilot study. Menopause. Jul-Aug. 2009;16(4):803-9. X-2. [pmid: 19194341].
193 Battino S, Ben-Ami M, Geslevich Y, et al. Factors associated with withdrawal bleeding after administration of oral dydrogesterone or medroxyprogesterone acetate in women with secondary amenorrhea. Gynecol Obstet Invest. 1996;42(2):113-6. X-2, X-3, X-4. [pmid: 8878716].
194 Battistella M, Mamdami MM, Juurlink DN, et al. Risk of upper gastrointestinal hemorrhage in warfarin users treated with nonselective NSAIDs or COX-2 inhibitors. Arch Intern Med. Jan. 24. 2005;165(2):189-92. X-4. [pmid: 15668365].
195 Baudouin C, Nordmann JP, Denis P, et al. Efficacy of indomethacin 0.1% and fluorometholone 0.1% on conjunctival inflammation following chronic application of antiglaucomatous drugs. Graefes Arch Clin Exp Ophthalmol. Nov. 2002;240(11):929-35. X-2, X-4. [pmid: 12486516].
196 Baughman RP, Lower EE. Leflunomide for chronic sarcoidosis. Sarcoidosis Vasc Diffuse Lung Dis. Mar. 2004;21(1):43-8. X-2, X-4. [pmid: 15127974].
197 Baumelou E, Guiguet M, Mary JY. Epidemiology of aplastic anemia in France: a case-control study. I. Medical history and medication use. The French Cooperative Group for Epidemiological Study of Aplastic Anemia. Blood. Mar. 15. 1993;81(6):1471-8. X-2, X-4. [pmid: 8453094].
198 Baur DM, Klotsche J, Hamnvik OP, et al. Type 2 diabetes mellitus and medications for type 2 diabetes mellitus are associated with risk for and mortality from cancer in a German primary care cohort. Metabolism. Oct. 2011;60(10):1363-71. X-2, X-4. [pmid: 21081242].
199 Bavry AA, Khaliq A, Gong Y, et al. Harmful effects of NSAIDs among patients with hypertension and coronary artery disease. Am J Med. Jul. 2011;124(7):614-20. X-4. [pmid: 21596367].
200 Bayan K, Tuzun Y, Yilmaz S, et al. Clarifying the relationship between ABO/Rhesus blood group antigens and upper gastrointestinal bleeding. Dig Dis Sci. May. 2009;54(5):1029-34. X-2, X-3, X-4. [pmid: 18716867].
201 Bayoglu Tekin Y, Dilbaz B, Altinbas SK, et al. Postoperative medical treatment of chronic pelvic pain related to severe endometriosis: levonorgestrel-releasing intrauterine system versus gonadotropin-releasing hormone analogue. Fertil Steril. Feb. 2011;95(2):492-6. X-2, X-3. [pmid: 20883991].
202 Beardon PH, Brown SV, McDevitt DG. Gastrointestinal events in patients prescribed non-steroidal anti-inflammatory drugs: a controlled study using record linkage in Tayside. Q J Med. Jun. 1989;71(266):497-505. X-4. [pmid: 2602546].
203 Becker A, Leber A, von Ziegler F, et al. Comparison of progression of coronary calcium in postmenopausal women on versus not on estrogen/progestin therapy. Am J Cardiol. Feb. 1. 2007;99(3):374-8. X-2, X-7. [pmid: 17261401].
204 Beksinska ME, Kleinschmidt I, Smit JA, et al. Bone mineral density in young women aged 19-24 after 4-5 years of exclusive and mixed use of hormonal contraception. Contraception. Aug. 2009;80(2):128-32. X-2. [pmid: 19631787].
205 Beksinska ME, Smit JA, Kleinschmidt I, et al. Prospective study of weight change in new adolescent users of DMPA NET-EN, COCs, nonusers and discontinuers of hormonal contraception. Contraception. Jan. 2010;81(1):30-4. X-2, X-4. [pmid: 20004270].
206 Bell D, Marasco S, Almeida A, et al. Tranexamic Acid in cardiac surgery and postoperative seizures: a case report series. Heart Surg Forum. Aug. 2010;13(4):E257-9. X-2. [pmid: 20719731].
207 Bellary SV, Isaacs PE, Lee FI. Upper gastrointestinal lesions in elderly patients presenting for endoscopy: relevance of NSAID usage. Am J Gastroenterol. Aug. 1991;86(8):961-4. X-2. [pmid: 1858761].
208 Belsey JD. Non-steroidal anti-inflammatory induced upper gastrointestinal event rates in patients awaiting joint replacement in the United Kingdom. An epidemiologically-based burden of disease model. Curr Med Res Opin. 2003;19(4):306-12. X-1, X-4. [pmid: 12841923].
209 Benagiano G. Comparison of two monophasic oral contraceptives: gestodene/ethinyl estradiol versus desogestrel/ethinyl estradiol. Int J Fertil. Sep. 1989;34(Suppl):31-9. X-2, X-4. [pmid: 2576255].
210 Benahmed S, Picot MC, Dumas F, et al. Accuracy of a pharmacovigilance algorithm in diagnosing drug hypersensitivity reactions. Arch Intern Med. Jul. 11. 2005;165(13):1500-5. X-2, X-3, X-4. [pmid: 16009865].
211 Benavides S, Striet J, Germak J, et al. Efficacy and safety of hypoglycemic drugs in children with type 2 diabetes mellitus. Pharmacotherapy. Jun. 2005;25(6):803-9. X-2, X-4. [pmid: 15927898].
212 Bennett K, Teeling M, Feely J. “Selective” switching from non-selective to selective non-steroidal anti-inflammatory drugs. Eur J Clin Pharmacol. Nov. 2003;59(8-9):645-9. X-3, X-4. [pmid: 12942226].
213 Bensen WG, Zhao SZ, Burke TA, et al. Upper gastrointestinal tolerability of celecoxib, a COX-2 specific inhibitor, compared to naproxen and placebo. J Rheumatol. Aug. 2000;27(8):1876-83. X-4. [pmid: 10955327].
214 Berenson AB, Rahman M. Changes in weight, total fat, percent body fat, and central-to-peripheral fat ratio associated with injectable and oral contraceptive use. Am J Obstet Gynecol. Mar. 2009;200(3):329 e1-8. X-2. [pmid: 19254592].
215 Berenson AB, Wiemann CM. Use of levonorgestrel implants versus oral contraceptives in adolescence: a case-control study. Am J Obstet Gynecol. Apr. 1995;172(4 Pt 1):1128-35. discussion 35-7. X-2, X-4. [pmid: 7726249].
216 Berenson AB, Wiemann CM, Rickerr VI, et al. Contraceptive outcomes among adolescents prescribed Norplant implants versus oral contraceptives after one year of use. Am J Obstet Gynecol. Mar. 1997;176(3):586-92. X-2. [pmid: 9077611].
217 Bergenstal RM, Garrison LP Jr., Miller LA, et al. Exenatide BID Observational Study (ExOS): results for primary and secondary endpoints of a prospective research study to evaluate the clinical effectiveness of exenatide BID use in patients with type 2 diabetes in a real-world setting. Curr Med Res Opin. Dec. 2011;27(12):2335-42. X-2. [pmid: 22085180].
218 Berger RE. Urinary tract infection in the users of depot-medroxyprogesterone acetate. J Urol. Sep. 2005;174(3):941. X-1, X-2. [pmid: 16093999].
219 Berges-Gimeno MP, Simon RA, Stevenson DD. The effect of leukotriene-modifier drugs on aspirin-induced asthma and rhinitis reactions. Clin Exp Allergy. Oct. 2002;32(10):1491-6. X-2, X-4. [pmid: 12372130].
220 Bergqvist A, Jacobson J, Harris S. A double-blind randomized study of the treatment of endometriosis with nafarelin or nafarelin plus norethisterone. Gynecol Endocrinol. Jun. 1997;11(3):187-94. X-2, X-3, X-4. [pmid: 9209899].
221 Berlin JM, Rigel DS. Diclofenac sodium 3% gel in the treatment of actinic keratoses postcryosurgery. J Drugs Dermatol. Jul. 2008;7(7):669-73. X-2, X-3, X-4. [pmid: 18664159].
222 Berman M, Cardone D, Sharples L, et al. Safety and efficacy of aprotinin and tranexamic acid in pulmonary endarterectomy surgery with hypothermia: review of 200 patients. Ann Thorac Surg. Nov. 2010;90(5):1432-6. X-2. [pmid: 20971234].
223 Bernard GR, Vincent JL, Laterre PF, et al. Efficacy and safety of recombinant human activated protein C for severe sepsis. N Engl J Med. Mar. 8. 2001;344(10):699-709. X-3, X-4. [pmid: 11236773].
224 Bernier MO, Mikaeloff Y, Hudson M, et al. Combined oral contraceptive use and the risk of systemic lupus erythematosus. Arthritis Rheum. Apr. 15. 2009;61(4):476-81. X-4. [pmid: 19333988].
225 Bernstein CN, Singh S, Graff LA, et al. A prospective population-based study of triggers of symptomatic flares in IBD. Am J Gastroenterol. Sep. 2010;105(9):1994-2002. X-2, X-3, X-4. [pmid: 20372115].
226 Bertolini S, Elicio N, Cordera R, et al. Effects of three low-dose oral contraceptive formulations on lipid metabolism. Acta Obstet Gynecol Scand. 1987;66(4):327-32. X-2. [pmid: 2962417].
227 Bertuola F, Morando C, Menniti-Ippolito F, et al. Association between drug and vaccine use and acute immune thrombocytopenia in childhood: a case-control study in Italy. Drug Saf. Jan. 1. 2010;33(1):65-72. X-4. [pmid: 20000868].
228 Beunza JJ, Martinez-Gonzalez MA, Bes-Rastrollo M, et al. Aspirin, non-aspirin analgesics and the risk of hypertension in the SUN cohort. Rev Esp Cardiol. Mar. 2010;63(3):286-93. X-4. [pmid: 20196989].
229 Beutler AI, Chesnut GT, Mattingly JC, et al. FPIN's Clinical Inquiries. Aspirin use in children for fever or viral syndromes. Am Fam Physician. Dec. 15. 2009;80(12):1472. X-1, X-4. [pmid: 20000310].
230 Bhat P, Cervantes-Castaneda RA, Doctor PP, et al. Mycophenolate mofetil therapy for sarcoidosis-associated uveitis. Ocul Immunol Inflamm. May-Jun. 2009;17(3):185-90. X-2, X-3, X-4. [pmid: 19585361].
231 Bhattacharyya T, Levin R, Vrahas MS, et al. Nonsteroidal antiinflammatory drugs and nonunion of humeral shaft fractures. Arthritis Rheum. Jun. 15. 2005;53(3):364-7. X-4. [pmid: 15934108].
232 Bianchi Porro G, Ardizzone S, Petrillo M, et al. Endoscopic assessment of the effects of dipyrone (metamizol) in comparison to paracetamol and placebo on the gastric and duodenal mucosa of healthy adult volunteers. Digestion. 1996;57(3):186-90. X-2, X-4. [pmid: 8739093].
233 Bianchi Porro G, Lazzaroni M, Petrillo M, et al. Prevention of gastroduodenal damage with omeprazole in patients receiving continuous NSAIDs treatment. A double blind placebo controlled study. Ital J Gastroenterol Hepatol. Feb. 1998;30(1):43-7. X-2, X-3, X-4. [pmid: 9615264].
234 Bianchi Porro G, Parente F, Imbesi V, et al. Role of Helicobacter pylori in ulcer healing and recurrence of gastric and duodenal ulcers in longterm NSAID users. Response to omeprazole dual therapy. Gut. Jul. 1996;39(1):22-6. X-2, X-4. [pmid: 8881802].
235 Bianco MA, Rotondano G, Buri L, et al. Gastroprotective strategies in primary care in Italy: the “Gas.Pro.” survey. Dig Liver Dis. May. 2010;42(5):359-64. X-4. [pmid: 20005189].
236 Biancone L, Tosti C, Geremia A, et al. Rofecoxib and early relapse of inflammatory bowel disease: an open-label trial. Aliment Pharmacol Ther. Apr. 1. 2004;19(7):755-64. X-2, X-4. [pmid: 15043516].
237 Biere-Rafi S, Di Nisio M, Gerdes V, et al. Non-steroidal anti-inflammatory drugs and risk of pulmonary embolism. Pharmacoepidemiol Drug Saf. Jun. 2011;20(6):635-42. X-4. [pmid: 21462279].
238 Bijol V, Mendez GP, Nose V, et al. Granulomatous interstitial nephritis: a clinicopathologic study of 46 cases from a single institution. Int J Surg Pathol. Jan. 2006;14(1):57-63. X-2, X-3, X-4. [pmid: 16501836].
239 Bilker WB, Berlin JA, Gail MH, et al. An efficient design for verifying disease outcome status in large cohorts with rare exposures and low disease rates. Stat Med. Nov. 30. 1999;18(22):3021-36. X-1. [pmid: 10544304].
240 Biller BM, Molitch ME, Vance ML, et al. Treatment of prolactin-secreting macroadenomas with the once-weekly dopamine agonist cabergoline. J Clin Endocrinol Metab. Jun. 1996;81(6):2338-43. X-2. [pmid: 8964874].
241 Bingham CO 3rd, Ince A, Haraoui B, et al. Effectiveness and safety of etanercept in subjects with RA who have failed infliximab therapy: 16-week, open-label, observational study. Curr Med Res Opin. May. 2009;25(5):1131-42. X-3, X-4. [pmid: 19317607].
242 Bingham CO 3rd, Sebba AI, Rubin BR, et al. Efficacy and safety of etoricoxib 30 mg and celecoxib 200 mg in the treatment of osteoarthritis in two identically designed, randomized, placebo-controlled, non-inferiority studies. Rheumatology (Oxford). Mar. 2007;46(3):496-507. X-2, X-3, X-4. [pmid: 16936327].
243 Birt CM. The use of topical ketorolac 0.5% for pain relief following cyclophotocoagulation. Ophthalmic Surg Lasers Imaging. Sep-Oct. 2003;34(5):381-5. X-2, X-3, X-4. [pmid: 14509461].
244 Biskupiak JE, Brixner DI, Howard K, et al. Gastrointestinal complications of over-the-counter nonsteroidal antiinflammatory drugs. J Pain Palliat Care Pharmacother. 2006;20(3):7-14. X-4. [pmid: 16931473].
245 Bitto A, Granese R, Triolo O, et al. Genistein aglycone: a new therapeutic approach to reduce endometrial hyperplasia. Phytomedicine. Sep. 2010;17(11):844-50. X-2, X-3, X-4. [pmid: 20570122].
246 Bivins HA Jr., Newman RB, Fyfe DA, et al. Randomized trial of oral indomethacin and terbutaline sulfate for the long-term suppression of preterm labor. Am J Obstet Gynecol. Oct. 1993;169(4):1065-70. X-2, X-4. [pmid: 8238121].
247 Bjorklund K, Nordstrom ML, Odlind V. Combined oral contraceptives do not increase the risk of back and pelvic pain during pregnancy or after delivery. Acta Obstet Gynecol Scand. Nov. 2000;79(11):979-83. X-2. [pmid: 11081684].
248 Black C, Kaye JA, Jick H. Clinical risk factors for venous thromboembolus in users of the combined oral contraceptive pill. Br J Clin Pharmacol. Jun. 2002;53(6):637-40. X-4. [pmid: 12047488].
249 Blaicher AM, Landsteiner HT, Al-Falaki O, et al. Acetylsalicylic acid, diclofenac, and lornoxicam, but not rofecoxib, affect platelet CD 62 expression. Anesth Analg. Apr. 2004;98(4):1082-5. table of contents. X-2, X-3, X-4. [pmid: 15041603].
250 Blanco G, Martinez C, Ladero JM, et al. Interaction of CYP2C8 and CYP2C9 genotypes modifies the risk for nonsteroidal anti-inflammatory drugs-related acute gastrointestinal bleeding. Pharmacogenet Genomics. Jan. 2008;18(1):37-43. X-2, X-3, X-4. [pmid: 18216720].
251 Blix HS, Viktil KK, Moger TA, et al. Use of renal risk drugs in hospitalized patients with impaired renal function--an underestimated problem?. Nephrol Dial Transplant. Nov. 2006;21(11):3164-71. X-2, X-3, X-4. [pmid: 16880181].
252 Blomqvist P, Feltelius N, Ekbom A, et al. Rheumatoid arthritis in Sweden. Drug prescriptions, costs, and adverse drug reactions. J Rheumatol. May. 2000;27(5):1171-7. X-4. [pmid: 10813283].
253 Blonde L, Dailey GE, Jabbour SA, et al. Gastrointestinal tolerability of extended-release metformin tablets compared to immediate-release metformin tablets: results of a retrospective cohort study. Curr Med Res Opin. Apr. 2004;20(4):565-72. X-2, X-4. [pmid: 15119994].
254 Blonde L, Klein EJ, Han J, et al. Interim analysis of the effects of exenatide treatment on A1C, weight and cardiovascular risk factors over 82 weeks in 314 overweight patients with type 2 diabetes. Diabetes Obes Metab. Jul. 2006;8(4):436-47. X-2, X-3, X-4. [pmid: 16776751].
255 Bloom BS. Direct medical costs of disease and gastrointestinal side effects during treatment for arthritis. Am J Med. Feb. 22. 1988;84(2A):20-4. X-3, X-4. [pmid: 3348239].
256 Bloom BS. Risk and cost of gastrointestinal side effects associated with nonsteroidal anti-inflammatory drugs. Arch Intern Med. May. 1989;149(5):1019-22. X-4. [pmid: 2719496].
257 Blot WJ, Fischer T, Nielsen GL, et al. Outcome of upper gastro-intestinal bleeding and use of ibuprofen versus paracetamol. Pharm World Sci. Dec. 2004;26(6):319-23. X-2, X-4. [pmid: 15683100].
258 Blot WJ, McLaughlin JK. Over the counter non-steroidal anti-inflammatory drugs and risk of gastrointestinal bleeding. J Epidemiol Biostat. 2000;5(2):137-42. X-2. [pmid: 10890286].
259 Blower AL, Brooks A, Fenn GC, et al. Emergency admissions for upper gastrointestinal disease and their relation to NSAID use. Aliment Pharmacol Ther. Apr. 1997;11(2):283-91. X-2, X-4. [pmid: 9146764].
260 Bluhm RE, Adedoyin A, McCarver DG, et al. Development of dapsone toxicity in patients with inflammatory dermatoses: activity of acetylation and hydroxylation of dapsone as risk factors. Clin Pharmacol Ther. Jun. 1999;65(6):598-605. X-2, X-4. [pmid: 10391665].
261 Blumenfeld Z, Boulman N, Leiba R, et al. High C-reactive protein levels are associated with oral hormonal menopausal therapy but not with intrauterine levonorgestrel and transdermal estradiol. Scand J Clin Lab Invest. 2007;67(3):257-63. X-2, X-3. [pmid: 17454839].
262 Bobrzynski A, Beben P, Budzynski A, et al. Incidence of complications of peptic ulcers in patients with Helicobacter pylori (Hp) infection and/or NSAID use in the era of Hp eradication. Med Sci Monit. Aug. 2002;8(8):CR554-7. X-4. [pmid: 12165741].
263 Bodelon C, Doherty JA, Chen C, et al. Use of nonsteroidal antiinflammatory drugs and risk of endometrial cancer. Am J Epidemiol. Dec. 15. 2009;170(12):1512-7. X-1, X-2, X-4. [pmid: 19897512].
264 Bodmer M, Becker C, Meier C, et al. Use of metformin and the risk of ovarian cancer: a case-control analysis. Gynecol Oncol. Nov. 2011;123(2):200-4. X-4. [pmid: 21802715].
265 Bodmer M, Becker C, Meier C, et al. Use of antidiabetic agents and the risk of pancreatic cancer: a case-control analysis. Am J Gastroenterol. Apr. 2012;107(4):620-6. X-3, X-8. [pmid: 22290402].
266 Bogazzi F, Buralli S, Manetti L, et al. Treatment with low doses of cabergoline is not associated with increased prevalence of cardiac valve regurgitation in patients with hyperprolactinaemia. Int J Clin Pract. Dec. 2008;62(12):1864-9. X-2. [pmid: 18462372].
267 Boissonnault WG, Meek PD. Risk factors for anti-inflammatory-drug- or aspirin-induced gastrointestinal complications in individuals receiving outpatient physical therapy services. J Orthop Sports Phys Ther. Oct. 2002;32(10):510-7. X-4. [pmid: 12403202].
268 Bokesch PM, Szabo G, Wojdyga R, et al. A phase 2 prospective, randomized, double-blind trial comparing the effects of tranexamic acid with ecallantide on blood loss from high-risk cardiac surgery with cardiopulmonary bypass (CONSERV-2 Trial). J Thorac Cardiovasc Surg. May. 2012;143(5):1022-9. X-2, X-4. [pmid: 21724197].
269 Bolaji II, Mortimer G, Grimes H, et al. Clinical evaluation of near-continuous oral micronized progesterone therapy in estrogenized postmenopausal women. Gynecol Endocrinol. Feb. 1996;10(1):41-7. X-2, X-3, X-4. [pmid: 8737191].
270 Bonanomi MT, Dantas NC, Medeiros FA. Retinal nerve fibre layer thickness measurements in patients using chloroquine. Clin Experiment Ophthalmol. Mar. 2006;34(2):130-6. X-2, X-3, X-4. [pmid: 16626426].
271 Bonfils P, Avan P. Non-specific bronchial hyperresponsiveness is a risk factor for steroid insensitivity in nasal polyposis. Acta Otolaryngol. Apr. 2004;124(3):290-6. X-2, X-3, X-4. [pmid: 15143747].
272 Bonfils P, Avan P, Malinvaud D. Influence of allergy on the symptoms and treatment of nasal polyposis. Acta Otolaryngol. Aug. 2006;126(8):839-44. X-2, X-3, X-4. [pmid: 16846927].
273 Bonnar J, Sheppard BL. Treatment of menorrhagia during menstruation: randomised controlled trial of ethamsylate, mefenamic acid, and tranexamic acid. BMJ. Sep. 7. 1996;313(7057):579-82. X-2, X-3, X-4. [pmid: 8806245].
274 Bonner GF, Fakhri A, Vennamaneni SR. A long-term cohort study of nonsteroidal anti-inflammatory drug use and disease activity in outpatients with inflammatory bowel disease. Inflamm Bowel Dis. Nov. 2004;10(6):751-7. X-2. [pmid: 15626893].
275 Bonner GF, Walczak M, Kitchen L, et al. Tolerance of nonsteroidal antiinflammatory drugs in patients with inflammatory bowel disease. Am J Gastroenterol. Aug. 2000;95(8):1946-8. X-2, X-4. [pmid: 10950040].
276 Bonny AE, Britto MT, Huang B, et al. Weight gain, adiposity, and eating behaviors among adolescent females on depot medroxyprogesterone acetate (DMPA). J Pediatr Adolesc Gynecol. Apr. 2004;17(2):109-15. X-2. [pmid: 15050987].
277 Bor S, Dagli U, Sarer B, et al. A retrospective study demonstrating properties of nonvariceal upper gastrointestinal bleeding in Turkey. Turk J Gastroenterol. Jun. 2011;22(3):249-54. X-2. [pmid: 21805414].
278 Borgstrom A, Kask K, Gulinello M, et al. Patients with adverse mood effects from combined oral contraceptives have lower levels of prepulse inhibition than healthy controls. Psychoneuroendocrinology. May. 2008;33(4):487-96. X-2, X-3, X-4. [pmid: 18329179].
279 Bori Segura G, Torres y Gutierrez Rubio A, Herrera Gomez LE, et al. Efficacy and tolerability of acemetacin, a non-steroidal anti-inflammatory drug, in Mexican patients: result of the ETAPAM Study. Proc West Pharmacol Soc. 2002;45:104-7. X-4. [pmid: 12434547].
280 Bornebroek M, de Lau LM, Haag MD, et al. Nonsteroidal anti-inflammatory drugs and the risk of Parkinson disease. Neuroepidemiology. 2007;28(4):193-6. X-4. [pmid: 17851257].
281 Bortnichak EA, Sachs RM. Piroxicam in recent epidemiologic studies. Am J Med. Nov. 28. 1986;81(5B):44-8. X-1, X-2, X-3, X-4. [pmid: 3491542].
282 Bosetti C, Bravi F, Talamini R, et al. Aspirin and risk of endometrial cancer: a case-control study from Italy. Eur J Cancer Prev. Sep. 2010;19(5):401-3. X-2, X-4. [pmid: 20698055].
283 Bosetti C, Talamini R, Franceschi S, et al. Aspirin use and cancers of the upper aerodigestive tract. Br J Cancer. Mar. 10. 2003;88(5):672-4. X-4. [pmid: 12618872].
284 Bottoni A, Criscuolo D. Cutaneous adverse reactions following the administration of nonsteroidal antiinflammatory drugs and antibiotics: an Italian survey. Int J Clin Pharmacol Ther Toxicol. Jul. 1992;30(7):257-9. X-2, X-4. [pmid: 1387114].
285 Bouaziz E, Canonico M, Verstuyft C, et al. Does the progesterone receptor genetic polymorphism +331G/A hPR influence the risk of venous thromboembolism among postmenopausal women using hormone therapy? The ESTHER Study. Maturitas. Oct. 20. 2009;64(2):136-8. X-2, X-4, X-7. [pmid: 19782484].
286 Boukthir S, Mazigh SM, Kalach N, et al. The effect of non-steroidal anti-inflammatory drugs and Helicobacter pylori infection on the gastric mucosa in children with upper gastrointestinal bleeding. Pediatr Surg Int. Feb. 2010;26(2):227-30. X-2. [pmid: 19823852].
287 Boulinguez S, Reix S, Bedane C, et al. Role of drug exposure in aphthous ulcers: a case-control study. Br J Dermatol. Dec. 2000;143(6):1261-5. X-2. [pmid: 11122030].
288 Bouvy ML, Heerdink ER, Hoes AW, et al. Effects of NSAIDs on the incidence of hospitalisations for renal dysfunction in users of ACE inhibitors. Drug Saf. 2003;26(13):983-9. X-2. [pmid: 14583072].
289 Bowker SL, Majumdar SR, Veugelers P, et al. Increased cancer-related mortality for patients with type 2 diabetes who use sulfonylureas or insulin. Diabetes Care. Feb. 2006;29(2):254-8. X-3. [pmid: 16443869].
290 Bowrey DJ, Morris-Stiff GJ. Drug allergy: fact or fiction?. Int J Clin Pract. Jan-Feb. 1998;52(1):20-1. X-2, X-3, X-4. [pmid: 9536562].
291 Boyapati SM, Bostick RM, McGlynn KA, et al. Calcium, vitamin D and risk for colorectal adenoma: dependency on vitamin D receptor BsmI polymorphism and nonsteroidal anti-inflammatory drug use?. Cancer Epidemiol Biomarkers Prev. Jul. 2003;12(7):631-7. X-2, X-4. [pmid: 12869402].
292 Boyd EJ, Penston JG, Russell RI, et al. Hiatal hernial ulcers: clinical features and follow-up. Postgrad Med J. Oct. 1991;67(792):900-3. X-2, X-3, X-4. [pmid: 1684655].
293 Bozkurt B, Torre-Amione G, Warren MS, et al. Results of targeted anti-tumor necrosis factor therapy with etanercept (ENBREL) in patients with advanced heart failure. Circulation. Feb. 27. 2001;103(8):1044-7. X-2, X-4. [pmid: 11222463].
294 Bracco F, Battaglia A, Chouza C, et al. The long-acting dopamine receptor agonist cabergoline in early Parkinson's disease: final results of a 5-year, double-blind, levodopa-controlled study. CNS Drugs. 2004;18(11):733-46. X-2. [pmid: 15330687].
295 Bradbury F. How important is the role of the physician in the correct use of a drug? An observational cohort study in general practice. Int J Clin Pract Suppl. Oct. 2004;(144):27-32. X-3, X-4. [pmid: 16035400].
296 Bradley MC, Hughes CM, Cantwell MM, et al. Non-steroidal anti-inflammatory drugs and pancreatic cancer risk: a nested case-control study. Br J Cancer. Apr. 27. 2010;102(9):1415-21. X-4. [pmid: 20372155].
297 Brahimi N, Routier E, Raison-Peyron N, et al. A three-year-analysis of fixed drug eruptions in hospital settings in France. Eur J Dermatol. Jul-Aug. 2010;20(4):461-4. X-2, X-4. [pmid: 20507840].
298 Bramlage P, Binz C, Gitt AK, et al. Diabetes treatment patterns and goal achievement in primary diabetes care (DiaRegis) - study protocol and patient characteristics at baseline. Cardiovasc Diabetol. 2010;9:53. X-3, X-4. [pmid: 20843379].
299 Bratt H, Skjeldestad FE, Cullberg Valentin K. A randomized trial of three copper IUDs (MLCu250, MLCu375 and Nova-T). Acta Obstet Gynecol Scand. 1988;67(3):247-51. X-2, X-3, X-4. [pmid: 3051876].
300 Braun JM, Schneider B, Beuth HJ. Therapeutic use, efficiency and safety of the proteolytic pineapple enzyme Bromelain-POS in children with acute sinusitis in Germany. In Vivo. Mar-Apr. 2005;19(2):417-21. X-2, X-4. [pmid: 15796206].
301 Brazer SR, Tyor MP, Pancotto FS, et al. Studies of gastric ulcer disease by community-based gastroenterologists. Am J Gastroenterol. Jul. 1990;85(7):824-8. X-2. [pmid: 2371983].
302 Breda A, Bui MH, Liao JC, et al. Association of bowel rest and ketorolac analgesia with short hospital stay after laparoscopic donor nephrectomy. Urology. May. 2007;69(5):828-31. X-2, X-3, X-4. [pmid: 17482915].
303 Breitner JC, Haneuse SJ, Walker R, et al. Risk of dementia and AD with prior exposure to NSAIDs in an elderly community-based cohort. Neurology. Jun. 2. 2009;72(22):1899-905. X-7. [pmid: 19386997].
304 Bremer JP, Ullrich S, Laudien M, et al. Methotrexate plus leflunomide for the treatment of relapsingWegener's granulomatosis. A retrospective uncontrolled study. Clin Exp Rheumatol. Jan-Feb. 2010;28(1 Suppl 57):67-71. X-2, X-4. [pmid: 20412706].
305 Breuer T, Martin K, Wilhelm M, et al. The blood sparing effect and the safety of aprotinin compared to tranexamic acid in paediatric cardiac surgery. Eur J Cardiothorac Surg. Jan. 2009;35(1):167-71. author reply 71. X-2. [pmid: 19027313].
306 Breuer-Katschinski B, Nemes K, Rump B, et al. Long-term use of nonsteroidal antiinflammatory drugs and the risk of colorectal adenomas. The Colorectal Adenoma Study Group. Digestion. 2000;61(2):129-34. X-2, X-4. [pmid: 10705177].
307 Bricker SR, Savage ME, Hanning CD. Peri-operative blood loss and non-steroidal anti-inflammatory drugs: an investigation using diclofenac in patients undergoing transurethral resection of the prostate. Eur J Anaesthesiol. Nov. 1987;4(6):429-34. X-2, X-6. [pmid: 3328684].
308 Briesacher B, Kamal-Bahl S, Hochberg M, et al. Three-tiered-copayment drug coverage and use of nonsteroidal anti-inflammatory drugs. Arch Intern Med. Aug. 9-23. 2004;164(15):1679-84. X-3, X-4. [pmid: 15302639].
309 Brinker A, Goldkind L, Bonnel R, et al. Spontaneous reports of hypertension leading to hospitalisation in association with rofecoxib, celecoxib, nabumetone and oxaprozin. Drugs Aging. 2004;21(7):479-84. X-3, X-4. [pmid: 15132714].
310 Briscoe TA, Anderson D, Usifo OS, et al. A retrospective analysis of the efficacy and safety of metformin in the African-American patient. J Natl Med Assoc. Nov. 1997;89(11):728-30. X-2. [pmid: 9375476].
311 Brock J, Sauaia A, Ahnen D, et al. Process of care and outcomes for elderly patients hospitalized with peptic ulcer disease: results from a quality improvement project. JAMA. Oct. 24-31. 2001;286(16):1985-93. X-3, X-4. [pmid: 11667935].
312 Brown DA, Vartan CM. Risk of venous thromboembolism with drospirenone-containing oral contraceptives. Am J Health Syst Pharm. Jun. 1. 2011;68(11):1003-10. X-1, X-2. [pmid: 21593228].
313 Brown EG, Waller PC, Sallie BA. Tiaprofenic acid and severe cystitis. Postgrad Med J. Jul. 1998;74(873):443-4. X-4. [pmid: 9799928].
314 Brown JS, Kulldorff M, Chan KA, et al. Early detection of adverse drug events within population-based health networks: application of sequential testing methods. Pharmacoepidemiol Drug Saf. Dec. 2007;16(12):1275-84. X-2, X-3, X-4. [pmid: 17955500].
315 Brown MD. Norplant: a welcome new contraceptive. Kans Med. Apr. 1993;94(4):110-1. X-1. [pmid: 8487456].
316 Brown NJ, Berkowitz RG. Epistaxis in healthy children requiring hospital admission. Int J Pediatr Otorhinolaryngol. Sep. 2004;68(9):1181-4. X-2, X-3, X-4. [pmid: 15302149].
317 Brucker C. Controlled trial with a monthly combination injectable contraceptive in Europe. Gynecol Endocrinol. Aug. Suppl 3. 2001;15:11-4. X-2. [pmid: 11570312].
318 Brune K, Katus HA, Moecks J, et al. N-terminal pro-B-type natriuretic peptide concentrations predict the risk of cardiovascular adverse events from antiinflammatory drugs: a pilot trial. Clin Chem. Jul. 2008;54(7):1149-57. X-2, X-3, X-4. [pmid: 18451314].
319 Brunser O, Espinoza J, Araya M, et al. Chronic iron intake and diarrhoeal disease in infants. A field study in a less-developed country. Eur J Clin Nutr. May. 1993;47(5):317-26. X-2, X-4. [pmid: 8319667].
320 Brzeski M, Madhok R, Capell HA. Evening primrose oil in patients with rheumatoid arthritis and side-effects of non-steroidal anti-inflammatory drugs. Br J Rheumatol. Oct. 1991;30(5):370-2. X-2, X-3, X-4. [pmid: 1913008].
321 Buchbinder R, Forbes A, Kobben F, et al. Clinical features of tiaprofenic acid (surgam) associated cystitis and a study of risk factors for its development. J Clin Epidemiol. Oct. 2000;53(10):1013-9. X-2, X-4. [pmid: 11027933].
322 Buck ML. Clinical experience with ketorolac in children. Ann Pharmacother. Sep. 1994;28(9):1009-13. X-2, X-4. [pmid: 7803871].
323 Buckshee K, Kumar S, Saraya L. Contraceptive vaginal ring--a rising star on the contraceptive horizon. Adv Contracept. Sep. 1990;6(3):177-83. X-2, X-4. [pmid: 2123369].
324 Bueno H, Bardaji A, Patrignani P, et al. Use of non-steroidal antiinflammatory drugs and type-specific risk of acute coronary syndrome. Am J Cardiol. Apr. 15. 2010;105(8):1102-6. X-4. [pmid: 20381660].
325 Bunton RW, Barrett DC, Palmer DG. Reintroduction of anti-inflammatory drug therapy after drug-associated gastro-intestinal disturbances. N Z Med J. Aug. 25. 1982;95(714):582-4. X-2. [pmid: 6982441].
326 Bunyaratavej N, Keorochana S, Pithkul S. Safety and efficacy of meloxicam 7.5 mg in the treatment of osteoarthritis in Thai patients. J Med Assoc Thai. Oct. Suppl 2. 2001;84:S542-6. X-2, X-4. [pmid: 11853278].
327 Burch DJ, Spowart KJ, Jesinger DK, et al. A dose-ranging study of the use of cyclical dydrogesterone with continuous 17 beta oestradiol. Br J Obstet Gynaecol. Mar. 1995;102(3):243-8. X-2, X-4. [pmid: 7794851].
328 Burkhardt H, Bruckner D, Gladisch R. Risk factors of worsening renal function in hospitalized elderly patients. J Nephrol. Mar-Apr. 2005;18(2):166-73. X-2, X-3, X-4. [pmid: 15931644].
329 Burnhill MS. The use of a large-scale surveillance system in Planned Parenthood Federation of America clinics to monitor cardiovascular events in users of combination oral contraceptives. Int J Fertil Womens Med. Jan-Feb. 1999;44(1):19-30. X-4. [pmid: 10206196].
330 Burns B, Watkins L, Goadsby PJ. Treatment of hemicrania continua by occipital nerve stimulation with a bion device: long-term follow-up of a crossover study. Lancet Neurol. Nov. 2008;7(11):1001-12. X-2, X-3, X-4. [pmid: 18845482].
331 Buse JB, Klonoff DC, Nielsen LL, et al. Metabolic effects of two years of exenatide treatment on diabetes, obesity, and hepatic biomarkers in patients with type 2 diabetes: an interim analysis of data from the open-label, uncontrolled extension of three double-blind, placebo-controlled trials. Clin Ther. Jan. 2007;29(1):139-53. X-2, X-3, X-4. [pmid: 17379054].
332 Butler AJ, Green A, Cohen M. Multi-centre open study of a triphasic levonorgestrel-ethinyloestradiol combined oral contraceptive (‘Trinordiol’). Curr Med Res Opin. 1987;10(8):503-13. X-4. [pmid: 2960493].
333 Buurma H, De Smet PA, Egberts AC. Clinical risk management in Dutch community pharmacies: the case of drug-drug interactions. Drug Saf. 2006;29(8):723-32. X-4. [pmid: 16872246].
334 Buysschaert M, Preumont V, Oriot PR, et al. One-year metabolic outcomes in patients with type 2 diabetes treated with exenatide in routine practice. Diabetes Metab. Nov. 2010;36(5):381-8. X-2, X-4. [pmid: 20598606].
335 Byamugisha JK, Mirembe FM, Faxelid E, et al. A randomized clinical trial of two emergency contraceptive pill regimens in a Ugandan population. Acta Obstet Gynecol Scand. May. 2010;89(5):670-6. X-2, X-4. [pmid: 20423278].
336 Bytzer P, Talley NJ, Jones MP, et al. Oral hypoglycaemic drugs and gastrointestinal symptoms in diabetes mellitus. Aliment Pharmacol Ther. Jan. 2001;15(1):137-42. X-2. [pmid: 11136287].
337 Caballero-Gordo A, Lopez-Nazareno N, Calderay M, et al. Oral cabergoline. Single-dose inhibition of puerperal lactation. J Reprod Med. Oct. 1991;36(10):717-21. X-2. [pmid: 1683403].
338 Cabrol D, Jannet D, Pannier E. Treatment of symptomatic polyhydramnios with indomethacin. Eur J Obstet Gynecol Reprod Biol. May. 1996;66(1):11-5. X-2, X-3, X-4. [pmid: 8735752].
339 Cady RK, Banks J, Jones BA, et al. Postmarketing migraine survey of frovatriptan: effectiveness and tolerability vs previous triptans, NSAIDs or a combination. Curr Med Res Opin. Nov. 2009;25(11):2711-21. X-4. [pmid: 19778164].
340 Caglar GS, Tasci Y, Kayikcioglu F, et al. Intravenous tranexamic acid use in myomectomy: a prospective randomized double-blind placebo controlled study. Eur J Obstet Gynecol Reprod Biol. Apr. 2008;137(2):227-31. X-2, X-3, X-4. [pmid: 17499419].
341 Cagnacci A, Ferrari S, Tirelli A, et al. Route of administration of contraceptives containing desogestrel/etonorgestrel and insulin sensitivity: a prospective randomized study. Contraception. Jul. 2009;80(1):34-9. X-2, X-3, X-4. [pmid: 19501213].
342 Cai XM, Wu J. The mind-tranquilizing and menstruation-regulating method for acupuncture treatment of delayed menstrual cycle--a clinical controlled study. J Tradit Chin Med. Mar. 2009;29(1):35-8. X-2, X-3, X-4. [pmid: 19514186].
343 Calabrese AT, Coley KC, DaPos SV, et al. Evaluation of prescribing practices: risk of lactic acidosis with metformin therapy. Arch Intern Med. Feb. 25. 2002;162(4):434-7. X-2, X-3, X-4. [pmid: 11863476].
344 Caldwell JR, Roth SH, Wu WC, et al. Sucralfate treatment of nonsteroidal anti-inflammatory drug-induced gastrointestinal symptoms and mucosal damage. Am J Med. Sep. 28. 1987;83(3B):74-82. X-2, X-3, X-4. [pmid: 3310631].
345 Caldwell M, Reilly C. Effects of topical nepafenac on corneal epithelial healing time and postoperative pain after PRK: a bilateral, prospective, randomized, masked trial. J Refract Surg. Apr. 2008;24(4):377-82. X-2, X-3, X-4. [pmid: 18500088].
346 Caliskan E, Ozturk N, Dilbaz BO, et al. Analysis of risk factors associated with uterine perforation by intrauterine devices. Eur J Contracept Reprod Health Care. Sep. 2003;8(3):150-5. X-2, X-4. [pmid: 14667326].
347 Calle EE, Feigelson HS, Hildebrand JS, et al. Postmenopausal hormone use and breast cancer associations differ by hormone regimen and histologic subtype. Cancer. Mar. 1. 2009;115(5):936-45. X-4, X-7. [pmid: 19156895].
348 Callejo J, Diaz J, Ruiz A, et al. Effect of a low-dose oral contraceptive containing 20 microg ethinylestradiol and 150 microg desogestrel on dysmenorrhea. Contraception. Sep. 2003;68(3):183-8. X-2, X-3, X-4. [pmid: 14561538].
349 Calvo-Alen J, De Cos MA, Rodriguez-Valverde V, et al. Subclinical renal toxicity in rheumatic patients receiving longterm treatment with nonsteroidal antiinflammatory drugs. J Rheumatol. Sep. 1994;21(9):1742-7. X-2. [pmid: 7799360].
350 Cameron IT, Haining R, Lumsden MA, et al. The effects of mefenamic acid and norethisterone on measured menstrual blood loss. Obstet Gynecol. Jul. 1990;76(1):85-8. X-2, X-3, X-4. [pmid: 2359570].
351 Cameron IT, Leask R, Kelly RW, et al. The effects of danazol, mefenamic acid, norethisterone and a progesterone-impregnated coil on endometrial prostaglandin concentrations in women with menorrhagia. Prostaglandins. Jul. 1987;34(1):99-110. X-2, X-3, X-4. [pmid: 3685399].
352 Campbell DR, Haber MM, Sheldon E, et al. Effect of H. pylori status on gastric ulcer healing in patients continuing nonsteroidal anti-inflammatory therapy and receiving treatment with lansoprazole or ranitidine. Am J Gastroenterol. Sep. 2002;97(9):2208-14. X-2, X-3, X-4. [pmid: 12358234].
353 Campbell K, Steele RJ. Non-steroidal anti-inflammatory drugs and complicated diverticular disease: a case-control study. Br J Surg. Feb. 1991;78(2):190-1. X-2. [pmid: 2015469].
354 Campbell KL, De Beaux AC. Non-steroidal anti-inflammatory drugs and appendicitis in patients aged over 50 years. Br J Surg. Sep. 1992;79(9):967-8. X-2. [pmid: 1307702].
355 Campos-Fernandez Mdel M, Ponce-De-Leon-Rosales S, Archer-Dubon C, et al. Incidence and risk factors for cutaneous adverse drug reactions in an intensive care unit. Rev Invest Clin. Nov-Dec. 2005;57(6):770-4. X-2, X-4. [pmid: 16708902].
356 Cannon GW, Holden WL, Juhaeri J, et al. Adverse events with disease modifying antirheumatic drugs (DMARD): a cohort study of leflunomide compared with other DMARD. J Rheumatol. Oct. 2004;31(10):1906-11. X-4. [pmid: 15468352].
357 Cano A, Calaf J, Molina J. The lipid and clinical effects of sequential transdermal estradiol and estradiol/norethisterone acetate in 674 women. Arch Gynecol Obstet. Oct. 2003;268(4):317-22. X-2, X-4. [pmid: 14504877].
358 Cano A, Tarin JJ, Duenas JL. Two-year prospective, randomized trial comparing an innovative twice-a-week progestin regimen with a continuous combined regimen as postmenopausal hormone therapy. Fertil Steril. Jan. 1999;71(1):129-36. X-2, X-4. [pmid: 9935129].
359 Canto TE, Vera L, Polanco LE, et al. Mini-pill in lactating women. Contraception. Jun. 1989;39(6):589-601. X-2. [pmid: 2752751].
360 Capizzi R, Landi F, Milani M, et al. Skin tolerability and efficacy of combination therapy with hydrogen peroxide stabilized cream and adapalene gel in comparison with benzoyl peroxide cream and adapalene gel in common acne. A randomized, investigator-masked, controlled trial. Br J Dermatol. Aug. 2004;151(2):481-4. X-2, X-3, X-4. [pmid: 15327558].
361 Capriles-Behrens E, Caplin J, Sanchez-Borges M. NSAID facial angioedema in a selected pediatric atopic population. J Investig Allergol Clin Immunol. Sep-Oct. 2000;10(5):277-9. X-2. [pmid: 11108437].
362 Capuano A, Motola G, Russo F, et al. Adverse drug events in two emergency departments in Naples, Italy: an observational study. Pharmacol Res. Dec. 2004;50(6):631-6. X-4. [pmid: 15501703].
363 Carbonell N, Verstuyft C, Massard J, et al. CYP2C9*3 Loss-of-Function Allele Is Associated With Acute Upper Gastrointestinal Bleeding Related to the Use of NSAIDs Other Than Aspirin. Clin Pharmacol Ther. Jun. 2010;87(6):693-8. X-2, X-4. [pmid: 20445534].
364 Carcopino X, Akkawi R, Conroy R, et al. Specific timing for colposcopy: is it worthwhile?. Obstet Gynecol. Feb. 2008;111(2 Pt 1):373-7. X-2, X-3, X-4. [pmid: 18238975].
365 Cardamakis E, Georgopoulos A, Fotopoulos A, et al. Clinical experience with Norplant subdermal implant system as long-term contraception during adolescence. Eur J Contracept Reprod Health Care. Mar. 2002;7(1):36-40. X-2, X-4. [pmid: 12041863].
366 Cardoso F, Polonia J, Santos A, et al. Low-dose oral contraceptives and 24-hour ambulatory blood pressure. Int J Gynaecol Obstet. Dec. 1997;59(3):237-43. X-2. [pmid: 9486514].
367 Cardoso JC, Canelas MM, Goncalo M, et al. Photopatch testing with an extended series of photoallergens: a 5-year study. Contact Dermatitis. Jun. 2009;60(6):325-9. X-2, X-3, X-4. [pmid: 19489967].
368 Carne X, Rios J, Torres F. Postmarketing cohort study to assess the safety profile of oral dexketoprofen trometamol for mild to moderate acute pain treatment in primary care. Methods Find Exp Clin Pharmacol. Oct. 2009;31(8):533-40. X-4. [pmid: 19967102].
369 Carney DE, Nicolette LA, Ratner MH, et al. Ketorolac reduces postoperative narcotic requirements. J Pediatr Surg. Jan. 2001;36(1):76-9. X-2, X-3, X-4. [pmid: 11150441].
370 Carr BR. Cycle control with desogestrel-containing oral contraceptives--comparison of a monophasic and triphasic regimen. Int J Fertil Menopausal Stud. Sep-Oct. 1993;38(5):274-9. X-4. [pmid: 8298666].
371 Carson JL. A case study: nonsteroidal antiinflammatory drugs and gastrointestinal bleeding. J Rheumatol Suppl. Oct. 1988;17:24-7. X-4. [pmid: 3264583].
372 Carson JL, Strom BL, Duff A, et al. Safety of nonsteroidal anti-inflammatory drugs with respect to acute liver disease. Arch Intern Med. Jun. 14. 1993;153(11):1331-6. X-2, X-4. [pmid: 8507123].
373 Carson JL, Strom BL, Morse ML, et al. The relative gastrointestinal toxicity of the nonsteroidal anti-inflammatory drugs. Arch Intern Med. Jun. 1987;147(6):1054-9. X-4. [pmid: 3496062].
374 Carson JL, Strom BL, Soper KA, et al. The association of nonsteroidal anti-inflammatory drugs with upper gastrointestinal tract bleeding. Arch Intern Med. Jan. 1987;147(1):85-8. X-4. [pmid: 3492182].
375 Carton E, Caldwell MT, McDonald G, et al. Specialized intestinal metaplasia in patients with gastro-oesophageal reflux disease. Br J Surg. Jan. 2000;87(1):116-21. X-2, X-3, X-4. [pmid: 10606922].
376 Caruso S, Agnello C, Intelisano G, et al. Prospective study on sexual behavior of women using 30 microg ethinylestradiol and 3 mg drospirenone oral contraceptive. Contraception. Jul. 2005;72(1):19-23. X-2, X-4. [pmid: 15964287].
377 Caruso S, Grillo C, Agnello C, et al. A prospective study evidencing rhinomanometric and olfactometric outcomes in women taking oral contraceptives. Hum Reprod. Nov. 2001;16(11):2288-94. X-2, X-4. [pmid: 11679506].
378 Carvajal A, Arias LH, Vega E, et al. Gastroprotection during the administration of non-steroidal anti-inflammatory drugs. A drug-utilization study. Eur J Clin Pharmacol. Aug. 2004;60(6):439-44. X-2, X-3, X-4. [pmid: 15221157].
379 Casado-Arroyo R, Scheiman JM, Polo-Tomas M, et al. Underutilization of gastroprotection for at-risk patients undergoing percutaneous coronary intervention: Spain compared with the United States. Aliment Pharmacol Ther. Sep. 2010;32(5):689-95. X-2, X-3, X-4. [pmid: 20626380].
380 Casati V, Gerli C, Franco A, et al. Tranexamic acid in off-pump coronary surgery: a preliminary, randomized, double-blind, placebo-controlled study. Ann Thorac Surg. Aug. 2001;72(2):470-5. X-2, X-4. [pmid: 11515884].
381 Casella G, Villanacci V, Fisogni S, et al. Colonic left-side increase of eosinophils: a clue to drug-related colitis in adults. Aliment Pharmacol Ther. Mar. 1. 2009;29(5):535-41. X-2, X-3. [pmid: 19077107].
382 Cassidy N, Duggan E, Williams DJ, et al. The epidemiology and type of medication errors reported to the National Poisons Information Centre of Ireland. Clin Toxicol (Phila). Jul. 2011;49(6):485-91. X-4 X-8. [pmid: 21824059].
383 Cassina M, De Santis M, Cesari E, et al. First trimester diclofenac exposure and pregnancy outcome. Reprod Toxicol. Nov. 2010;30(3):401-4. X-2, X-4. [pmid: 20438830].
384 Castelao JE, Yuan JM, Gago-Dominguez M, et al. Non-steroidal anti-inflammatory drugs and bladder cancer prevention. Br J Cancer. Apr. 2000;82(7):1364-9. X-4. [pmid: 10755416].
385 Castellsague J, Holick CN, Hoffman CC, et al. Risk of upper gastrointestinal complications associated with cyclooxygenase-2 selective and nonselective nonsteroidal antiinflammatory drugs. Pharmacotherapy. Dec. 2009;29(12):1397-407. X-4. [pmid: 19947799].
386 Castellsague X, Diaz M, Vaccarella S, et al. Intrauterine device use, cervical infection with human papillomavirus, and risk of cervical cancer: a pooled analysis of 26 epidemiological studies. Lancet Oncol. Oct. 2011;12(11):1023-31. X-1, X-4, X-8. [pmid: 21917519].
387 Castelo-Branco C, Moyano D, Gomez O, et al. Long-term safety and tolerability of flutamide for the treatment of hirsutism. Fertil Steril. Apr. 2009;91(4):1183-8. X-2, X-3, X-4. [pmid: 18339379].
388 Castle PE, Walker JL, Schiffman M, et al. Hormonal contraceptive use, pregnancy and parity, and the risk of cervical intraepithelial neoplasia 3 among oncogenic HPV DNA-positive women with equivocal or mildly abnormal cytology. Int J Cancer. Dec. 20. 2005;117(6):1007-12. X-4. [pmid: 15986443].
389 Catalano O. Greater curvature antral flattening due to nonsteroidal antiinflammatory drugs. Rofo. Aug. 1997;167(2):122-4. X-2. [pmid: 9309163].
390 Cataldi L, Leone R, Moretti U, et al. Potential risk factors for the development of acute renal failure in preterm newborn infants: a case-control study. Arch Dis Child Fetal Neonatal Ed. Nov. 2005;90(6):F514-9. X-2, X-4. [pmid: 16244211].
391 Caughey GE, Roughead EE, Pratt N, et al. Stroke risk and NSAIDs: an Australian population-based study. Med J Aust. Nov. 7. 2011;195(9):525-9. X-7. [pmid: 22060087].
392 Caunedo-Alvarez A, Gomez-Rodriguez BJ, Romero-Vazquez J, et al. Macroscopic small bowel mucosal injury caused by chronic nonsteroidal anti-inflammatory drugs (NSAID) use as assessed by capsule endoscopy. Rev Esp Enferm Dig. Feb. 2010;102(2):80-5. X-2. [pmid: 20361843].
393 Cebollero-Santamaria F, Smith J, Gioe S, et al. Selective outpatient management of upper gastrointestinal bleeding in the elderly. Am J Gastroenterol. May. 1999;94(5):1242-7. X-2, X-3. [pmid: 10235201].
394 Cepeda MS, Farrar JT, Baumgarten M, et al. Side effects of opioids during short-term administration: effect of age, gender, and race. Clin Pharmacol Ther. Aug. 2003;74(2):102-12. X-4. [pmid: 12891220].
395 Cerhan JR, Anderson KE, Janney CA, et al. Association of aspirin and other non-steroidal anti-inflammatory drug use with incidence of non-Hodgkin lymphoma. Int J Cancer. Sep. 20. 2003;106(5):784-8. X-4, X-7. [pmid: 12866040].
396 Chalasani N, Patel K, Clark WS, et al. The prevalence and significance of leukocytosis in upper gastrointestinal bleeding. Am J Med Sci. Apr. 1998;315(4):233-6. X-2, X-3, X-4. [pmid: 9537636].
397 Chalmers RT, Darling Iii RC, Wingard JT, et al. Randomized clinical trial of tranexamic acid-free fibrin sealant during vascular surgical procedures. Br J Surg. Dec. 2010;97(12):1784-9. X-2, X-4. [pmid: 20730858].
398 Cham E, Hall L, Ernst AA, et al. Awareness and use of over-the-counter pain medications: a survey of emergency department patients. South Med J. May. 2002;95(5):529-35. X-2, X-3, X-4. [pmid: 12005011].
399 Chan AT, Manson JE, Albert CM, et al. Nonsteroidal antiinflammatory drugs, acetaminophen, and the risk of cardiovascular events. Circulation. Mar. 28. 2006;113(12):1578-87. X-4. [pmid: 16534006].
400 Chan FK, Hung LC, Suen BY, et al. Celecoxib versus diclofenac and omeprazole in reducing the risk of recurrent ulcer bleeding in patients with arthritis. N Engl J Med. Dec. 26. 2002;347(26):2104-10. X-2, X-3, X-4. [pmid: 12501222].
401 Chan FK, Sung JJ, Ching JY, et al. Randomized trial of low-dose misoprostol and naproxen vs. nabumetone to prevent recurrent upper gastrointestinal haemorrhage in users of non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. Jan. 2001;15(1):19-24. X-2. [pmid: 11136274].
402 Chan FK, Sung JJ, Chung SC, et al. Randomised trial of eradication of Helicobacter pylori before non-steroidal anti-inflammatory drug therapy to prevent peptic ulcers. Lancet. Oct. 4. 1997;350(9083):975-9. X-2, X-3, X-4. [pmid: 9329511].
403 Chan HL, Wu JC, Chan FK, et al. Is non-Helicobacter pylori, non-NSAID peptic ulcer a common cause of upper GI bleeding? A prospective study of 977 patients. Gastrointest Endosc. Apr. 2001;53(4):438-42. X-4. [pmid: 11275883].
404 Chan JK, Sleat G, Sharma S, et al. Gastroprotection in trauma patients receiving non-steroidal anti-inflammatory drugs. Surgeon. Aug. 2010;8(4):206-10. X-2, X-3, X-4. [pmid: 20569940].
405 Chan SS, Luben R, Bergmann MM, et al. Aspirin in the aetiology of Crohn's disease and ulcerative colitis: a European prospective cohort study. Aliment Pharmacol Ther. Sep. 2011;34(6):649-55. X-4. [pmid: 21790683].
406 Chan TM, Tse KC, Tang CS, et al. Long-term study of mycophenolate mofetil as continuous induction and maintenance treatment for diffuse proliferative lupus nephritis. J Am Soc Nephrol. Apr. 2005;16(4):1076-84. X-2, X-3, X-4. [pmid: 15728784].
407 Chan TY, Critchley JA, Lau JT, et al. The relationship between upper gastrointestinal hemorrhage and drug use: a case control study. Int J Clin Pharmacol Ther. Jul. 1996;34(7):304-8. X-2. [pmid: 8832307].
408 Chande N, Driman DK, Reynolds RP. Collagenous colitis and lymphocytic colitis: patient characteristics and clinical presentation. Scand J Gastroenterol. Mar. 2005;40(3):343-7. X-2, X-3, X-4. [pmid: 15932175].
409 Chang CH, Chen HC, Lin JW, et al. Risk of hospitalization for upper gastrointestinal adverse events associated with nonsteroidal anti-inflammatory drugs: a nationwide case-crossover study in Taiwan. Pharmacoepidemiol Drug Saf. Jul. 2011;20(7):763-71. X-4. [pmid: 21618340].
410 Chang CH, Lin JW, Chen HC, et al. Non-steroidal anti-inflammatory drugs and risk of lower gastrointestinal adverse events: a nationwide study in Taiwan. Gut. Oct. 2011;60(10):1372-8. X-4. [pmid: 21415083].
411 Chang CH, Shau WY, Kuo CW, et al. Increased risk of stroke associated with nonsteroidal anti-inflammatory drugs: a nationwide case-crossover study. Stroke. Sep. 2010;41(9):1884-90. X-4. [pmid: 20671253].
412 Chang CY, Wu MS, Lee CT, et al. Prospective survey for the etiology and outcome of peptic ulcer bleeding: a community based study in southern Taiwan. J Formos Med Assoc. Apr. 2011;110(4):223-9. X-2. [pmid: 21540004].
413 Chang JY, Locke GR, Schleck CD, et al. Risk factors for chronic constipation and a possible role of analgesics. Neurogastroenterol Motil. Nov. 2007;19(11):905-11. X-2. [pmid: 17988275].
414 Charonis G, Larsson PG. Prolonged use of intrauterine contraceptive device as a risk factor for tubo-ovarian abscess. Acta Obstet Gynecol Scand. 2009;88(6):680-4. X-2. [pmid: 19412803].
415 Chasan-Taber L, Willett WC, Stampfer MJ, et al. A prospective study of oral contraceptives and NIDDM among U.S. women. Diabetes Care. Mar. 1997;20(3):330-5. X-4. [pmid: 9051382].
416 Chassaignon C, Letoumelin P, Pateron D. Upper gastrointestinal haemorrhage in Emergency Departments in France: causes and management. Eur J Emerg Med. Dec. 2003;10(4):290-5. X-2, X-4. [pmid: 14676507].
417 Chattopdhyay B, Nigam A, Goswami S, et al. Clinical outcome of levonorgestrel intra-uterine system in idiopathic menorrhagia. Eur Rev Med Pharmacol Sci. Jul. 2011;15(7):764-8. X-2, X-4. [pmid: 21780544].
418 Chaudhuri SK, Das A, De KC, et al. Some hitherto unreported findings on the extragenital effects of progesterone in human females--a clinical study. Indian J Physiol Pharmacol. Jul. 1994;38(3):174-80. X-2, X-3. [pmid: 7814077].
419 Check JH, Rankin A, Teichman M. The risk of fetal anomalies as a result of progesterone therapy during pregnancy. Fertil Steril. Apr. 1986;45(4):575-7. X-2, X-3, X-4. [pmid: 3956772].
420 Cheetham TC, Levy G, Niu F, et al. Gastrointestinal safety of nonsteroidal antiinflammatory drugs and selective cyclooxygenase-2 inhibitors in patients on warfarin. Ann Pharmacother. Nov. 2009;43(11):1765-73. X-4. [pmid: 19809010].
421 Cheetham TC, Levy G, Spence M. Predicting the risk of gastrointestinal bleeding due to nonsteroidal antiinflammatory drugs: NSAID electronic assessment of risk. J Rheumatol. Oct. 2003;30(10):2241-4. X-4. [pmid: 14528523].
422 Chegini N, Rhoton-Vlasak A, Williams RS. Expression of matrix metalloproteinase-26 and tissue inhibitor of matrix metalloproteinase-3 and -4 in endometrium throughout the normal menstrual cycle and alteration in users of levonorgestrel implants who experience irregular uterine bleeding. Fertil Steril. Sep. 2003;80(3):564-70. X-2, X-3, X-4. [pmid: 12969699].
423 Chen C, Li Y, Chen F, et al. Estrogen receptor beta genetic variants and combined oral contraceptive use as relates to the risk of hypertension in Chinese women. Arch Med Res. Nov. 2010;41(8):599-605. X-2, X-3. [pmid: 21199728].
424 Chen CH, Chiu CC, Huang MC, et al. Metformin for metabolic dysregulation in schizophrenic patients treated with olanzapine. Prog Neuropsychopharmacol Biol Psychiatry. May. 15. 2008;32(4):925-31. X-2, X-3, X-4. [pmid: 18082302].
425 Chen FP, Lee N, Wang CH, et al. Effects of hormone replacement therapy on cardiovascular risk factors in postmenopausal women. Fertil Steril. Feb. 1998;69(2):267-73. X-2, X-4. [pmid: 9496340].
426 Chen JY, Wu GJ, Mok MS, et al. Effect of adding ketorolac to intravenous morphine patient-controlled analgesia on bowel function in colorectal surgery patients--a prospective, randomized, double-blind study. Acta Anaesthesiol Scand. Apr. 2005;49(4):546-51. X-2, X-3, X-4. [pmid: 15777304].
427 Chen MJ, Yang WS, Chen HF, et al. Increased follistatin levels after oral contraceptive treatment in obese and non-obese women with polycystic ovary syndrome. Hum Reprod. Mar. 2010;25(3):779-85. X-2, X-3, X-4. [pmid: 20093255].
428 Chen QJ, Xiang WP, Zhang DK, et al. Efficacy and safety of a levonorgestrel enteric-coated tablet as an over-the-counter drug for emergency contraception: a Phase IV clinical trial. Hum Reprod. Sep. 2011;26(9):2316-21. X-4. [pmid: 21672924].
429 Chen TM, Lin CC, Huang PT, et al. Metformin associated with lower mortality in diabetic patients with early stage hepatocellular carcinoma after radiofrequency ablation. J Gastroenterol Hepatol. May. 2011;26(5):858-65. X-2, X-3. [pmid: 21251068].
430 Cheraghali AM. Injectable diclofenac: a painful shot into Iran's health system. Soc Sci Med. Sep. 2006;63(6):1597-601. X-2, X-4. [pmid: 16782253].
431 Cherian PT, Cherian S, Singh P. Long-term follow-up of patients with gastric outlet obstruction related to peptic ulcer disease treated with endoscopic balloon dilatation and drug therapy. Gastrointest Endosc. Sep. 2007;66(3):491-7. X-2, X-3, X-4. [pmid: 17640640].
432 Chi IC, Potts M, Wilkens LR, et al. Performance of the copper T-380A intrauterine device in breastfeeding women. Contraception. Jun. 1989;39(6):603-18. X-2, X-4. [pmid: 2666018].
433 Chi IC, Waszak CS, Wilkens LR. Do insertion-related problems affect subsequent IUD performance?. Contraception. Nov. 1986;34(5):497-503. X-2, X-4. [pmid: 3816233].
434 Chiba T, Sato K, Kudara N, et al. Upper gastrointestinal disorders induced by non-steroidal anti-inflammatory drugs. Inflammopharmacology. Feb. 2008;16(1):16-20. X-2. [pmid: 18256801].
435 Chin CJ, Franklin JH, Turner B, et al. Ketorolac in thyroid surgery: quantifying the risk of hematoma. J Otolaryngol Head Neck Surg. Jun. 1. 2011;40(3):196-9. X-2, X-4. [pmid: 21518639].
436 Chittacharoen A, Domhardt R, Manonai J, et al. Efficacy and tolerability of the hormone replacement drug estradiol valerate/levonorgestrel in the treatment of menopausal syndrome in Thai women. Methods Find Exp Clin Pharmacol. Oct. 2003;25(8):645-51. X-2, X-4. [pmid: 14671683].
437 Chlebowski RT, Anderson GL, Gass M, et al. Estrogen plus progestin and breast cancer incidence and mortality in postmenopausal women. JAMA. Oct. 20. 2010;304(15):1684-92. X-7. [pmid: 20959578].
438 Chlebowski RT, Hendrix SL, Langer RD, et al. Influence of estrogen plus progestin on breast cancer and mammography in healthy postmenopausal women: the Women's Health Initiative Randomized Trial. JAMA. Jun. 25. 2003;289(24):3243-53. X-7. [pmid: 12824205].
439 Chlebowski RT, Kuller LH, Prentice RL, et al. Breast cancer after use of estrogen plus progestin in postmenopausal women. N Engl J Med. Feb. 5. 2009;360(6):573-87. X-4, X-7. [pmid: 19196674].
440 Cho E, Curhan G, Hankinson SE, et al. Prospective evaluation of analgesic use and risk of renal cell cancer. Arch Intern Med. Sep. 12. 2011;171(16):1487-93. X-4. [pmid: 21911634].
441 Choi HK, Seeger JD, Kuntz KM. Effects of rofecoxib and naproxen on life expectancy among patients with rheumatoid arthritis: a decision analysis. Am J Med. May. 1. 2004;116(9):621-9. X-4, X-7. [pmid: 15093759].
442 Choi KH, Kim AJ, Son IJ, et al. Risk factors of drug interaction between warfarin and nonsteroidal anti-inflammatory drugs in practical setting. J Korean Med Sci. Mar. 2010;25(3):337-41. X-2. [pmid: 20191029].
443 Choi NK, Hahn S, Yoon BW, et al. Potential bias caused by control selection in secondary data analysis: nonaspirin nonsteroidal anti-inflammatory drugs and hemorrhagic stroke. Pharmacoepidemiol Drug Saf. Jun. 2010;19(6):604-9. X-4. [pmid: 20049849].
444 Choi NK, Park BJ, Jeong SW, et al. Nonaspirin nonsteroidal anti-inflammatory drugs and hemorrhagic stroke risk: the Acute Brain Bleeding Analysis study. Stroke. Mar. 2008;39(3):845-9. X-4. [pmid: 18258834].
445 Chokrungvaranon N, Chentanez T, Arakaki RF. Clinical experience with exenatide in predominantly Asian and Pacific Islander patients with type 2 diabetes. Endocrine. Dec. 2007;32(3):311-6. X-2, X-4. [pmid: 18266113].
446 Choma NN, Griffin MR, Huang RL, et al. An algorithm to identify incident myocardial infarction using Medicaid data. Pharmacoepidemiol Drug Saf. Nov. 2009;18(11):1064-71. X-2, X-3, X-4. [pmid: 19718697].
447 Choo PW, Donahue JG, Platt R. Ibuprofen and skin and soft tissue superinfections in children with varicella. Ann Epidemiol. Oct. 1997;7(7):440-5. X-4. [pmid: 9349910].
448 Chotnopparatpattara P, Taneepanichskul S, Treratanachat S, et al. Relationship between progesterone receptor level in endometrium and bleeding pattern in depot medroxyprogesterone acetate users. J Med Assoc Thai. Feb. 2003;86(2):172-7. X-2, X-3, X-4. [pmid: 12678156].
449 Chou TC, Chang HY, Chen CJ, et al. Effect of hand dermatitis on the total body burden of chromium after ferrous sulfate application in cement among cement workers. Contact Dermatitis. Sep. 2008;59(3):151-6. X-2, X-3, X-4. [pmid: 18759895].
450 Choudhary DR, Naithani R, Mahapatra M, et al. Intracranial hemorrhage in childhood immune thrombocytopenic purpura. Pediatr Blood Cancer. Apr. 2009;52(4):529-31. X-2, X-3, X-4. [pmid: 19058201].
451 Chow GK, Fabrizio MD, Steer T, et al. Prospective double-blind study of effect of ketorolac administration after laparoscopic urologic surgery. J Endourol. Mar. 2001;15(2):171-4. X-2, X-3, X-4. [pmid: 11325088].
452 Chowdhury A, Ganguly G, Chowdhury D, et al. Gastro-duodenal mucosal changes associated with low-dose aspirin therapy: a prospective, endoscopic study. Indian J Gastroenterol. Nov-Dec. 2001;20(6):227-9. X-2, X-3, X-4. [pmid: 11817775].
453 Christen WG, Ajani UA, Schaumberg DA, et al. Aspirin use and risk of cataract in posttrial follow-up of Physicians' Health Study I. Arch Ophthalmol. Mar. 2001;119(3):405-12. X-4. [pmid: 11231774].
454 Christensen ST, Sondergaard B, Honore PH, et al. Pharmacy student driven detection of adverse drug reactions in the community pharmacy setting. Pharmacoepidemiol Drug Saf. Apr. 2011;20(4):399-404. X-2, X-3, X-4. [pmid: 21442686].
455 Christie GA, Lucas C, Bateman DN, et al. Redefining the ACE-inhibitor dose-response relationship: substantial blood pressure lowering after massive doses. Eur J Clin Pharmacol. Dec. 2006;62(12):989-93. X-2, X-3, X-4. [pmid: 17089106].
456 Chrubasik S, Kunzel O, Model A, et al. Treatment of low back pain with a herbal or synthetic anti-rheumatic: a randomized controlled study. Willow bark extract for low back pain. Rheumatology (Oxford). Dec. 2001;40(12):1388-93. X-2, X-3, X-4. [pmid: 11752510].
457 Chrubasik S, Kunzel O, Thanner J, et al. A 1-year follow-up after a pilot study with Doloteffin for low back pain. Phytomedicine. Jan. 2005;12(1-2):1-9. X-2, X-3, X-4. [pmid: 15693701].
458 Ciarrocca KN, Greenberg MS. A retrospective study of the management of oral mucous membrane pemphigoid with dapsone. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Aug. 1999;88(2):159-63. X-2, X-3, X-4. [pmid: 10468458].
459 Cibere J, Sibley JT, Haga M. Rheumatologists' adherence to guidelines for misoprostol use in patients at high risk for nonsteroidal antiinflammatory drug gastropathy. J Rheumatol. Feb. 2002;29(2):339-46. X-2, X-3, X-4. [pmid: 11838854].
460 Cino M, Greenberg GR. Bone mineral density in Crohn's disease: a longitudinal study of budesonide, prednisone, and nonsteroid therapy. Am J Gastroenterol. Apr. 2002;97(4):915-21. X-2, X-4. [pmid: 12003427].
461 Civic D, Scholes D, Ichikawa L, et al. Depressive symptoms in users and non-users of depot medroxyprogesterone acetate. Contraception. Jun. 2000;61(6):385-90. X-2. [pmid: 10958882].
462 Clark MK, Dillon JS, Sowers M, et al. Weight, fat mass, and central distribution of fat increase when women use depot-medroxyprogesterone acetate for contraception. Int J Obes (Lond). Oct. 2005;29(10):1252-8. X-2. [pmid: 15997247].
463 Clark MK, Sowers MR, Nichols S, et al. Bone mineral density changes over two years in first-time users of depot medroxyprogesterone acetate. Fertil Steril. Dec. 2004;82(6):1580-6. X-2. [pmid: 15589863].
464 Clark MK, Stockdale CK, Railsback L, et al. Differences in cervical cytologic and histologic findings between women using depot-medroxyprogesterone acetate and oral contraceptives. J Low Genit Tract Dis. Jul. 2011;15(3):219-23. X-2. [pmid: 21716050].
465 Clarke LL, Schmitt K, Bono CA, et al. Norplant selection and satisfaction among low-income women. Am J Public Health. Aug. 1998;88(8):1175-81. X-2, X-3, X-4. [pmid: 9702143].
466 Clayton R, Chaudhry S, Ali I, et al. Mucosal (oral and vulval) lichen planus in women: are angiotensin-converting enzyme inhibitors protective, and beta-blockers and non-steroidal anti-inflammatory drugs associated with the condition?. Clin Exp Dermatol. Jun. 2010;35(4):384-7. X-2. [pmid: 19874335].
467 Cleophas TJ, Tavenier P, Niemeyer MG. The risk of emergency intestinal bleeding among users of acenocoumarin: a population-based cohort study. Angiology. Feb. 1993;44(2):85-92. X-2, X-4. [pmid: 8434814].
468 Clerc S, Vuilleumier H, Frascarolo P, et al. Is the effect of inguinal field block with 0.5% bupivacaine on postoperative pain after hernia repair enhanced by addition of ketorolac or S(+) ketamine?. Clin J Pain. Jan-Feb. 2005;21(1):101-5. X-2, X-3, X-4. [pmid: 15599137].
469 Cleves MA, Savell VH Jr., Raj S, et al. Maternal use of acetaminophen and nonsteroidal anti-inflammatory drugs (NSAIDs), and muscular ventricular septal defects. Birth Defects Res A Clin Mol Teratol. Mar. 2004;70(3):107-13. X-2, X-4. [pmid: 15039924].
470 Clinard F, Sgro C, Bardou M, et al. Association between concomitant use of several systemic NSAIDs and an excess risk of adverse drug reaction. A case/non-case study from the French Pharmacovigilance system database. Eur J Clin Pharmacol. Jun. 2004;60(4):279-83. X-4. [pmid: 15103437].
471 Clinch D. Why not have definitive trials of gastrointestinal safety for non-steroidal anti-inflammatory drugs? Discussion paper. J R Soc Med. Mar. 1988;81(3):158-60. X-1, X-2, X-3, X-4. [pmid: 3357159].
472 Clinton OP, Priestman TJ, Latief TN, et al. A prospective randomized trial to evaluate different oral dose regimens of medroxyprogesterone acetate in women with advanced breast cancer. Clin Oncol (R Coll Radiol). 1995;7(4):251-6. X-2, X-3. [pmid: 8845325].
473 Clunie M, Crone LA, Klassen L, et al. Psychiatric side effects of indomethacin in parturients. Can J Anaesth. Jun-Jul. 2003;50(6):586-8. X-2, X-4. [pmid: 12826551].
474 Coaccioli S, Allegra A, Di Cato L, et al. Clinical efficacy and tolerance of nabumetone in articular and non-articular rheumatic disorders: personal experience during 12 weeks of treatment. Panminerva Med. Jun. 1998;40(2):110-5. X-2, X-4. [pmid: 9689831].
475 Coffee AL, Sulak PJ, Kuehl TJ. Long-term assessment of symptomatology and satisfaction of an extended oral contraceptive regimen. Contraception. Jun. 2007;75(6):444-9. X-2, X-4. [pmid: 17519150].
476 Cohen AD, Bonneh DY, Reuveni H, et al. Drug exposure and psoriasis vulgaris: case-control and case-crossover studies. Acta Derm Venereol. 2005;85(4):299-303. X-2. [pmid: 16191849].
477 Cohen JS. Dose discrepancies between the Physicians' Desk Reference and the medical literature, and their possible role in the high incidence of dose-related adverse drug events. Arch Intern Med. Apr. 9. 2001;161(7):957-64. X-2, X-3, X-4. [pmid: 11295958].
478 Cohen M, Sapoznikov B, Niv Y. Primary and secondary nonvariceal upper gastrointestinal bleeding. J Clin Gastroenterol. Oct. 2007;41(9):810-3. X-3, X-4. [pmid: 17881925].
479 Cohen S, Cannon GW, Schiff M, et al. Two-year, blinded, randomized, controlled trial of treatment of active rheumatoid arthritis with leflunomide compared with methotrexate. Utilization of Leflunomide in the Treatment of Rheumatoid Arthritis Trial Investigator Group. Arthritis Rheum. Sep. 2001;44(9):1984-92. X-2, X-3, X-4. [pmid: 11592358].
480 Colacurci N, De Placido G, Mollo A, et al. Short-term use of Goserelin depot in the treatment of dysfunctional uterine bleeding. Clin Exp Obstet Gynecol. 1995;22(3):212-9. X-2, X-3, X-4. [pmid: 7554259].
481 Colao A, Abs R, Barcena DG, et al. Pregnancy outcomes following cabergoline treatment: extended results from a 12-year observational study. Clin Endocrinol (Oxf). Jan. 2008;68(1):66-71. X-2. [pmid: 17760883].
482 Colao A, Di Sarno A, Guerra E, et al. Predictors of remission of hyperprolactinaemia after long-term withdrawal of cabergoline therapy. Clin Endocrinol (Oxf). Sep. 2007;67(3):426-33. X-2, X-3. [pmid: 17573902].
483 Colao A, Galderisi M, Di Sarno A, et al. Increased prevalence of tricuspid regurgitation in patients with prolactinomas chronically treated with cabergoline. J Clin Endocrinol Metab. Oct. 2008;93(10):3777-84. X-2. [pmid: 18682513].
484 Colao A, Vitale G, Di Sarno A, et al. Prolactin and prostate hypertrophy: a pilot observational, prospective, case-control study in men with prolactinoma. J Clin Endocrinol Metab. Jun. 2004;89(6):2770-5. X-2, X-3, X-4. [pmid: 15181056].
485 Cole LP, Potts DM, Aranda C, et al. An evaluation of the TCu 380Ag and the Multiload Cu375. Fertil Steril. Feb. 1985;43(2):214-7. X-2, X-4. [pmid: 3881295].
486 Collen MJ, Abdulian JD. Do non-steroidal anti-inflammatory drugs cause duodenal ulcer? Evaluation of basal acid output and ulcer complications. J Gastroenterol Hepatol. Jun. 1996;11(6):520-3. X-2. [pmid: 8792303].
487 Colli E, Tong D, Penhallegon R, et al. Reasons for contraceptive discontinuation in women 20-39 years old in New Zealand. Contraception. Apr. 1999;59(4):227-31. X-4. [pmid: 10457866].
488 Collins AJ, Davies J, Dixon AS. A prospective endoscopic study of the effect of Orudis and Oruvail on the upper gastrointestinal tract, in patients with osteoarthritis. Br J Rheumatol. Apr. 1988;27(2):106-9. X-3, X-4. [pmid: 3365527].
489 Colt HG, Shapiro AP. Drug-induced illness as a cause for admission to a community hospital. J Am Geriatr Soc. Apr. 1989;37(4):323-6. X-2. [pmid: 2921453].
490 Comfort MB, Tse AS, Tsang AC, et al. A study of the comparative efficacy of three common analgesics in the control of pain after third molar surgery under local anaesthesia. Aust Dent J. Dec. 2002;47(4):327-30. X-3, X-4. [pmid: 12587769].
491 Comfort VK, Code WE, Rooney ME, et al. Naproxen premedication reduces postoperative tubal ligation pain. Can J Anaesth. Apr. 1992;39(4):349-52. X-2, X-4. [pmid: 1348663].
492 Confino E, Ismajovich B, Rudick A, et al. Comparison between OM-GA Cu and Copper-T IUCDs. Contraception. Dec. 1983;28(6):521-5. X-2, X-4. [pmid: 6370586].
493 Conforti A, Leone R, Moretti U, et al. Adverse drug reactions related to the use of NSAIDs with a focus on nimesulide: results of spontaneous reporting from a Northern Italian area. Drug Saf. 2001;24(14):1081-90. X-4. [pmid: 11735663].
494 Connell EB. Minimizing the metabolic risks of oral contraceptives through patient counseling and monitoring. J Reprod Med. Sep. 1986;31(9 Suppl):934-8. X-1. [pmid: 3772914].
495 Connelly CS, Panush RS. Should nonsteroidal anti-inflammatory drugs be stopped before elective surgery?. Arch Intern Med. Oct. 1991;151(10):1963-6. X-2. [pmid: 1929684].
496 Conner P, Soderqvist G, Skoog L, et al. Breast cell proliferation in postmenopausal women during HRT evaluated through fine needle aspiration cytology. Breast Cancer Res Treat. Mar. 2003;78(2):159-65. X-2. [pmid: 12725416].
497 Connor PD, Tavernier LA, Thomas SM, et al. Determining risk between Depo-Provera use and increased uterine bleeding in obese and overweight women. J Am Board Fam Pract. Jan-Feb. 2002;15(1):7-10. X-2. [pmid: 11841143].
498 Cooper JW. Adverse drug reaction-related hospitalizations of nursing facility patients: a 4-year study. South Med J. May. 1999;92(5):485-90. X-2. [pmid: 10342894].
499 Cooper KG, Jack SA, Parkin DE, et al. Five-year follow up of women randomised to medical management or transcervical resection of the endometrium for heavy menstrual loss: clinical and quality of life outcomes. BJOG. Dec. 2001;108(12):1222-8. X-2, X-3, X-4. [pmid: 11843383].
500 Cooper KG, Parkin DE, Garratt AM, et al. A randomised comparison of medical and hysteroscopic management in women consulting a gynaecologist for treatment of heavy menstrual loss. Br J Obstet Gynaecol. Dec. 1997;104(12):1360-6. X-2, X-3, X-4. [pmid: 9422013].
501 Cooper KG, Parkin DE, Garratt AM, et al. Two-year follow up of women randomised to medical management or transcervical resection of the endometrium for heavy menstrual loss: clinical and quality of life outcomes. Br J Obstet Gynaecol. Mar. 1999;106(3):258-65. X-2. [pmid: 10426646].
502 Cormican LJ, Farooque S, Altmann DR, et al. Improvements in an oral aspirin challenge protocol for the diagnosis of aspirin hypersensitivity. Clin Exp Allergy. Jun. 2005;35(6):717-22. X-2, X-4. [pmid: 15969660].
503 Cormio M, Citerio G, Spear S, et al. Control of fever by continuous, low-dose diclofenac sodium infusion in acute cerebral damage patients. Intensive Care Med. May. 2000;26(5):552-7. X-2, X-4. [pmid: 10923729].
504 Corre KA, Spielberg TE. Adverse drug reaction processing in the United States and its dependence on physician reporting: zomepirac (Zomax) as a case in point. Ann Emerg Med. Feb. 1988;17(2):145-9. X-1, X-2, X-3, X-4. [pmid: 3257365].
505 Cortes-Prieto J, Juez-Martel P. Incidences of breast cancer throughout long-term hormone replacement therapy. J Steroid Biochem Mol Biol. May. 2007;104(3-5):180-9. X-2, X-3, X-4. [pmid: 17467269].
506 Cote GA, Norvell JP, Rice JP, et al. Use of gastroprotection in patients discharged from hospital on nonsteroidal anti-inflammatory drugs. Am J Ther. Sep-Oct. 2008;15(5):444-9. X-2, X-3, X-4. [pmid: 18806520].
507 Couser RJ, Hoekstra RE, Ferrara TB, et al. Neurodevelopmental follow-up at 36 months' corrected age of preterm infants treated with prophylactic indomethacin. Arch Pediatr Adolesc Med. Jun. 2000;154(6):598-602. X-2, X-4. [pmid: 10850507].
508 Cox ER, Motheral B, Mager D. Verification of a decision analytic model assumption using real-world practice data: implications for the cost effectiveness of cyclo-oxygenase 2 inhibitors (COX-2s). Am J Manag Care. Dec. 2003;9(12):785-94. X-3, X-4. [pmid: 14712755].
509 Cox M, Blacksell S. Clinical performance of the levonorgestrel intra-uterine system in routine use by the UK Family Planning and Reproductive Health Research Network: 12-month report. Br J Fam Plann. Jul. 2000;26(3):143-7. X-2, X-3, X-4. [pmid: 10920290].
510 Cox M, Blacksell SE. Clinical performance of the Nova-T380 IUD in routine use by the UK Family Planning and Reproductive Health Research Network: 12-month report. Br J Fam Plann. Jul. 2000;26(3):148-51. X-2, X-4. [pmid: 10920291].
511 Cozzi R, Attanasio R, Lodrini S, et al. Cabergoline addition to depot somatostatin analogues in resistant acromegalic patients: efficacy and lack of predictive value of prolactin status. Clin Endocrinol (Oxf). Aug. 2004;61(2):209-15. X-2, X-3. [pmid: 15272916].
512 Cramer DW, Harlow BL, Titus-Ernstoff L, et al. Over-the-counter analgesics and risk of ovarian cancer. Lancet. Jan. 10. 1998;351(9096):104-7. X-2, X-3, X-4. [pmid: 9439495].
513 Crandall CJ, Markovic D, Huang MH, et al. Predictors of breast discomfort among women initiating menopausal hormone therapy. Menopause. May-Jun. 2010;17(3):462-70. X-2. [pmid: 20009961].
514 Crawford ML, Waller PC, Wood SM. Severe cystitis associated with tiaprofenic acid. Br J Urol. Apr. 1997;79(4):578-84. X-2, X-4. [pmid: 9126086].
515 Creinin MD, Lisman R, Strickler RC. Screening for factor V Leiden mutation before prescribing combination oral contraceptives. Fertil Steril. Oct. 1999;72(4):646-51. X-1, X-4. [pmid: 10521103].
516 Critchley HO, Wang H, Jones RL, et al. Morphological and functional features of endometrial decidualization following long-term intrauterine levonorgestrel delivery. Hum Reprod. May. 1998;13(5):1218-24. X-2. [pmid: 9647550].
517 Critchley HO, Wang H, Kelly RW, et al. Progestin receptor isoforms and prostaglandin dehydrogenase in the endometrium of women using a levonorgestrel-releasing intrauterine system. Hum Reprod. May. 1998;13(5):1210-7. X-2, X-4. [pmid: 9647549].
518 Cromer BA, Bonny AE, Stager M, et al. Bone mineral density in adolescent females using injectable or oral contraceptives: a 24-month prospective study. Fertil Steril. Dec. 2008;90(6):2060-7. X-2. [pmid: 18222431].
519 Cromer BA, Smith RD, Blair JM, et al. A prospective study of adolescents who choose among levonorgestrel implant (Norplant), medroxyprogesterone acetate (Depo-Provera), or the combined oral contraceptive pill as contraception. Pediatrics. Nov. 1994;94(5):687-94. X-2, X-3, X-4. [pmid: 7936897].
520 Cromer BA, Stager M, Bonny A, et al. Depot medroxyprogesterone acetate, oral contraceptives and bone mineral density in a cohort of adolescent girls. J Adolesc Health. Dec. 2004;35(6):434-41. X-2. [pmid: 15581522].
521 Cropsey KL, Matthews C, Campbel S, et al. Long-term, reversible contraception use among high-risk women treated in a university-based gynecology clinic: comparison between IUD and depo-provera. J Womens Health (Larchmt). Feb. 2010;19(2):349-53. X-2. [pmid: 20109106].
522 Cross RK, Wilson KT, Binion DG. Polypharmacy and Crohn's disease. Aliment Pharmacol Ther. May. 15. 2005;21(10):1211-6. X-2, X-3, X-4. [pmid: 15882241].
523 Cruz-Correa M, Hylind LM, Romans KE, et al. Long-term treatment with sulindac in familial adenomatous polyposis: a prospective cohort study. Gastroenterology. Mar. 2002;122(3):641-5. X-2, X-4. [pmid: 11874996].
524 Cullen DJ, Hawkey GM, Greenwood DC, et al. Peptic ulcer bleeding in the elderly: relative roles of Helicobacter pylori and non-steroidal anti-inflammatory drugs. Gut. Oct. 1997;41(4):459-62. X-2, X-4. [pmid: 9391242].
525 Cullins VE, Blumenthal PD, Remsburg RE, et al. Preliminary experience with Norplant in an inner city population. Contraception. Feb. 1993;47(2):193-203. X-2, X-3, X-4. [pmid: 8449019].
526 Cunnington M, Webb D, Qizilbash N, et al. Risk of ischaemic cardiovascular events from selective cyclooxygenase-2 inhibitors in osteoarthritis. Pharmacoepidemiol Drug Saf. Jun. 2008;17(6):601-8. X-4. [pmid: 18383442].
527 Cuong DT, My Huong NT. Comparative phase III clinical trial of two injectable contraceptive preparations, depot-medroxyprogesterone acetate and Cyclofem, in Vietnamese women. Contraception. Sep. 1996;54(3):169-79. X-2, X-4. [pmid: 8899259].
528 Curhan GC, Willett WC, Rosner B, et al. Frequency of analgesic use and risk of hypertension in younger women. Arch Intern Med. Oct. 28. 2002;162(19):2204-8. X-4. [pmid: 12390063].
529 Currie CJ, Poole CD, Gale EA. The influence of glucose-lowering therapies on cancer risk in type 2 diabetes. Diabetologia. Sep. 2009;52(9):1766-77. X-3. [pmid: 19572116].
530 Curtis JR, Cheng H, Delzell E, et al. Adaptation of Bayesian data mining algorithms to longitudinal claims data: coxib safety as an example. Med Care. Sep. 2008;46(9):969-75. X-4. [pmid: 18725852].
531 Curtis JR, Olivieri J, Allison JJ, et al. A group randomized trial to improve safe use of nonsteroidal anti-inflammatory drugs. Am J Manag Care. Sep. 2005;11(9):537-43. X-2, X-3, X-4. [pmid: 16159043].
532 Cury DB, Moss AC. Ocular manifestations in a community-based cohort of patients with inflammatory bowel disease. Inflamm Bowel Dis. Aug. 2010;16(8):1393-6. X-2, X-4. [pmid: 19998457].
533 Cushman M, Kuller LH, Prentice R, et al. Estrogen plus progestin and risk of venous thrombosis. JAMA. Oct. 6. 2004;292(13):1573-80. X-7. [pmid: 15467059].
534 Czeizel AE, Kodaj I. A changing pattern in the association of oral contraceptives and the different groups of congenital limb deficiencies. Contraception. Jan. 1995;51(1):19-24. X-4. [pmid: 7750279].
535 da Silva Dal Pizzol T, Schuler-Faccini L, Mengue SS, et al. Dipyrone use during pregnancy and adverse perinatal events. Arch Gynecol Obstet. Mar. 2009;279(3):293-7. X-4. [pmid: 18568358].
536 da Silva MO, Costa MM. Reason, myths and fantasies: preliminary data and reflections about the Portuguese experience with LNG-IUS-induced hypomenorrhea. Eur J Contracept Reprod Health Care. Mar. 1999;4(1):21-5. X-2, X-3, X-4. [pmid: 10367192].
537 Dai C, Stafford RS, Alexander GC. National trends in cyclooxygenase-2 inhibitor use since market release: nonselective diffusion of a selectively cost-effective innovation. Arch Intern Med. Jan. 24. 2005;165(2):171-7. X-3, X-4. [pmid: 15668363].
538 Dalmau A, Sabate A, Acosta F, et al. Tranexamic acid reduces red cell transfusion better than epsilon-aminocaproic acid or placebo in liver transplantation. Anesth Analg. Jul. 2000;91(1):29-34. X-2, X-3, X-4. [pmid: 10866882].
539 Dalton SO, Johansen C, Mellemkjaer L, et al. Use of selective serotonin reuptake inhibitors and risk of upper gastrointestinal tract bleeding: a population-based cohort study. Arch Intern Med. Jan. 13. 2003;163(1):59-64. X-4. [pmid: 12523917].
540 Dammann HG, Saleki M, Torz M, et al. Effects of buffered and plain acetylsalicylic acid formulations with and without ascorbic acid on gastric mucosa in healthy subjects. Aliment Pharmacol Ther. Feb. 1. 2004;19(3):367-74. X-2, X-4. [pmid: 14984384].
541 Daniel E, Thorne JE, Newcomb CW, et al. Mycophenolate mofetil for ocular inflammation. Am J Ophthalmol. Mar. 2010;149(3):423-32 e1-2. X-2, X-3, X-4. [pmid: 20042178].
542 Daniels S, Robbins J, West CR, et al. Celecoxib in the treatment of primary dysmenorrhea: results from two randomized, double-blind, active- and placebo-controlled, crossover studies. Clin Ther. Jun. 2009;31(6):1192-208. X-1, X-2, X-3, X-4. [pmid: 19695387].
543 Daperno M, Sostegni R, Canaparo R, et al. Prospective study of the effects of concomitant medications on thiopurine metabolism in inflammatory bowel disease. Aliment Pharmacol Ther. Oct. 15. 2009;30(8):843-53. X-2, X-3, X-4. [pmid: 19650826].
544 Dastjerdi MS, Kazemi F, Najafian A, et al. An open-label pilot study of the combination therapy of metformin and fluoxetine for weight reduction. Int J Obes (Lond). Apr. 2007;31(4):713-7. X-2, X-3, X-4. [pmid: 16969361].
545 Davies NM, Jamali F. COX-2 selective inhibitors cardiac toxicity: getting to the heart of the matter. J Pharm Pharm Sci. Oct. 29. 2004;7(3):332-6. X-1, X-4. [pmid: 15576013].
546 Davis A, Godwin A, Lippman J, et al. Triphasic norgestimate-ethinyl estradiol for treating dysfunctional uterine bleeding. Obstet Gynecol. Dec. 2000;96(6):913-20. X-2, X-3, X-4. [pmid: 11084177].
547 Davis AR, Kroll R, Soltes B, et al. Occurrence of menses or pregnancy after cessation of a continuous oral contraceptive. Fertil Steril. May. 2008;89(5):1059-63. X-2, X-3, X-4. [pmid: 17658522].
548 Davis JM, Hendricks-Munoz KD, Hagberg D, et al. The effects of indomethacin on renal function and intracranial hemorrhage in infants with patent ductus arteriosus. Dev Pharmacol Ther. 1990;14(1):15-9. X-4. [pmid: 2311476].
549 Dawkins TN, Barclay CA, Gardiner RL, et al. Safety of intravenous use of ketorolac in infants following cardiothoracic surgery. Cardiol Young. Feb. 2009;19(1):105-8. X-2, X-4. [pmid: 19134246].
550 de Abajo FJ, Garcia Rodriguez LA. Risk of upper gastrointestinal bleeding and perforation associated with low-dose aspirin as plain and enteric-coated formulations. BMC Clin Pharmacol. 2001;1:1. X-4. [pmid: 11228592].
551 de Abajo FJ, Rodriguez LA, Montero D. Association between selective serotonin reuptake inhibitors and upper gastrointestinal bleeding: population based case-control study. BMJ. Oct. 23. 1999;319(7217):1106-9. X-4. [pmid: 10531103].
552 de Aloysio D, Mauloni M, Roncuzzi A, et al. Effects of an oral contraceptive combination containing 0.150 mg desogestrel plus 0.020 mg ethinyl estradiol on healthy premenopausal women. Arch Gynecol Obstet. 1993;253(1):15-9. X-2, X-4. [pmid: 8328816].
553 de Andrade RP. A multicenter clinical evaluation of a new monophasic combination: Minulet (gestodene and ethinyl estradiol). Int J Fertil. Sep. 1989;34(Suppl):22-30. X-4. [pmid: 2576253].
554 De Bellis A, Colao A, Savoia A, et al. Effect of long-term cabergoline therapy on the immunological pattern and pituitary function of patients with idiopathic hyperprolactinaemia positive for antipituitary antibodies. Clin Endocrinol (Oxf). Aug. 2008;69(2):285-91. X-2, X-3. [pmid: 18221394].
555 de Carvalho MN, Nobre F, Mendes MC, et al. Low-dose transdermal hormone therapy does not interfere with the blood pressure of hypertensive menopausal women: a pilot study. Blood Press Monit. Oct. 2008;13(5):277-83. X-2, X-4. [pmid: 18799953].
556 De Caterina R, Ruigomez A, Rodriguez LA. Long-term use of anti-inflammatory drugs and risk of atrial fibrillation. Arch Intern Med. Sep. 13. 2010;170(16):1450-5. X-2. [pmid: 20837831].
557 De Groote D, Perrier d'Hauterive S, Pintiaux A, et al. Effects of oral contraception with ethinylestradiol and drospirenone on oxidative stress in women 18-35 years old. Contraception. Aug. 2009;80(2):187-93. X-2. [pmid: 19631796].
558 de Jong DJ, Tielen J, Habraken CM, et al. 5-Aminosalicylates and effects on renal function in patients with Crohn's disease. Inflamm Bowel Dis. Nov. 2005;11(11):972-6. X-2, X-4. [pmid: 16239842].
559 de Jong JC, van den Berg PB, Tobi H, et al. Combined use of SSRIs and NSAIDs increases the risk of gastrointestinal adverse effects. Br J Clin Pharmacol. Jun. 2003;55(6):591-5. X-4. [pmid: 12814454].
560 de Jonge ET, Yigit R, Molenberghs G, et al. Predictors of oligoamenorrhea at 1-year follow-up in premenopausal women using a levonorgestrel-releasing intrauterine system. Contraception. Aug. 2007;76(2):91-5. X-2, X-3, X-4. [pmid: 17656176].
561 De Ledinghen V, Heresbach D, Fourdan O, et al. Anti-inflammatory drugs and variceal bleeding: a case-control study. Gut. Feb. 1999;44(2):270-3. X-2. [pmid: 9895389].
562 de Ledinghen V, Mannant PR, Foucher J, et al. Non-steroidal anti-inflammatory drugs and variceal bleeding: a case-control study. J Hepatol. May. 1996;24(5):570-3. X-2, X-4. [pmid: 8773912].
563 De Santis M, Cavaliere AF, Straface G, et al. Failure of the emergency contraceptive levonorgestrel and the risk of adverse effects in pregnancy and on fetal development: an observational cohort study. Fertil Steril. Aug. 2005;84(2):296-9. X-2, X-3, X-4. [pmid: 16084867].
564 De Silva B, Banney L, Uttley W, et al. Pseudoporphyria and nonsteroidal antiinflammatory agents in children with juvenile idiopathic arthritis. Pediatr Dermatol. Nov-Dec. 2000;17(6):480-3. X-2. [pmid: 11123786].
565 De Valle MB, Av Klinteberg V, Alem N, et al. Drug-induced liver injury in a Swedish University hospital out-patient hepatology clinic. Aliment Pharmacol Ther. Oct. 15. 2006;24(8):1187-95. X-2, X-4. [pmid: 17014577].
566 de Vlam K, Lories RJ. Efficacy, effectiveness and safety of etanercept in monotherapy for refractory psoriatic arthritis: a 26-week observational study. Rheumatology (Oxford). Mar. 2006;45(3):321-4. X-2, X-4. [pmid: 16234275].
567 de Vries F, Setakis E, van Staa TP. Concomitant use of ibuprofen and paracetamol and the risk of major clinical safety outcomes. Br J Clin Pharmacol. Sep. 2010;70(3):429-38. X-4. [pmid: 20716244].
568 de Vries NK, Jagroep FK, Jaarsma AS, et al. Continuous indomethacin infusion may be less effective than bolus infusions for ductal closure in very low birth weight infants. Am J Perinatol. Feb. 2005;22(2):71-5. X-2, X-3, X-4. [pmid: 15731984].
569 de Waal WJ, Torn M, de Muinck Keizer-Schrama SM, et al. Long term sequelae of sex steroid treatment in the management of constitutionally tall stature. Arch Dis Child. Oct. 1995;73(4):311-5. X-2. [pmid: 7492194].
570 DeBisschop M. What are the risks of long-term NSAIDs and COX-2 inhibitors?. J Fam Pract. Mar. 2003;52(3):199-200. X-1, X-3, X-4. [pmid: 12620173].
571 Dedier J, Stampfer MJ, Hankinson SE, et al. Nonnarcotic analgesic use and the risk of hypertension in US women. Hypertension. Nov. 2002;40(5):604-8. discussion 1-3. X-4. [pmid: 12411450].
572 Defrance C, Bousquet PJ, Demoly P. Evaluating the negative predictive value of provocation tests with nonsteroidal anti-inflammatory drugs. Allergy. Nov. 2011;66(11):1410-4. X-2. [pmid: 21722141].
573 DeFronzo RA, Okerson T, Viswanathan P, et al. Effects of exenatide versus sitagliptin on postprandial glucose, insulin and glucagon secretion, gastric emptying, and caloric intake: a randomized, cross-over study. Curr Med Res Opin. Oct. 2008;24(10):2943-52. X-2. [pmid: 18786299].
574 Degner F, Sigmund R, Zeidler H. Efficacy and tolerability of meloxicam in an observational, controlled cohort study in patients with rheumatic disease. Clin Ther. Apr. 2000;22(4):400-10. X-4. [pmid: 10823362].
575 Deguchi M, Rapoff AJ, Zdeblick TA. Posterolateral fusion for isthmic spondylolisthesis in adults: analysis of fusion rate and clinical results. J Spinal Disord. Dec. 1998;11(6):459-64. X-2, X-3, X-4. [pmid: 9884288].
576 del Carmen Cravioto M, Alvarado G, Canto-de-Cetina T, et al. A multicenter comparative study on the efficacy, safety, and acceptability of the contraceptive subdermal implants Norplant and Norplant-II. Contraception. Jun. 1997;55(6):359-67. X-2, X-4. [pmid: 9262932].
577 Del Dotto P, Gambaccini G, Caneparo D, et al. Bedtime cabergoline in Parkinson's disease patients with excessive daytime sleepiness induced by dopamine agonists. Neurol Sci. Oct. 2003;24(3):170-1. X-2. [pmid: 14598071].
578 Delgrange E, Daems T, Verhelst J, et al. Characterization of resistance to the prolactin-lowering effects of cabergoline in macroprolactinomas: a study in 122 patients. Eur J Endocrinol. May. 2009;160(5):747-52. X-2, X-3. [pmid: 19223454].
579 Delzell E, Shapiro S. Commentary on the National Kidney Foundation position paper on analgesics and the kidney. Am J Kidney Dis. Nov. 1996;28(5):783-5. X-1. [pmid: 9158222].
580 Demco TA, Sutton H, Demco CJ, et al. Topical diclofenac sodium compared with prednisolone acetate after phacoemulsification-lens implant surgery. Eur J Ophthalmol. Jul-Sep. 1997;7(3):236-40. X-2, X-4. [pmid: 9352276].
581 Depont F, Fourrier A, Merliere Y, et al. The CADEUS study: methods and logistics. Pharmacoepidemiol Drug Saf. May. 2007;16(5):571-80. X-1, X-4, X-7. [pmid: 17121428].
582 Dequeker J, Hawkey C, Kahan A, et al. Improvement in gastrointestinal tolerability of the selective cyclooxygenase (COX)-2 inhibitor, meloxicam, compared with piroxicam: results of the Safety and Efficacy Large-scale Evaluation of COX-inhibiting Therapies (SELECT) trial in osteoarthritis. Br J Rheumatol. Sep. 1998;37(9):946-51. X-4. [pmid: 9783758].
583 Devi DP, Sushma M, Guido S. Drug-induced upper gastrointestinal disorders requiring hospitalization: a five-year study in a South Indian hospital. Pharmacoepidemiol Drug Saf. Dec. 2004;13(12):859-62. X-2. [pmid: 15386699].
584 Devi K, George S, Criton S, et al. Carbamazepine--the commonest cause of toxic epidermal necrolysis and Stevens-Johnson syndrome: a study of 7 years. Indian J Dermatol Venereol Leprol. Sep-Oct. 2005;71(5):325-8. X-2, X-4. [pmid: 16394456].
585 Devin JK, Lakhani VT, Byrd BF 3rd, et al. Prevalence of valvular heart disease in a cohort of patients taking cabergoline for management of hyperprolactinemia. Endocr Pract. Sep. 2008;14(6):672-7. X-2. [pmid: 18996784].
586 Dhawan V, Medcalf P, Stegie F, et al. Retrospective evaluation of cardio-pulmonary fibrotic side effects in symptomatic patients from a group of 234 Parkinson's disease patients treated with cabergoline. J Neural Transm. May. 2005;112(5):661-8. X-2. [pmid: 15785862].
587 Di Carlo C, Tommaselli GA, Gargano V, et al. Transdermal estradiol and oral or vaginal natural progesterone: bleeding patterns. Climacteric. Oct. 2010;13(5):442-6. X-2, X-3, X-4. [pmid: 20575654].
588 Di Fiore F, Lecleire S, Merle V, et al. Changes in characteristics and outcome of acute upper gastrointestinal haemorrhage: a comparison of epidemiology and practices between 1996 and 2000 in a multicentre French study. Eur J Gastroenterol Hepatol. Jun. 2005;17(6):641-7. X-4. [pmid: 15879726].
589 Di Paolo MC, Paoluzi OA, Pica R, et al. Sulphasalazine and 5-aminosalicylic acid in long-term treatment of ulcerative colitis: report on tolerance and side-effects. Dig Liver Dis. Oct. 2001;33(7):563-9. X-2, X-4. [pmid: 11816545].
590 Di Sarno A, Landi ML, Cappabianca P, et al. Resistance to cabergoline as compared with bromocriptine in hyperprolactinemia: prevalence, clinical definition, and therapeutic strategy. J Clin Endocrinol Metab. Nov. 2001;86(11):5256-61. X-2. [pmid: 11701688].
591 Di Silverio F, Sciarra A. Combination therapy of ethinylestradiol and somatostatin analogue reintroduces objective clinical responses and decreases chromogranin a in patients with androgen ablation refractory prostate cancer. J Urol. Nov. 2003;170(5):1812-6. X-2, X-3, X-4. [pmid: 14532782].
592 Diav-Citrin O, Park YH, Veerasuntharam G, et al. The safety of mesalamine in human pregnancy: a prospective controlled cohort study. Gastroenterology. Jan. 1998;114(1):23-8. X-2, X-4. [pmid: 9428214].
593 Diaz J, Bahamondes L, Diaz M, et al. Evaluation of the performance of the copper T380A IUD up to ten years. Is this IUD a reversible but potentially permanent method?. Adv Contracept. Dec. 1992;8(4):275-80. X-2, X-3, X-4. [pmid: 1290329].
594 Diaz J, Bahamondes L, Monteiro I, et al. Acceptability and performance of the levonorgestrel-releasing intrauterine system (Mirena) in Campinas, Brazil. Contraception. Aug. 2000;62(2):59-61. X-2. [pmid: 11102588].
595 Diaz J, Faundes A, Olmos P, et al. Bleeding complaints during the first year of norplant implants use and their impact on removal rate. Contraception. Feb. 1996;53(2):91-5. X-2, X-3, X-4. [pmid: 8838485].
596 Diaz J, Pinto Neto A, Diaz M, et al. Long-term evaluation of the clinical performance of the TCu200B and the TCu380A in Campinas, Brazil. Adv Contracept. Mar. 1992;8(1):67-72. X-3, X-4. [pmid: 1590103].
597 Diaz J, Pinto Neto AM, Bahamondes L, et al. Performance of the copper T 200 in parous adolescents: are copper IUDs suitable for these women?. Contraception. Jul. 1993;48(1):23-8. X-2, X-4. [pmid: 8403902].
598 Diaz RL, Gardeazabal J, Manrique P, et al. Greater allergenicity of topical ketoprofen in contact dermatitis confirmed by use. Contact Dermatitis. May. 2006;54(5):239-43. X-4. [pmid: 16689806].
599 Diaz S, Pavez M, Brandeis A, et al. A longitudinal study on cortisol, prolactin and thyroid hormones in users of Norplant subdermal implants or a copper T device. Contraception. Oct. 1989;40(4):505-17. X-2, X-4. [pmid: 2510969].
600 Diaz S, Pavez M, Miranda P, et al. Long-term follow-up of women treated with Norplant implants. Contraception. Jun. 1987;35(6):551-67. X-2, X-4. [pmid: 3117490].
601 Diaz S, Zepeda A, Maturana X, et al. Fertility regulation in nursing women. IX. Contraceptive performance, duration of lactation, infant growth, and bleeding patterns during use of progesterone vaginal rings, progestin-only pills, Norplant implants, and Copper T 380A intrauterine devices. Contraception. Oct. 1997;56(4):223-32. X-2, X-3, X-4. [pmid: 9408703].
602 Dichtwald S, Weinbroum AA, Sorkine P, et al. Metformin-associated lactic acidosis following acute kidney injury. Efficacious treatment with continuous renal replacement therapy. Diabet Med. Feb. 2012;29(2):245-50. X-2. [pmid: 21977945].
603 Diestelhorst M, Schmidl B, Konen W, et al. Efficacy and tolerance of diclofenac sodium 0.1%, flurbiprofen 0.03%, and indomethacin 1.0% in controlling postoperative inflammation. J Cataract Refract Surg. Suppl 1. 1996;22:788-93. X-2, X-3, X-4. [pmid: 9279673].
604 Dincer D, Duman A, Dikici H, et al. NSAID-related upper gastrointestinal bleeding: are risk factors considered during prophylaxis?. Int J Clin Pract. May. 2006;60(5):546-8. X-2. [pmid: 16700851].
605 Dinesh KU, Subish P, Pranaya M, et al. Pattern of potential drug-drug interactions in diabetic out-patients in a tertiary care teaching hospital in Nepal. Med J Malaysia. Oct. 2007;62(4):294-8. X-2, X-3, X-4. [pmid: 18551932].
606 Ding WY, Lee CK, Choon SE. Cutaneous adverse drug reactions seen in a tertiary hospital in Johor, Malaysia. Int J Dermatol. Jul. 2010;49(7):834-41. X-2. [pmid: 20618508].
607 Dinger J, Assmann A, Mohner S, et al. Risk of venous thromboembolism and the use of dienogest- and drospirenone-containing oral contraceptives: results from a German case-control study. J Fam Plann Reprod Health Care. Jul. 2010;36(3):123-9. X-4. [pmid: 20659364].
608 Dinger J, Bardenheuer K, Minh TD. Levonorgestrel-releasing and copper intrauterine devices and the risk of breast cancer. Contraception. Mar. 2011;83(3):211-7. X-4. [pmid: 21310281].
609 Dinger JC, Bardenheuer K, Assmann A. International Active Surveillance Study of Women Taking Oral Contraceptives (INAS-OC Study). BMC Med Res Methodol. 2009;9:77. X-1. [pmid: 19922634].
610 Dinger JC, Heinemann LA, Kuhl-Habich D. The safety of a drospirenone-containing oral contraceptive: final results from the European Active Surveillance Study on oral contraceptives based on 142,475 women-years of observation. Contraception. May. 2007;75(5):344-54. X-4. [pmid: 17434015].
611 Dinis PB, Gomes A. Sinusitis and asthma: how do they interrelate in sinus surgery?. Am J Rhinol. Nov-Dec. 1997;11(6):421-8. X-2, X-3, X-4. [pmid: 9438054].
612 Diogo LP, Saitovitch D, Biehl M, et al. Is there an association between non-steroidal anti-inflammatory drugs and contrast nephropathy?. Arq Bras Cardiol. Dec. 2010;95(6):726-31. X-2. [pmid: 21109911].
613 Dionne RA, Snyder J, Hargreaves KM. Analgesic efficacy of flurbiprofen in comparison with acetaminophen, acetaminophen plus codeine, and placebo after impacted third molar removal. J Oral Maxillofac Surg. Sep. 1994;52(9):919-24. discussion 25-6. X-3, X-4. [pmid: 8064454].
614 Dizon CD, Allen LM, Ornstein MP. Menstrual and contraceptive issues among young women with developmental delay: a retrospective review of cases at the Hospital for Sick Children, Toronto. J Pediatr Adolesc Gynecol. Jun. 2005;18(3):157-62. X-2, X-3, X-4. [pmid: 15970247].
615 Doan S, Lerouic JF, Robin H, et al. Treatment of ocular cicatricial pemphigoid with sulfasalazine. Ophthalmology. Sep. 2001;108(9):1565-8. X-2, X-3, X-4. [pmid: 11535451].
616 Dominick KL, Bosworth HB, Jeffreys AS, et al. Nonsteroidal antiinflammatory drug use among patients with GI bleeding. Ann Pharmacother. Jul-Aug. 2004;38(7-8):1159-64. X-4, X-7. [pmid: 15187205].
617 Domschke S, Domschke W. Longer relapse-free period after sucralfate than after H2-blocker treatment of duodenal and gastric ulcers. Am J Med. Aug. 8. 7. 1991;91(2A):4S-83S. X-3, X-4. [pmid: 1679297].
618 Donnenfeld ED, Nichamin LD, Hardten DR, et al. Twice-daily, preservative-free ketorolac 0.45% for treatment of inflammation and pain after cataract surgery. Am J Ophthalmol. Mar. 2011;151(3):420-6 e1. X-2, X-3, X-4. [pmid: 21145532].
619 Dore DD, Norman H, Loughlin J, et al. Extended case-control study results on thromboembolic outcomes among transdermal contraceptive users. Contraception. May. 2010;81(5):408-13. X-4. [pmid: 20399947].
620 Doren M, Rubig A, Coelingh Bennink HJ, et al. Impact on uterine bleeding and endometrial thickness: tibolone compared with continuous combined estradiol and norethisterone acetate replacement therapy. Menopause. Winter. 1999;6(4):299-306. X-2, X-4. [pmid: 10614676].
621 Dorjgochoo T, Shu XO, Li HL, et al. Use of oral contraceptives, intrauterine devices and tubal sterilization and cancer risk in a large prospective study, from 1996 to 2006. Int J Cancer. May. 15. 2009;124(10):2442-9. X-4. [pmid: 19170208].
622 Dormuth CR, Maclure M, Carney G, et al. Rosiglitazone and myocardial infarction in patients previously prescribed metformin. PLoS One. 2009;4(6):e6080. X-4. [pmid: 19562036].
623 Dougados M, Gueguen A, Nakache JP, et al. Ankylosing spondylitis: what is the optimum duration of a clinical study? A one year versus a 6 weeks non-steroidal anti-inflammatory drug trial. Rheumatology (Oxford). Mar. 1999;38(3):235-44. X-2, X-4. [pmid: 10325662].
624 Dougherty PL. Menstrual suppression: benefits and risks of continuous combined oral contraceptives. Nurs Womens Health. Jun. 2008;12(3):243-8. X-1. [pmid: 18557855].
625 Dowd JE, Cimaz R, Fink CW. Nonsteroidal antiinflammatory drug-induced gastroduodenal injury in children. Arthritis Rheum. Sep. 1995;38(9):1225-31. X-2. [pmid: 7575716].
626 Doycheva D, Zierhut M, Blumenstock G, et al. Long-term results of therapy with mycophenolate mofetil in chronic non-infectious uveitis. Graefes Arch Clin Exp Ophthalmol. Aug. 2011;249(8):1235-43. X-2, X-3, X-4. [pmid: 21720813].
627 Doyle G, Furey S, Berlin R, et al. Gastrointestinal safety and tolerance of ibuprofen at maximum over-the-counter dose. Aliment Pharmacol Ther. Jul. 1999;13(7):897-906. X-2. [pmid: 10383524].
628 Doyle NM, Gardner MO, Wells L, et al. Outcome of very low birth weight infants exposed to antenatal indomethacin for tocolysis. J Perinatol. May. 2005;25(5):336-40. X-2, X-3, X-4. [pmid: 15861198].
629 Dreiser RL, Benevelli DC. Long term tolerability profile of nimesulide in the treatment of osteoarthritis. Drugs. Suppl 1. 1993;46:270-4. X-2, X-4. [pmid: 7506188].
630 Driver JA, Logroscino G, Lu L, et al. Use of non-steroidal anti-inflammatory drugs and risk of Parkinson's disease: nested case-control study. BMJ. 2011;342:d198. X-4, X-6. [pmid: 21252104].
631 Du MK, Chow LP, Zheng HM, et al. A 10-year follow-up study of contraceptive Norplant implants. Int J Gynaecol Obstet. Mar. 2000;68(3):249-56. X-4. [pmid: 10699196].
632 Du MK, Zheng HM, Chen HC, et al. Study of Norplant implants in Shanghai: three-year experience. Int J Gynaecol Obstet. Dec. 1990;33(4):345-57. X-2, X-3, X-4. [pmid: 1979289].
633 Duan L, Yan D, Zeng W, et al. Effect of progesterone treatment due to threatened abortion in early pregnancy for obstetric and perinatal outcomes. Early Hum Dev. Jan. 2010;86(1):41-3. X-2, X-3, X-4. [pmid: 20079582].
634 Dubos F, Hue V, Grandbastien B, et al. Bacterial skin infections in children hospitalized with varicella: a possible negative impact of non-steroidal anti-inflammatory drugs?. Acta Derm Venereol. 2008;88(1):26-30. X-2, X-4. [pmid: 18176746].
635 Dugoff L, Jones OW 3rd, Allen-Davis J, et al. Assessing the acceptability of Norplant contraceptive in four patient populations. Contraception. Jul. 1995;52(1):45-9. X-2, X-3, X-4. [pmid: 8521714].
636 Duijkers I, Engels L, Klipping C. Length of the menstrual cycle after discontinuation of oral contraceptives. Gynecol Endocrinol. Feb. 2005;20(2):74-9. X-2, X-3, X-4. [pmid: 15823825].
637 Dunn K, Kovacs GT. Do copper containing intrauterine contraceptive devices need to be changed after 2 years?. Clin Reprod Fertil. Dec. 1983;2(4):283-7. X-1, X-2, X-3, X-4. [pmid: 6678604].
638 Dunn N. 10-minute consultation: adverse drug event. BMJ. May. 10. 2003;326(7397):1018. X-1. [pmid: 12742925].
639 Dunn N, Thorogood M, Faragher B, et al. Oral contraceptives and myocardial infarction: results of the MICA case-control study. BMJ. Jun. 12. 1999;318(7198):1579-83. X-3, X-4. [pmid: 10364115].
640 Dunson TR, McLaurin VL, Grubb GS, et al. A multicenter clinical trial of a progestin-only oral contraceptive in lactating women. Contraception. Jan. 1993;47(1):23-35. X-4. [pmid: 8435999].
641 Duong HV, Westfield KC, Chalkley TH. Ketorolac tromethamine LS 0.4% versus nepafenac 0.1% in patients having cataract surgery. Prospective randomized double-masked clinical trial. J Cataract Refract Surg. Nov. 2007;33(11):1925-9. X-2, X-3, X-4. [pmid: 17964399].
642 Durrieu G, Olivier P, Montastruc JL. COX-2 inhibitors and arterial hypertension: an analysis of spontaneous case reports in the Pharmacovigilance database. Eur J Clin Pharmacol. Sep. 2005;61(8):611-4. X-2, X-3, X-4. [pmid: 16133552].
643 Dushay J, Gao C, Gopalakrishnan GS, et al. Short-term exenatide treatment leads to significant weight loss in a subset of obese women without diabetes. Diabetes Care. Jan. 2012;35(1):4-11. X-2. [pmid: 22040840].
644 Dusterberg B, Brill K. Clinical experience with a low-dose oral contraceptive containing gestodene. Adv Contracept. Dec. 1990;6(Suppl):37-49. discussion 50. X-11. [pmid: 2291446].
645 Dutka J, Dutka L, Janiszewski M, et al. Cost analysis and sociomedical aspects of the conservative and surgical treatment of hip osteoarthritis. Ortop Traumatol Rehabil. Nov-Dec. 2008;10(6):537-46. X-2, X-3, X-4. [pmid: 19153542].
646 Earl HM, Rubens RD, Knight RK, et al. Norethisterone acetate in the treatment of advanced breast cancer. Clin Oncol. Jun. 1984;10(2):103-9. X-2, X-3, X-4. [pmid: 6734001].
647 East-Innis AD, Thompson DS. Cutaneous drug reactions in patients admitted to the dermatology unit at the University Hospital of the West Indies, Kingston, Jamaica. West Indian Med J. Jun. 2009;58(3):227-30. X-4. [pmid: 20043529].
648 Ebeling K, Ray R, Nischan P, et al. Combined oral contraceptives containing chlormadinone acetate and breast cancer: results of a case-control study. Br J Cancer. May. 1991;63(5):804-8. X-4. [pmid: 1710136].
649 Eberlein B, Eicke C, Reinhardt HW, et al. Adjuvant treatment of atopic eczema: assessment of an emollient containing N-palmitoylethanolamine (ATOPA study). J Eur Acad Dermatol Venereol. Jan. 2008;22(1):73-82. X-3, X-4. [pmid: 18181976].
650 Ebert MP, Schafer C, Chen J, et al. Protective role of heat shock protein 27 in gastric mucosal injury. J Pathol. Oct. 2005;207(2):177-84. X-3, X-4. [pmid: 16041694].
651 Edwards MJ, Kollenberg SJ, Brandt ML, et al. Surgery for peptic ulcer disease in children in the post-histamine2-blocker era. J Pediatr Surg. May. 2005;40(5):850-4. X-2, X-4. [pmid: 15937829].
652 Egarter C, Putz M, Strohmer H, et al. Ovarian function during low-dose oral contraceptive use. Contraception. Jun. 1995;51(6):329-33. X-2, X-4. [pmid: 7554971].
653 Egberg N, van Beek A, Gunnervik C, et al. Effects on the hemostatic system and liver function in relation to Implanon and Norplant. A prospective randomized clinical trial. Contraception. Aug. 1998;58(2):93-8. X-2, X-4. [pmid: 9773263].
654 Egberts AC, Meyboom RH, van Puijenbroek EP. Use of measures of disproportionality in pharmacovigilance: three Dutch examples. Drug Saf. 2002;25(6):453-8. X-1. [pmid: 12071783].
655 Eilertsen AL, Sandvik L, Mowinckel MC, et al. Differential effects of conventional and low dose oral hormone therapy (HT), tibolone, and raloxifene on coagulation and fibrinolysis. Thromb Res. 2007;120(3):371-9. X-2, X-3, X-4. [pmid: 17156824].
656 Ekenel M, Avsar E, Imeryuz N, et al. Effects of selective COX-2 inhibitors on the gastric permeability of sucrose: a controlled study with placebo and ibuprofen. Eur J Gastroenterol Hepatol. Apr. 2003;15(4):403-6. X-2, X-4. [pmid: 12655261].
657 Ekici F, Atasay B, Gunlemez A, et al. Management of patent ductus arteriosus in preterm infants. Anadolu Kardiyol Derg. Mar. 2006;6(1):28-33. X-2, X-3, X-4. [pmid: 16524797].
658 Elder MG, Lawson JP, Elstein M, et al. The efficacy and acceptability of a low-dose levonorgestrel intravaginal ring for contraception in a UK cohort. Contraception. Feb. 1991;43(2):129-37. X-2, X-3, X-4. [pmid: 1904020].
659 Elhakim M, Siam A, Rashed I, et al. Topical tenoxicam from pharyngeal pack reduces postoperative sore throat. Acta Anaesthesiol Scand. Jul. 2000;44(6):733-6. X-2, X-3, X-4. [pmid: 10903018].
660 Eliakim R, Karmeli F, Rachmilewitz D. Ketotifen--old drug, new indication: reduction of gastric mucosal injury. Scand J Gastroenterol. Mar. 1993;28(3):202-4. X-2, X-3, X-4. [pmid: 8446844].
661 Eliakim R, Ophir M, Rachmilewitz D. Duodenal mucosal injury with nonsteroidal antiinflammatory drugs. J Clin Gastroenterol. Aug. 1987;9(4):395-9. X-2. [pmid: 3498747].
662 Elkik F, Basdevant A, Jackanicz TM, et al. Contraception in hypertensive women using a vaginal ring delivering estradiol and levonorgestrel. J Clin Endocrinol Metab. Jul. 1986;63(1):29-35. X-2, X-3, X-4. [pmid: 3086360].
663 Elkind-Hirsch K, Marrioneaux O, Bhushan M, et al. Comparison of single and combined treatment with exenatide and metformin on menstrual cyclicity in overweight women with polycystic ovary syndrome. Journal of Clinical Endocrinology and Metabolism. 2008;93(7):2670-8. X-2, X-3, X-4. [pmid: 18460557].
664 Elovainio M, Teperi J, Aalto AM, et al. Depressive symptoms as predictors of discontinuation of treatment of menorrhagia by levonorgestrel-releasing intrauterine system. Int J Behav Med. 2007;14(2):70-5. X-2. [pmid: 17926434].
665 el-Reshaid K, Kapoor M, Johny KV, et al. Acute renal failure in Kuwait--a prospective study. J Trop Med Hyg. Oct. 1993;96(5):323-9. X-2, X-3, X-4. [pmid: 8411309].
666 Elseviers MM, D'Haens G, Lerebours E, et al. Renal impairment in patients with inflammatory bowel disease: association with aminosalicylate therapy?. Clin Nephrol. Feb. 2004;61(2):83-9. X-2, X-4. [pmid: 14989626].
667 Elwatidy S, Jamjoom Z, Elgamal E, et al. Efficacy and safety of prophylactic large dose of tranexamic acid in spine surgery: a prospective, randomized, double-blind, placebo-controlled study. Spine (Phila Pa 1976). Nov. 15. 2008;33(24):2577-80. X-2. [pmid: 19011538].
668 Endo H, Hosono K, Inamori M, et al. Characteristics of small bowel injury in symptomatic chronic low-dose aspirin users: the experience of two medical centers in capsule endoscopy. J Gastroenterol. 2009;44(6):544-9. X-2. [pmid: 19373431].
669 Endo N, Kato S, Haruyama K, et al. Efficacy of bromfenac sodium ophthalmic solution in preventing cystoid macular oedema after cataract surgery in patients with diabetes. Acta Ophthalmol. Dec. 2010;88(8):896-900. X-2, X-3, X-4. [pmid: 19725815].
670 Endrikat J, Dusterberg B, Ruebig A, et al. Comparison of efficacy, cycle control, and tolerability of two low-dose oral contraceptives in a multicenter clinical study. Contraception. Nov. 1999;60(5):269-74. X-2, X-4. [pmid: 10717778].
671 Endrikat J, Jaques MA, Mayerhofer M, et al. A twelve-month comparative clinical investigation of two low-dose oral contraceptives containing 20 micrograms ethinylestradiol/75 micrograms gestodene and 20 micrograms ethinylestradiol/150 micrograms desogestrel, with respect to efficacy, cycle control and tolerance. Contraception. Oct. 1995;52(4):229-35. X-2. [pmid: 8605781].
672 Endrikat J, Klipping C, Cronin M, et al. An open label, comparative study of the effects of a dose-reduced oral contraceptive containing 20 microg ethinyl estradiol and 100 microg levonorgestrel on hemostatic, lipids, and carbohydrate metabolism variables. Contraception. Mar. 2002;65(3):215-21. X-2, X-4. [pmid: 11929643].
673 Endrikat J, Mih E, Dusterberg B, et al. A 3-year double-blind, randomized, controlled study on the influence of two oral contraceptives containing either 20 microg or 30 microg ethinylestradiol in combination with levonorgestrel on bone mineral density. Contraception. Mar. 2004;69(3):179-87. X-2, X-4. [pmid: 14969664].
674 Endrikat J, Noah M, Gerlinger C, et al. Impact of oral contraceptive use on APC-resistance: a prospective, randomized clinical trial with three low-dose preparations. Contraception. Oct. 2001;64(4):217-22. X-2, X-4. [pmid: 11747870].
675 Endrikat J, Shapiro H, Lukkari-Lax E, et al. A Canadian, multicentre study comparing the efficacy of a levonorgestrel-releasing intrauterine system to an oral contraceptive in women with idiopathic menorrhagia. J Obstet Gynaecol Can. Apr. 2009;31(4):340-7. X-2, X-3. [pmid: 19497153].
676 Engeland A, Skurtveit S, Morland J. Risk of road traffic accidents associated with the prescription of drugs: a registry-based cohort study. Ann Epidemiol. Aug. 2007;17(8):597-602. X-4. [pmid: 17574863].
677 Engoren M, Hadaway J, Schwann TA, et al. Ketorolac improves graft patency after coronary artery bypass grafting: a propensity-matched analysis. Ann Thorac Surg. Aug. 2011;92(2):603-9. X-2, X-4. [pmid: 21801915].
678 Engoren MC, Habib RH, Zacharias A, et al. Postoperative analgesia with ketorolac is associated with decreased mortality after isolated coronary artery bypass graft surgery in patients already receiving aspirin: a propensity-matched study. J Cardiothorac Vasc Anesth. Dec. 2007;21(6):820-6. X-2, X-4. [pmid: 18068059].
679 Erbagci Z. Multiple NSAID intolerance in chronic idiopathic urticaria is correlated with delayed, pronounced and prolonged autoreactivity. J Dermatol. May. 2004;31(5):376-82. X-2. [pmid: 15187304].
680 Ericson A, Kallen BA. Nonsteroidal anti-inflammatory drugs in early pregnancy. Reprod Toxicol. Jul-Aug. 2001;15(4):371-5. X-4. [pmid: 11489592].
681 Ernst E, Schmolzl C, Matrai A, et al. Hemorheological effects of oral contraceptives. Contraception. Nov. 1989;40(5):571-80. X-2, X-4. [pmid: 2692965].
682 Ernst ME, Iyer SS, Doucette WR. Drug-related problems and quality of life in arthritis and low back pain sufferers. Value Health. Jan-Feb. 2003;6(1):51-8. X-2, X-3, X-4. [pmid: 12535238].
683 Eroglu K, Akkuzu G, Vural G, et al. Comparison of efficacy and complications of IUD insertion in immediate postplacental/early postpartum period with interval period: 1 year follow-up. Contraception. Nov. 2006;74(5):376-81. X-2, X-4. [pmid: 17046378].
684 Esparza F, Cobian C, Jimenez JF, et al. Topical ketoprofen TDS patch versus diclofenac gel: efficacy and tolerability in benign sport related soft-tissue injuries. Br J Sports Med. Mar. 2007;41(3):134-9. X-2, X-3, X-4. [pmid: 17138642].
685 Espey E, Steinhart J, Ogburn T, et al. Depo-provera associated with weight gain in Navajo women. Contraception. Aug. 2000;62(2):55-8. X-2. [pmid: 11102587].
686 Espinoza LR, Jara LJ, Martinez-Osuna P, et al. Refractory nephrotic syndrome in lupus nephritis: favorable response to indomethacin therapy. Lupus. Feb. 1993;2(1):9-14. X-2, X-4. [pmid: 8485564].
687 Essving P, Axelsson K, Kjellberg J, et al. Reduced hospital stay, morphine consumption, and pain intensity with local infiltration analgesia after unicompartmental knee arthroplasty. Acta Orthop. Apr. 2009;80(2):213-9. X-2, X-3, X-4. [pmid: 19404806].
688 Etienney I, Beaugerie L, Viboud C, et al. Non-steroidal anti-inflammatory drugs as a risk factor for acute diarrhoea: a case crossover study. Gut. Feb. 2003;52(2):260-3. X-2. [pmid: 12524410].
689 Etminan M, Delaney JA, Bressler B, et al. Oral contraceptives and the risk of gallbladder disease: a comparative safety study. CMAJ. May. 17. 2011;183(8):899-904. X-4. [pmid: 21502354].
690 Etminan M, Levesque L, Fitzgerald JM, et al. Risk of upper gastrointestinal bleeding with oral bisphosphonates and non steroidal anti-inflammatory drugs: a case-control study. Aliment Pharmacol Ther. Jun. 1. 2009;29(11):1188-92. X-4. [pmid: 19298582].
691 Etminan M, Suissa S. NSAID use and the risk of Parkinson's disease. Curr Drug Saf. Aug. 2006;1(3):223-5. X-4. [pmid: 18690932].
692 Evans A, Perez I, Yu G, et al. Should stroke subtype influence anticoagulation decisions to prevent recurrence in stroke patients with atrial fibrillation?. Stroke. Dec. 1. 2001;32(12):2828-32. X-2, X-3, X-4. [pmid: 11739981].
693 Evans JM, Macgregor AM, Murray FE, et al. No association between non-steroidal anti-inflammatory drugs and acute appendicitis in a case-control study. Br J Surg. Mar. 1997;84(3):372-4. X-2, X-4. [pmid: 9117311].
694 Evans JM, McGregor E, McMahon AD, et al. Non-steroidal anti-inflammatory drugs and hospitalization for acute renal failure. QJM. Aug. 1995;88(8):551-7. X-4. [pmid: 7648241].
695 Evans JM, McMahon AD, McGilchrist MM, et al. Topical non-steroidal anti-inflammatory drugs and admission to hospital for upper gastrointestinal bleeding and perforation: a record linkage case-control study. BMJ. Jul. 1. 1995;311(6996):22-6. X-4. [pmid: 7613317].
696 Evans JM, McMahon AD, Murray FE, et al. Non-steroidal anti-inflammatory drugs are associated with emergency admission to hospital for colitis due to inflammatory bowel disease. Gut. May. 1997;40(5):619-22. X-4. [pmid: 9203940].
697 Evers S, Husstedt IW. Alternatives in drug treatment of chronic paroxysmal hemicrania. Headache. Jul-Aug. 1996;36(7):429-32. X-2, X-3, X-4. [pmid: 8783475].
698 Eyster ME, Asaad SM, Gold BD, et al. Upper gastrointestinal bleeding in haemophiliacs: incidence and relation to use of non-steroidal anti-inflammatory drugs. Haemophilia. May. 2007;13(3):279-86. X-4. [pmid: 17498077].
699 Fagnani F, Bouvenot G, Valat JP, et al. Medico-economic analysis of diacerein with or without standard therapy in the treatment of osteoarthritis. Pharmacoeconomics. Jan. 1998;13(1 Pt 2):135-46. X-2, X-3, X-4. [pmid: 10176148].
700 Fakeye O, Balogh S. Effect of Norplant contraceptive use on hemoglobin, packed cell volume and menstrual bleeding patterns. Contraception. Mar. 1989;39(3):265-74. X-2, X-4. [pmid: 2496950].
701 Famodu AA. Serial changes in plasma fibrinogen concentration and fibrinolytic activity in African women on oral contraceptive pills. Afr J Reprod Health. Sep. 1997;1(2):90-5. X-2. [pmid: 10214418].
702 Fan M, Sujuan G. Menstrual bleeding patterns in Chinese women using the Norplant subdermal implant. Hum Reprod. Oct. Suppl 2. 1996;11:14-9. X-2, X-4. [pmid: 8982740].
703 Fanos V, Benini D, Verlato G, et al. Efficacy and renal tolerability of ibuprofen vs. indomethacin in preterm infants with patent ductus arteriosus. Fundam Clin Pharmacol. Apr. 2005;19(2):187-93. X-2, X-4. [pmid: 15810899].
704 Farley TM, Meirik O, Chang CL, et al. Combined oral contraceptives, smoking, and cardiovascular risk. J Epidemiol Community Health. Dec. 1998;52(12):775-85. X-4. [pmid: 10396518].
705 Farmer RD, Lawrenson R. Utilization patterns of oral contraceptives in UK general practice. Contraception. Apr. 1996;53(4):211-5. X-2, X-3, X-4. [pmid: 8706438].
706 Farmer RD, Lawrenson RA, Thompson CR, et al. Population-based study of risk of venous thromboembolism associated with various oral contraceptives. Lancet. Jan. 11. 1997;349(9045):83-8. X-4. [pmid: 8996419].
707 Farmer RD, Lawrenson RA, Todd JC, et al. A comparison of the risks of venous thromboembolic disease in association with different combined oral contraceptives. Br J Clin Pharmacol. Jun. 2000;49(6):580-90. X-4. [pmid: 10848722].
708 Farr G, Rivera R. Interactions between intrauterine contraceptive device use and breast-feeding status at time of intrauterine contraceptive device insertion: analysis of TCu-380A acceptors in developing countries. Am J Obstet Gynecol. Jul. 1992;167(1):144-51. X-4. [pmid: 1442918].
709 Farr G, Rivera R, Amatya R. Non-physician insertion of IUDs: clinical outcomes among TCu380A insertions in three developing-country clinics. Adv Contracept. Mar. 1998;14(1):45-57. X-2, X-3, X-4. [pmid: 9587008].
710 Faundes D, Bahamondes L, Faundes A, et al. No relationship between the IUD position evaluated by ultrasound and complaints of bleeding and pain. Contraception. Jul. 1997;56(1):43-7. X-2, X-3, X-4. [pmid: 9306030].
711 Fauno P, Petersen KD, Husted SE. Increased blood loss after preoperative NSAID. Retrospective study of 186 hip arthroplasties. Acta Orthop Scand. Oct. 1993;64(5):522-4. X-2, X-4. [pmid: 8237316].
712 Fayaz MK, Abel RJ, Pugh SC, et al. Opioid-sparing effects of diclofenac and paracetamol lead to improved outcomes after cardiac surgery. J Cardiothorac Vasc Anesth. Dec. 2004;18(6):742-7. X-2, X-4. [pmid: 15650984].
713 Feenstra J, Heerdink ER, Grobbee DE, et al. Association of nonsteroidal anti-inflammatory drugs with first occurrence of heart failure and with relapsing heart failure: the Rotterdam Study. Arch Intern Med. Feb. 11. 2002;162(3):265-70. X-4, X-7. [pmid: 11822918].
714 Felder JB, Korelitz BI, Rajapakse R, et al. Effects of nonsteroidal antiinflammatory drugs on inflammatory bowel disease: a case-control study. Am J Gastroenterol. Aug. 2000;95(8):1949-54. X-2. [pmid: 10950041].
715 Felfernig M, Salat A, Kimberger O, et al. Preemptive analgesia by lornoxicam--an NSAID--significantly inhibits perioperative platelet aggregation. Eur J Anaesthesiol. Sep. 2008;25(9):726-31. X-2, X-3, X-4. [pmid: 18471341].
716 Fenner H. Evaluation of the efficacy and safety of NSAIDs. A new methodological approach. Scand J Rheumatol Suppl. 1989;80:32-9. X-1. [pmid: 2688078].
717 Fenske WK, Pournaras DJ, Aasheim ET, et al. Can a protocol for glycaemic control improve type 2 diabetes outcomes after gastric bypass?. Obes Surg. Jan. 2012;22(1):90-6. X-2. [pmid: 22052198].
718 Ferenczy A, Gelfand MM. Endometrial histology and bleeding patterns in post-menopausal women taking sequential, combined estradiol and dydrogesterone. Maturitas. Apr. 1997;26(3):219-26. X-2, X-3, X-4. [pmid: 9147354].
719 Ferguson MA, Mackay SM, Ramchandani SR, et al. Cryptogenic emboli in patients with patent foramen ovale or atrial septal defect associated with the use of nonsteroidal anti-inflammatory drugs. Cardiology. 2009;113(1):20-4. X-2. [pmid: 18931493].
720 Ferraro-Peyret C, Coury F, Tebib JG, et al. Infliximab therapy in rheumatoid arthritis and ankylosing spondylitis-induced specific antinuclear and antiphospholipid autoantibodies without autoimmune clinical manifestations: a two-year prospective study. Arthritis Res Ther. 2004;6(6):R535-43. X-2, X-3, X-4. [pmid: 15535831].
721 Ferrero S, Camerini G, Ragni N, et al. Norethisterone acetate in the treatment of colorectal endometriosis: a pilot study. Hum Reprod. Jan. 2010;25(1):94-100. X-2, X-3, X-4. [pmid: 19820247].
722 Ferrero S, Camerini G, Seracchioli R, et al. Letrozole combined with norethisterone acetate compared with norethisterone acetate alone in the treatment of pain symptoms caused by endometriosis. Hum Reprod. Dec. 2009;24(12):3033-41. X-2, X-4. [pmid: 19726448].
723 Fielder JH. The Vioxx debacle. IEEE Eng Med Biol Mag. Mar-Apr. 2005;24(2):106-9. X-1. [pmid: 15825852].
724 Figueras A, Capella D, Castel JM, et al. Spontaneous reporting of adverse drug reactions to non-steroidal anti-inflammatory drugs. A report from the Spanish System of Pharmacovigilance, including an early analysis of topical and enteric-coated formulations. Eur J Clin Pharmacol. 1994;47(4):297-303. X-4. [pmid: 7875178].
725 Figus M, Fogagnolo P, Lazzeri S, et al. Treatment of allergic conjunctivitis: results of a 1-month, single-masked randomized study. Eur J Ophthalmol. Sep-Oct. 2010;20(5):811-8. X-2, X-3, X-4. [pmid: 20383847].
726 Fiore LD, Ezekowitz MD, Brophy MT, et al. Department of Veterans Affairs Cooperative Studies Program Clinical Trial comparing combined warfarin and aspirin with aspirin alone in survivors of acute myocardial infarction: primary results of the CHAMP study. Circulation. Feb. 5. 2002;105(5):557-63. X-3, X-4. [pmid: 11827919].
727 Fischer LM, Schlienger RG, Matter CM, et al. Current use of nonsteroidal antiinflammatory drugs and the risk of acute myocardial infarction. Pharmacotherapy. Apr. 2005;25(4):503-10. X-4, X-7. [pmid: 15977911].
728 Fisman EZ, Tenenbaum A, Benderly M, et al. Antihyperglycemic treatment in diabetics with coronary disease: increased metformin-associated mortality over a 5-year follow-up. Cardiology. 1999;91(3):195-202. X-3. [pmid: 10516414].
729 Fitzgerald GA. Coxibs and cardiovascular disease. N Engl J Med. Oct. 21. 2004;351(17):1709-11. X-1. [pmid: 15470192].
730 Flach AJ, Dolan BJ, Donahue ME, et al. Comparative effects of ketorolac 0.5% or diclofenac 0.1% ophthalmic solutions on inflammation after cataract surgery. Ophthalmology. Sep. 1998;105(9):1775-9. X-2, X-4. [pmid: 9754191].
731 Flato B, Vinje O, Forre O. Toxicity of antirheumatic and anti-inflammatory drugs in children. Clin Rheumatol. 1998;17(6):505-10. X-2. [pmid: 9890680].
732 Fleischmann RM. Clinical efficacy and safety of nabumetone in rheumatoid arthritis and osteoarthritis. J Rheumatol Suppl. Nov. 1992;36:32-40. X-4. [pmid: 1474533].
733 Fleming R, Hopkinson ZE, Wallace AM, et al. Ovarian function and metabolic factors in women with oligomenorrhea treated with metformin in a randomized double blind placebo-controlled trial. J Clin Endocrinol Metab. Feb. 2002;87(2):569-74. X-2, X-3. [pmid: 11836287].
734 Fletcher AP. Profile of a large-scale cohort study. Drugs. Suppl 5. 1990;40:43-7. X-11. [pmid: 2081492].
735 Flick ED, Chan KA, Bracci PM, et al. Use of nonsteroidal antiinflammatory drugs and non-Hodgkin lymphoma: a population-based case-control study. Am J Epidemiol. Sep. 1. 2006;164(5):497-504. X-4. [pmid: 16840523].
736 Flint SR, O'Sullivan C, Arthur N. An update of adverse drug reactions of relevance to general dental practice. J Ir Dent Assoc. 2000;46(2):67-70. X-1. [pmid: 11326529].
737 Florentinus SR, Heerdink ER, de Boer A, et al. The trade-off between cardiovascular and gastrointestinal effects of rofecoxib. Pharmacoepidemiol Drug Saf. Jul. 2005;14(7):437-41. X-4. [pmid: 15937867].
738 Foeldvari I, Szer IS, Zemel LS, et al. A prospective study comparing celecoxib with naproxen in children with juvenile rheumatoid arthritis. J Rheumatol. Jan. 2009;36(1):174-82. X-2. [pmid: 19012356].
739 Fontana RJ, Sanyal AJ, Mehta S, et al. Portal hypertensive gastropathy in chronic hepatitis C patients with bridging fibrosis and compensated cirrhosis: results from the HALT-C trial. Am J Gastroenterol. May. 2006;101(5):983-92. X-2, X-3, X-4. [pmid: 16573786].
740 Fontbonne A, Andre P, Eschwege E. BIGPRO (biguanides and the prevention of the risk of obesity): study design. A randomized trial of metformin versus placebo in the correction of the metabolic abnormalities associated with insulin resistance. Diabete Metab. May. 1991;17(1 Pt 2):249-54. X-1. [pmid: 1936485].
741 Ford AC, Forman D, Bailey AG, et al. Who consults with dyspepsia? Results from a longitudinal 10-yr follow-up study. Am J Gastroenterol. May. 2007;102(5):957-65. X-4. [pmid: 17313501].
742 Fored CM, Ejerblad E, Lindblad P, et al. Acetaminophen, aspirin, and chronic renal failure. N Engl J Med. Dec. 20. 2001;345(25):1801-8. X-2, X-4. [pmid: 11752356].
743 Forget P, Vandenhende J, Berliere M, et al. Do intraoperative analgesics influence breast cancer recurrence after mastectomy? A retrospective analysis. Anesth Analg. Jun. 1. 2010;110(6):1630-5. X-2, X-4. [pmid: 20435950].
744 Foroutan M, Loloei B, Irvani S, et al. Accuracy of rapid urease test in diagnosing Helicobacter pylori infection in patients using NSAIDs. Saudi J Gastroenterol. Apr-Jun. 2010;16(2):110-2. X-2, X-4. [pmid: 20339181].
745 Forrest JB, Camu F, Greer IA, et al. Ketorolac, diclofenac, and ketoprofen are equally safe for pain relief after major surgery. Br J Anaesth. Feb. 2002;88(2):227-33. X-4. [pmid: 11883386].
746 Fortuny J, Johnson CC, Bohlke K, et al. Use of anti-inflammatory drugs and lower esophageal sphincter-relaxing drugs and risk of esophageal and gastric cancers. Clin Gastroenterol Hepatol. Oct. 2007;5(10):1154-9 e3. X-2, X-4. [pmid: 17644046].
747 Fortuny J, Kogevinas M, Garcia-Closas M, et al. Use of analgesics and nonsteroidal anti-inflammatory drugs, genetic predisposition, and bladder cancer risk in Spain. Cancer Epidemiol Biomarkers Prev. Sep. 2006;15(9):1696-702. X-2, X-4. [pmid: 16985032].
748 Fosbol EL, Folke F, Jacobsen S, et al. Cause-specific cardiovascular risk associated with nonsteroidal antiinflammatory drugs among healthy individuals. Circ Cardiovasc Qual Outcomes. Jul. 2010;3(4):395-405. X-4. [pmid: 20530789].
749 Fosbol EL, Gislason GH, Jacobsen S, et al. Risk of myocardial infarction and death associated with the use of nonsteroidal anti-inflammatory drugs (NSAIDs) among healthy individuals: a nationwide cohort study. Clin Pharmacol Ther. Feb. 2009;85(2):190-7. X-4. [pmid: 18987620].
750 Foster M, Kendall R, Todd M. COX-2 inhibitor safety in the workers' compensation market. Lippincotts Case Manag. Jul-Aug. 2005;10(4):217-20. X-1. [pmid: 16056119].
751 Fournier A, Berrino F, Clavel-Chapelon F. Unequal risks for breast cancer associated with different hormone replacement therapies: results from the E3N cohort study. Breast Cancer Res Treat. Jan. 2008;107(1):103-11. X-4. [pmid: 17333341].
752 Fourrier-Reglat A, Cuong HM, Lassalle R, et al. Concordance between prescriber- and patient-reported previous medical history and NSAID indication in the CADEUS cohort. Pharmacoepidemiol Drug Saf. May. 2010;19(5):474-81. X-4. [pmid: 20437457].
753 Foutch PG. Diverticular bleeding: are nonsteroidal anti-inflammatory drugs risk factors for hemorrhage and can colonoscopy predict outcome for patients?. Am J Gastroenterol. Oct. 1995;90(10):1779-84. X-2. [pmid: 7572894].
754 Fraenkel L, Bogardus ST Jr., Concato J, et al. Treatment options in knee osteoarthritis: the patient's perspective. Arch Intern Med. Jun. 28. 2004;164(12):1299-304. X-2, X-3, X-4. [pmid: 15226163].
755 Fraj J, Valero A, Vives R, et al. Safety of triflusal (antiplatelet drug) in patients with aspirin-exacerbated respiratory diseases. Allergy. Jan. 2008;63(1):112-5. X-2, X-3, X-4. [pmid: 18053020].
756 Franck H, Rau R, Herborn G. Thrombocytopenia in patients with rheumatoid arthritis on long-term treatment with low dose methotrexate. Clin Rheumatol. May. 1996;15(3):266-70. X-2, X-4. [pmid: 8793258].
757 Francois P, Desrumaux A, Cans C, et al. Prevalence and risk factors of suppurative complications in children with pneumonia. Acta Paediatr. Jun. 2010;99(6):861-6. X-2. [pmid: 20178517].
758 Frankel A, Sohn A, Patel RV, et al. Bilateral comparison study of pimecrolimus cream 1% and a ceramide-hyaluronic acid emollient foam in the treatment of patients with atopic dermatitis. J Drugs Dermatol. Jun. 2011;10(6):666-72. X-2, X-3, X-4. [pmid: 21637908].
759 Fraser D, Whitehead M, Schenkel L, et al. Does low-dose, transdermal, norethisterone acetate reliably cause endometrial transformation in postmenopausal oestrogen-users?. Maturitas. Jan. 1993;16(1):23-30. X-2, X-4. [pmid: 8429801].
760 Fraser IS, McCarron G. Randomized trial of 2 hormonal and 2 prostaglandin-inhibiting agents in women with a complaint of menorrhagia. Aust N Z J Obstet Gynaecol. Feb. 1991;31(1):66-70. X-2, X-3, X-4. [pmid: 1872778].
761 Fraser IS, McCarron G, Markham R, et al. Long-term treatment of menorrhagia with mefenamic acid. Obstet Gynecol. Jan. 1983;61(1):109-12. X-2. [pmid: 6337354].
762 Fraser IS, Pearse C, Shearman RP, et al. Efficacy of mefenamic acid in patients with a complaint of menorrhagia. Obstet Gynecol. Nov. 1981;58(5):543-51. X-2, X-3, X-4. [pmid: 7029369].
763 Fraser IS, Romer T, Parke S, et al. Effective treatment of heavy and/or prolonged menstrual bleeding with an oral contraceptive containing estradiol valerate and dienogest: A randomized, double-blind Phase III trial. Human Reproduction. 2011;26(10):2698-708. X-2, X-3. [pmid: 21784734].
764 Fraser JS, Muller AF, Smith DJ, et al. Renal tubular injury is present in acute inflammatory bowel disease prior to the introduction of drug therapy. Aliment Pharmacol Ther. Aug. 2001;15(8):1131-7. X-2, X-3, X-4. [pmid: 11472315].
765 Freedland SJ, Blanco-Yarosh M, Sun JC, et al. Ketorolac-based analgesia improves outcomes for living kidney donors. Transplantation. Mar. 15. 2002;73(5):741-5. X-2, X-3, X-4. [pmid: 11907420].
766 Friedman S, Flidel-Rimon O, Steinberg M, et al. Indomethacin tocolysis and white matter injury in preterm infants. J Matern Fetal Neonatal Med. Aug. 2005;18(2):87-91. X-4. [pmid: 16203592].
767 Fries J. Toward an understanding of NSAID-related adverse events: the contribution of longitudinal data. Scand J Rheumatol Suppl. 1996;102:3-8. X-4. [pmid: 8628980].
768 Fries JF. Safety issues related to DMARD therapy. J Rheumatol Suppl. Nov. 1990;25:14-7. X-1, X-4. [pmid: 2273518].
769 Fries JF. ARAMIS and toxicity measurement. (Arthritis Rheumatism and Aging Medical Information System). J Rheumatol. May. 1995;22(5):995-7. X-1, X-2, X-3, X-4. [pmid: 8587097].
770 Fries JF, Williams CA, Bloch DA. The relative toxicity of nonsteroidal antiinflammatory drugs. Arthritis Rheum. Nov. 1991;34(11):1353-60. X-4. [pmid: 1953813].
771 Fries JF, Williams CA, Bloch DA, et al. Nonsteroidal anti-inflammatory drug-associated gastropathy: incidence and risk factor models. Am J Med. Sep. 1991;91(3):213-22. X-4. [pmid: 1892140].
772 Fries JF, Williams CA, Ramey D, et al. The relative toxicity of disease-modifying antirheumatic drugs. Arthritis Rheum. Mar. 1993;36(3):297-306. X-4. [pmid: 8452574].
773 Friesecke S, Abel P, Roser M, et al. Outcome of severe lactic acidosis associated with metformin accumulation. Crit Care. 2010;14(6):R226. X-2. [pmid: 21171991].
774 Friis S, Thomassen L, Sorensen HT, et al. Nonsteroidal anti-inflammatory drug use and breast cancer risk: a Danish cohort study. Eur J Cancer Prev. Apr. 2008;17(2):88-96. X-4. [pmid: 18287865].
775 Fromm GL, Freedman RS, Fritsche HA, et al. Sequentially administered ethinyl estradiol and medroxyprogesterone acetate in the treatment of refractory epithelial ovarian carcinoma in patients with positive estrogen receptors. Cancer. Nov. 1. 1991;68(9):1885-9. X-2, X-3, X-4. [pmid: 1833046].
776 Froud T, Faradji RN, Pileggi A, et al. The use of exenatide in islet transplant recipients with chronic allograft dysfunction: safety, efficacy, and metabolic effects. Transplantation. Jul. 15. 2008;86(1):36-45. X-2, X-4. [pmid: 18622276].
777 Fuchs N, Dusterberg B, Weber-Diehl F, et al. The effect on blood pressure of a monophasic oral contraceptive containing ethinylestradiol and gestodene. Contraception. Jun. 1995;51(6):335-9. X-4. [pmid: 7554972].
778 Fugere P. Five years experience of intrauterine contraception with the Nova-T. Contraception. Jan. 1990;41(1):1-7. X-2, X-3, X-4. [pmid: 2302943].
779 Fujii AM, Brown E, Mirochnick M, et al. Neonatal necrotizing enterocolitis with intestinal perforation in extremely premature infants receiving early indomethacin treatment for patent ductus arteriosus. J Perinatol. Oct-Nov. 2002;22(7):535-40. X-2, X-3, X-4. [pmid: 12368968].
780 Fujii T, Nakabayashi T, Hashimoto S, et al. Correlation between serum triglycerides and gastro-duodenal ulcer associated with low-dose aspirin. Hepatogastroenterology. Jul-Aug. 2009;56(93):1241-4. X-2, X-4. [pmid: 19760979].
781 Fujimori S, Gudis K, Takahashi Y, et al. Distribution of small intestinal mucosal injuries as a result of NSAID administration. Eur J Clin Invest. Jun. 2010;40(6):504-10. X-2. [pmid: 20412292].
782 Fujisawa N, Inamori M, Endo H, et al. Incidence of and risk factors for upper gastrointestinal complications in patients taking low-dose aspirin in Japan. Hepatogastroenterology. Jan-Feb. 2011;58(105):229-34. X-2, X-4. [pmid: 21510320].
783 Fujita WH, McCormick CL, Parneix-Spake A. An exploratory study to evaluate the efficacy of pimecrolimus cream 1% for the treatment of pityriasis alba. Int J Dermatol. Jul. 2007;46(7):700-5. X-2, X-3, X-4. [pmid: 17614797].
784 Fuldeore MJ, Marx SE, Chwalisz K, et al. Add-back therapy use and its impact on LA persistence in patients with endometriosis. Curr Med Res Opin. Mar. 2010;26(3):729-36. X-2, X-3, X-4. [pmid: 20092387].
785 Fuller JR, Bevin TH, Molteno AC, et al. Anti-inflammatory fibrosis suppression in threatened trabeculectomy bleb failure produces good long term control of intraocular pressure without risk of sight threatening complications. Br J Ophthalmol. Dec. 2002;86(12):1352-4. X-2, X-3, X-4. [pmid: 12446362].
786 Furberg CD, Vittinghoff E, Davidson M, et al. Subgroup interactions in the Heart and Estrogen/Progestin Replacement Study: lessons learned. Circulation. Feb. 26. 2002;105(8):917-22. X-3, X-4. [pmid: 11864918].
787 Gabb GM, Ryan P, Wing LM, et al. Epidemiological study of angioedema and ACE inhibitors. Aust N Z J Med. Dec. 1996;26(6):777-82. X-2, X-3, X-4. [pmid: 9028507].
788 Gabriel SE, Campion ME, O'Fallon WM. A cost-utility analysis of misoprostol prophylaxis for rheumatoid arthritis patients receiving nonsteroidal antiinflammatory drugs. Arthritis Rheum. Mar. 1994;37(3):333-41. X-2, X-3, X-4. [pmid: 8129789].
789 Gabriel SE, Sunku J, Salvarani C, et al. Adverse outcomes of antiinflammatory therapy among patients with polymyalgia rheumatica. Arthritis Rheum. Oct. 1997;40(10):1873-8. X-2. [pmid: 9336424].
790 Gadsby R, Holden J. The Multiload CU250 in general practice. Practitioner. Dec. 1988;232(1460):1343. 7. X-1, X-2, X-3, X-4. [pmid: 3256888].
791 Gagne JJ, Maio V, Rabinowitz C. Prevalence and predictors of potential drug-drug interactions in Regione Emilia-Romagna, Italy. J Clin Pharm Ther. Apr. 2008;33(2):141-51. X-3, X-4. [pmid: 18315779].
792 Gal P, Ransom JL, Schall S, et al. Indomethacin for patent ductus arteriosus closure. Application of serum concentrations and pharmacodynamics to improve response. J Perinatol. Mar. 1990;10(1):20-6. X-2, X-3, X-4. [pmid: 2313390].
793 Galasko CS, Courtney P, Jayne M, et al. Comparison of the efficacy of naproxen sodium and dihydrocodeine tartrate in the treatment of post-operative pain. Curr Med Res Opin. 1988;10(10):656-62. X-2, X-3, X-4. [pmid: 3371081].
794 Gallagher PF, Barry PJ, Ryan C, et al. Inappropriate prescribing in an acutely ill population of elderly patients as determined by Beers' Criteria. Age Ageing. Jan. 2008;37(1):96-101. X-2, X-3, X-4. [pmid: 17933759].
795 Gallelli L, Colosimo M, Pirritano D, et al. Retrospective evaluation of adverse drug reactions induced by nonsteroidal anti-inflammatory drugs. Clin Drug Investig. 2007;27(2):115-22. X-4. [pmid: 17217316].
796 Gallerani M, Simonato M, Manfredini R, et al. Risk of hospitalization for upper gastrointestinal tract bleeding. J Clin Epidemiol. Jan. 2004;57(1):103-10. X-4. [pmid: 15019017].
797 Gallicchio L, Visvanathan K, Burke A, et al. Nonsteroidal anti-inflammatory drugs and the risk of developing breast cancer in a population-based prospective cohort study in Washington County, MD. Int J Cancer. Jul. 1. 2007;121(1):211-15. X-4. [pmid: 17330846].
798 Ganacharya S, Bhattoa HP, Batar I. Ectopic pregnancy among non-medicated and copper-containing intrauterine device users: a 10-year follow-up. Eur J Obstet Gynecol Reprod Biol. Nov. 10. 2003;111(1):78-82. X-4. [pmid: 14557017].
799 Ganacharya S, Bhattoa HP, Batar I. Pre-malignant and malignant cervical pathologies among inert and copper-bearing intrauterine contraceptive device users: a 10-year follow-up study. Eur J Contracept Reprod Health Care. Jun. 2006;11(2):89-97. X-4. [pmid: 16854681].
800 Ganie MA, Khurana ML, Eunice M, et al. Comparison of efficacy of spironolactone with metformin in the management of polycystic ovary syndrome: an open-labeled study. J Clin Endocrinol Metab. Jun. 2004;89(6):2756-62. X-2, X-4. [pmid: 15181054].
801 Garamvolgyi G. Change to Tri-Regol from other oral contraceptives. Ther Hung. 1991;39(3):122-4. X-2, X-3, X-4. [pmid: 1818425].
802 Garbe E, Andersohn F, Bronder E, et al. Drug induced immune haemolytic anaemia in the Berlin Case-Control Surveillance Study. Br J Haematol. Sep. 2011;154(5):644-53. X-2, X-4. [pmid: 21749359].
803 Garcia Rodriguez LA, Barreales Tolosa L. Risk of upper gastrointestinal complications among users of traditional NSAIDs and COXIBs in the general population. Gastroenterology. Feb. 2007;132(2):498-506. X-4. [pmid: 17258728].
804 Garcia Rodriguez LA, Egan K, FitzGerald GA. Traditional nonsteroidal anti-inflammatory drugs and postmenopausal hormone therapy: a drug-drug interaction?. PLoS Med. May. 2007;4(5):e157. X-4. [pmid: 17518513].
805 Garcia Rodriguez LA, Gonzalez-Perez A. Risk of breast cancer among users of aspirin and other anti-inflammatory drugs. Br J Cancer. Aug. 2. 2004;91(3):525-9. X-4. [pmid: 15226764].
806 Garcia Rodriguez LA, Gonzalez-Perez A. Long-term use of non-steroidal anti-inflammatory drugs and the risk of myocardial infarction in the general population. BMC Med. 2005;3:17. X-4. [pmid: 16316472].
807 Garcia Rodriguez LA, Gonzalez-Perez A, Johansson S, et al. Risk factors for inflammatory bowel disease in the general population. Aliment Pharmacol Ther. Aug. 15. 2005;22(4):309-15. X-4. [pmid: 16097997].
808 Garcia Rodriguez LA, Hernandez-Diaz S. Relative risk of upper gastrointestinal complications among users of acetaminophen and nonsteroidal anti-inflammatory drugs. Epidemiology. Sep. 2001;12(5):570-6. X-4. [pmid: 11505178].
809 Garcia Rodriguez LA, Hernandez-Diaz S. Nonsteroidal antiinflammatory drugs as a trigger of clinical heart failure. Epidemiology. Mar. 2003;14(2):240-6. X-4. [pmid: 12606892].
810 Garcia Rodriguez LA, Hernandez-Diaz S. Risk of uncomplicated peptic ulcer among users of aspirin and nonaspirin nonsteroidal antiinflammatory drugs. Am J Epidemiol. Jan. 1. 2004;159(1):23-31. X-4. [pmid: 14693656].
811 Garcia Rodriguez LA, Jick H. Risk of upper gastrointestinal bleeding and perforation associated with individual non-steroidal anti-inflammatory drugs. Lancet. Mar. 26. 1994;343(8900):769-72. X-4. [pmid: 7907735].
812 Garcia Rodriguez LA, Lin KJ, Hernandez-Diaz S, et al. Risk of upper gastrointestinal bleeding with low-dose acetylsalicylic acid alone and in combination with clopidogrel and other medications. Circulation. Mar. 15. 2011;123(10):1108-15. X-4. [pmid: 21357821].
813 Garcia Rodriguez LA, Perez Gutthann S, Walker AM, et al. The role of non-steroidal anti-inflammatory drugs in acute liver injury. BMJ. Oct. 10. 1992;305(6858):865-8. X-4. [pmid: 1422399].
814 Garcia Rodriguez LA, Ruigomez A. Secondary prevention of upper gastrointestinal bleeding associated with maintenance acid-suppressing treatment in patients with peptic ulcer bleed. Epidemiology. May. 1999;10(3):228-32. X-2, X-3, X-4. [pmid: 10230829].
815 Garcia Rodriguez LA, Ruigomez A, Jick H. A review of epidemiologic research on drug-induced acute liver injury using the general practice research data base in the United Kingdom. Pharmacotherapy. Jul-Aug. 1997;17(4):721-8. X-4. [pmid: 9250549].
816 Garcia Rodriguez LA, Tacconelli S, Patrignani P. Role of dose potency in the prediction of risk of myocardial infarction associated with nonsteroidal anti-inflammatory drugs in the general population. J Am Coll Cardiol. Nov. 11. 2008;52(20):1628-36. X-4. [pmid: 18992652].
817 Garcia Rodriguez LA, Walker AM, Perez Gutthann S. Nonsteroidal antiinflammatory drugs and gastrointestinal hospitalizations in Saskatchewan: a cohort study. Epidemiology. Jul. 1992;3(4):337-42. X-4. [pmid: 1637896].
818 Garcia Rodriguez LA, Williams R, Derby LE, et al. Acute liver injury associated with nonsteroidal anti-inflammatory drugs and the role of risk factors. Arch Intern Med. Feb. 14. 1994;154(3):311-6. X-4. [pmid: 8297198].
819 Garcia-Gonzalez MA, Lanas A, Savelkoul PH, et al. Association of interleukin 1 gene family polymorphisms with duodenal ulcer disease. Clin Exp Immunol. Dec. 2003;134(3):525-31. X-2, X-3, X-4. [pmid: 14632761].
820 Garcia-Porrua C, Gonzalez-Gay MA, Lopez-Lazaro L. Drug associated cutaneous vasculitis in adults in northwestern Spain. J Rheumatol. Sep. 1999;26(9):1942-4. X-2. [pmid: 10493674].
821 Gardner MO, Owen J, Skelly S, et al. Preterm delivery after indomethacin. A risk factor for neonatal complications?. J Reprod Med. Dec. 1996;41(12):903-6. X-2, X-4. [pmid: 8979204].
822 Garza-Flores J. Cyclofem/Cyclo-Provera: emerging countries' perspective. Int J Gynaecol Obstet. Aug. Suppl 1. 1998;62:S31-6. X-4. [pmid: 9806236].
823 Garza-Flores J, Martinez M, Valles De Bourges V, et al. Comparative assessment of two low-dose oral contraceptives, Lo-Femenal and Lo-Estrin, in Mexican women. Adv Contracept. Dec. 1992;8(4):291-301. X-2. [pmid: 1290331].
824 Garza-Flores J, Moraks del Olmo A, Fuziwara JL, et al. Introduction of cyclofem once-a-month injectable contraceptive in Mexico. Contraception. Jul. 1998;58(1):7-12. X-4. [pmid: 9743890].
825 Garza-Flores J, Valles de Bourges V, Martinez M, et al. Safety and efficacy of a combined oral contraceptive: gestodene 75 micrograms plus ethinyl estradiol 30 micrograms in Mexican women. Adv Contracept. Mar. 1994;10(1):19-26. X-2, X-4. [pmid: 8030449].
826 Gasse C, Christensen S, Riis A, et al. Preadmission use of SSRIs alone or in combination with NSAIDs and 30-day mortality after peptic ulcer bleeding. Scand J Gastroenterol. 2009;44(11):1288-95. X-4. [pmid: 19891579].
827 Gasse C, Hollowell J, Meier CR, et al. Drug interactions and risk of acute bleeding leading to hospitalisation or death in patients with chronic atrial fibrillation treated with warfarin. Thromb Haemost. Sep. 2005;94(3):537-43. X-4. [pmid: 16268469].
828 Gazarian M, Berkovitch M, Koren G, et al. Experience with misoprostol therapy for NSAID gastropathy in children. Ann Rheum Dis. Apr. 1995;54(4):277-80. X-2, X-3, X-4. [pmid: 7763105].
829 Geborek P, Crnkic M, Petersson IF, et al. Etanercept, infliximab, and leflunomide in established rheumatoid arthritis: clinical experience using a structured follow up programme in southern Sweden. Ann Rheum Dis. Sep. 2002;61(9):793-8. X-2, X-4. [pmid: 12176803].
830 Geczy M, Peltier L, Wolbach R. Naproxen tolerability in the elderly: a summary report. J Rheumatol. Apr. 1987;14(2):348-54. X-7. [pmid: 3599004].
831 Geisser P, Rumyantsev V. Pharmacodynamics and safety of ferric carboxymaltose: a multiple-dose study in patients with iron-deficiency anaemia secondary to a gastrointestinal disorder. Arzneimittelforschung. 2010;60(6a):373-85. X-2, X-4. [pmid: 20648929].
832 Gemzell-Danielsson K, Inki P, Boubli L, et al. Bleeding pattern and safety of consecutive use of the levonorgestrel-releasing intrauterine system (LNG-IUS)--a multicentre prospective study. Hum Reprod. Feb. 2010;25(2):354-9. X-2, X-4. [pmid: 19955104].
833 Genkinger JM, De Vivo I, Stampfer MJ, et al. Nonsteroidal antiinflammatory drug use and risk of bladder cancer in the health professionals follow-up study. Int J Cancer. May. 15. 2007;120(10):2221-5. X-4, X-6. [pmid: 17290403].
834 Georgiev DB, Manassiev NA. Effect of long-term continuous combined hormone replacement therapy with estradiol valerate and either dienogest or norethisterone acetate on mammographic density in postmenopausal women. Medscape Womens Health. Jul-Aug. 2002;7(4):1. X-2, X-3, X-4. [pmid: 12466733].
835 Gerais AS, Alwahab S, Omran KF, et al. A comparative study of two estrogen dosages in combined oral contraceptives among Sudanese women. Int J Gynaecol Obstet. Dec. 1983;21(6):459-68. X-2, X-4. [pmid: 6141106].
836 Germond M, Capelli P, Bruno G, et al. Comparison of the efficacy and safety of two formulations of micronized progesterone (Ellios and Utrogestan) used as luteal phase support after in vitro fertilization. Fertil Steril. Feb. 2002;77(2):313-7. X-2, X-4. [pmid: 11821089].
837 Geyer M, Peter S, Buhler H, et al. Application of bleeding prophylactic criteria (NICE) in patients with acute gastrointestinal bleeding. A Swiss prospective study. Swiss Med Wkly. Mar. 10. 2007;137(9-10):146-50. X-2, X-3, X-4. [pmid: 17370155].
838 Giannoudis PV, MacDonald DA, Matthews SJ, et al. Nonunion of the femoral diaphysis. The influence of reaming and non-steroidal anti-inflammatory drugs. J Bone Joint Surg Br. Jul. 2000;82(5):655-8. X-2. [pmid: 10963160].
839 Gibson PR, Fixa B, Pekarkova B, et al. Comparison of the efficacy and safety of Eudragit-L-coated mesalazine tablets with ethylcellulose-coated mesalazine tablets in patients with mild to moderately active ulcerative colitis. Aliment Pharmacol Ther. Apr. 1. 2006;23(7):1017-26. X-2, X-3, X-4. [pmid: 16573804].
840 Giercksky KE. Piroxicam and gastrointestinal bleeding. Am J Med. Nov. 28. 1986;81(5B):2-5. X-2, X-4. [pmid: 3491541].
841 Giercksky KE, Huseby G, Rugstad HE. Epidemiology of NSAID-related gastrointestinal side effects. Scand J Gastroenterol Suppl. 1989;163:3-8. X-4. [pmid: 2683027].
842 Gill JK, Maskarinec G, Wilkens LR, et al. Nonsteroidal antiinflammatory drugs and breast cancer risk: the multiethnic cohort. Am J Epidemiol. Nov. 15. 2007;166(10):1150-8. X-4. [pmid: 17698973].
843 Giordano N, Senesi M, Battisti E, et al. Tolerability of nabumetone: a pilot in vitro study showing absence of injury to articular cartilage. Int J Tissue React. 1996;18(4-6):105-8. X-4. [pmid: 9195245].
844 Giribela CR, Rubira MC, Melo NR, et al. Effect of a low-dose oral contraceptive on venous endothelial function in healthy young women: preliminary results. Clinics (Sao Paulo). Apr. 2007;62(2):151-8. X-2, X-4. [pmid: 17505700].
845 Girolami A, Spiezia L, Girolami B, et al. Effect of age on oral contraceptive-induced venous thrombosis. Clin Appl Thromb Hemost. Jul. 2004;10(3):259-63. X-2, X-3. [pmid: 15247983].
846 Gisbert JP, Gonzalez L, de Pedro A, et al. Helicobacter pylori and bleeding duodenal ulcer: prevalence of the infection and role of non-steroidal anti-inflammatory drugs. Scand J Gastroenterol. Jul. 2001;36(7):717-24. X-2, X-3, X-4. [pmid: 11444470].
847 Gisbert JP, Legido J, Garcia-Sanz I, et al. Helicobacter pylori and perforated peptic ulcer prevalence of the infection and role of non-steroidal anti-inflammatory drugs. Dig Liver Dis. Feb. 2004;36(2):116-20. X-2. [pmid: 15002818].
848 Gislason GH, Jacobsen S, Rasmussen JN, et al. Risk of death or reinfarction associated with the use of selective cyclooxygenase-2 inhibitors and nonselective nonsteroidal antiinflammatory drugs after acute myocardial infarction. Circulation. Jun. 27. 2006;113(25):2906-13. X-4. [pmid: 16785336].
849 Gislason GH, Rasmussen JN, Abildstrom SZ, et al. Increased mortality and cardiovascular morbidity associated with use of nonsteroidal anti-inflammatory drugs in chronic heart failure. Arch Intern Med. Jan. 26. 2009;169(2):141-9. X-4. [pmid: 19171810].
850 Giugliano D, Quatraro A, Consoli G, et al. Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol. 1993;44(2):107-12. X-2, X-4. [pmid: 8453955].
851 Giuseppe P, Antonino R, Alessandro DB, et al. Floctafenine: a valid alternative in patients with adverse reactions to nonsteroidal anti-inflammatory drugs. Ann Allergy Asthma Immunol. Jan. 1997;78(1):74-8. X-2, X-3, X-4. [pmid: 9012626].
852 Glantz S, Glantz JC, Campbell-Heider N, et al. Norplant use among urban minority women in the United States. Contraception. Feb. 2000;61(2):83-90. X-2, X-3, X-4. [pmid: 10802272].
853 Glantz S, Schaff E, Campbell-Heider N, et al. Contraceptive implant use among inner city teens. J Adolesc Health. May. 1995;16(5):389-95. X-2, X-3. [pmid: 7662690].
854 Glasier A, Yan Y, Wellings K. How do health care professionals respond to advice on adverse side effects of contraceptive methods? The case of Depo Provera. Contraception. Jul. 2007;76(1):18-22. X-2, X-3, X-4. [pmid: 17586131].
855 Glasier AF, Wang H, Davie JE, et al. Administration of an antiprogesterone up-regulates estrogen receptors in the endometrium of women using Norplant: a pilot study. Fertil Steril. Feb. 2002;77(2):366-72. X-2, X-3, X-4. [pmid: 11821099].
856 Gleason JM, Slezak JM, Jung H, et al. Regular nonsteroidal anti-inflammatory drug use and erectile dysfunction. J Urol. Apr. 2011;185(4):1388-93. X-6. [pmid: 21334642].
857 Gleeson MH, Davis AJ. Non-steroidal anti-inflammatory drugs, aspirin and newly diagnosed colitis: a case-control study. Aliment Pharmacol Ther. Mar. 15. 2003;17(6):817-25. X-2. [pmid: 12641504].
858 Glueck CJ, Bornovali S, Pranikoff J, et al. Metformin, pre-eclampsia, and pregnancy outcomes in women with polycystic ovary syndrome. Diabet Med. Aug. 2004;21(8):829-36. X-2, X-4. [pmid: 15270785].
859 Glueck CJ, Pranikoff J, Aregawi D, et al. Prevention of gestational diabetes by metformin plus diet in patients with polycystic ovary syndrome. Fertil Steril. Mar. 2008;89(3):625-34. X-2, X-3, X-4. [pmid: 17678910].
860 Glueck CJ, Wang P, Kobayashi S, et al. Metformin therapy throughout pregnancy reduces the development of gestational diabetes in women with polycystic ovary syndrome. Fertil Steril. Mar. 2002;77(3):520-5. X-2, X-3, X-4. [pmid: 11872206].
861 Gobeaux-Castadot MJ, Boria MC, Chervenak FA, et al. Five year clinical experience with the Copper 7 intrauterine device. Int J Gynaecol Obstet. Jun. 1981;19(3):181-92. X-2, X-3, X-4. [pmid: 6120864].
862 Godil A, DeGuzman L, Schilling RC 3rd, et al. Recent nonsteroidal anti-inflammatory drug use increases the risk of early recurrence of bleeding in patients presenting with bleeding ulcer. Gastrointest Endosc. Feb. 2000;51(2):146-51. X-2. [pmid: 10650255].
863 Goh H, Bourne R. Non-steroidal anti-inflammatory drugs and perforated diverticular disease: a case-control study. Ann R Coll Surg Engl. Mar. 2002;84(2):93-6. X-2. [pmid: 11995772].
864 Goh JE, Sadler L, Rowan J. Metformin for gestational diabetes in routine clinical practice. Diabet Med. Sep. 2011;28(9):1082-7. X-2, X-3. [pmid: 21679232].
865 Goicoechea M, Caramelo C, Ochando A, et al. Antiplatelet therapy alters iron requirements in hemodialysis patients. Am J Kidney Dis. Jul. 2000;36(1):80-7. X-2, X-3, X-4. [pmid: 10873876].
866 Gokmen O, Yapar Eyi EG. Hormone replacement therapy and lipid-lipoprotein concentrations. Eur J Obstet Gynecol Reprod Biol. Jul. 1999;85(1):31-41. X-4, X-7. [pmid: 10428319].
867 Golbs S, Domhardt R, Presl J, et al. Clinical findings with the oral contraceptive combination ethinylestradiol/dienogest in the Czech Republic. Methods Find Exp Clin Pharmacol. Dec. 2002;24(10):689-96. X-2. [pmid: 12616963].
868 Golbs S, Domhardt R, Radowicky S, et al. Clinical findings with the oral contraceptive combination ethinylestradiol/dienogest in Poland. Methods Find Exp Clin Pharmacol. Nov. 2002;24(9):585-92. X-2. [pmid: 12616705].
869 Goldenberg NA, Jacobson L, Manco-Johnson MJ. Brief communication: duration of platelet dysfunction after a 7-day course of Ibuprofen. Ann Intern Med. Apr. 5. 2005;142(7):506-9. X-2. [pmid: 15809462].
870 Goldstein JL, Chan FK, Lanas A, et al. Haemoglobin decreases in NSAID users over time: an analysis of two large outcome trials. Aliment Pharmacol Ther. Oct. 2011;34(7):808-16. X-4. [pmid: 21810115].
871 Goldstein JL, Cryer B, Amer F, et al. Celecoxib plus aspirin versus naproxen and lansoprazole plus aspirin: a randomized, double-blind, endoscopic trial. Clin Gastroenterol Hepatol. Oct. 2007;5(10):1167-74. X-2, X-4. [pmid: 17916545].
872 Goldstein JL, Eisen GM, Lewis B, et al. Video capsule endoscopy to prospectively assess small bowel injury with celecoxib, naproxen plus omeprazole, and placebo. Clin Gastroenterol Hepatol. Feb. 2005;3(2):133-41. X-2. [pmid: 15704047].
873 Goldstein JL, Huang B, Amer F, et al. Ulcer recurrence in high-risk patients receiving nonsteroidalanti-inflammatory drugs plus low-dose aspirin: results of a post HOC subanalysis. Clin Ther. Oct. 2004;26(10):1637-43. X-2, X-3, X-4. [pmid: 15598480].
874 Goldstein JL, Johanson JF, Suchower LJ, et al. Healing of gastric ulcers with esomeprazole versus ranitidine in patients who continued to receive NSAID therapy: a randomized trial. Am J Gastroenterol. Dec. 2005;100(12):2650-7. X-2, X-3, X-4. [pmid: 16393215].
875 Goldstein JL, Lowry SC, Lanza FL, et al. The impact of low-dose aspirin on endoscopic gastric and duodenal ulcer rates in users of a non-selective non-steroidal anti-inflammatory drug or a cyclo-oxygenase-2-selective inhibitor. Aliment Pharmacol Ther. May. 15. 2006;23(10):1489-98. X-2, X-7. [pmid: 16669964].
876 Goldstein JL, Zhao SZ, Burke TA, et al. Incidence of outpatient physician claims for upper gastrointestinal symptoms among new users of celecoxib, ibuprofen, and naproxen in an insured population in the United States. Am J Gastroenterol. Dec. 2003;98(12):2627-34. X-4. [pmid: 14687808].
877 Gomez F, Ruiz P, Lopez R, et al. Treatment with megestrol acetate improves human immunodeficiency virus-associated immune thrombocytopenia. Clin Diagn Lab Immunol. May. 2002;9(3):583-7. X-2, X-3, X-4. [pmid: 11986264].
878 Gomez HF, McClafferty HH, Flory D, et al. Prevention of gastrointestinal iron absorption by chelation from an orally administered premixed deferoxamine/charcoal slurry. Ann Emerg Med. Nov. 1997;30(5):587-92. X-3, X-4. [pmid: 9360566].
879 Goni AZ, Lacruz RL, Paricio JJ, et al. The levonorgestrel intrauterine system as an alternative to hysterectomy for the treatment of idiopathic menorrhagia. Gynecol Endocrinol. Sep. 2009;25(9):581-6. X-2, X-3, X-4. [pmid: 19562603].
880 Gonzalez Baron M, Feliu J, Espinosa E, et al. Comparison of two chemotherapeutic regimens--mitomycin + vindesine + cisplatin (MVP) vs. mitomycin + ifosfamide + cisplatin (MIP)--in advanced non-small-cell lung cancer. ONCOPAZ Cooperative Group. Ann Oncol. Apr. 1994;5(4):323-7. X-2, X-4. [pmid: 8075028].
881 Gonzalez E, Gutierrez E, Galeano C, et al. Early steroid treatment improves the recovery of renal function in patients with drug-induced acute interstitial nephritis. Kidney Int. Apr. 2008;73(8):940-6. X-2, X-3, X-4. [pmid: 18185501].
882 Gooch K, Culleton BF, Manns BJ, et al. NSAID use and progression of chronic kidney disease. Am J Med. Mar. 2007;120(3):280 e1-7. X-7, X-8. [pmid: 17349452].
883 Goodson NJ, Brookhart AM, Symmons DP, et al. Non-steroidal anti-inflammatory drug use does not appear to be associated with increased cardiovascular mortality in patients with inflammatory polyarthritis: results from a primary care based inception cohort of patients. Ann Rheum Dis. Mar. 2009;68(3):367-72. X-2, X-4. [pmid: 18408253].
884 Gordon P, Rutledge J, Sawin R, et al. Early postnatal dexamethasone increases the risk of focal small bowel perforation in extremely low birth weight infants. J Perinatol. Dec. 1999;19(8 Pt 1):573-7. X-2, X-3, X-4. [pmid: 10645522].
885 Gorgen H, Api M, Akca A, et al. Use of the Levonorgestrel-IUS in the treatment of menorrhagia: assessment of quality of life in Turkish users. Arch Gynecol Obstet. Jun. 2009;279(6):835-40. X-2. [pmid: 19018547].
886 Gracia CR, Sammel MD, Charlesworth S, et al. Sexual function in first-time contraceptive ring and contraceptive patch users. Fertil Steril. Jan. 2010;93(1):21-8. X-2, X-3. [pmid: 18976753].
887 Graff-Iversen S, Hammar N, Thelle DS, et al. Hormone therapy and mortality during a 14-year follow-up of 14 324 Norwegian women. J Intern Med. Nov. 2004;256(5):437-45. X-7. [pmid: 15485480].
888 Graff-Iversen S, Tverdal A, Stensvold I. Cardiovascular risk factors in Norwegian women using oral contraceptives: results from a cardiovascular health screening 1985-88. Contraception. Jun. 1996;53(6):337-44. X-4. [pmid: 8773420].
889 Graham DJ, Campen D, Hui R, et al. Risk of acute myocardial infarction and sudden cardiac death in patients treated with cyclo-oxygenase 2 selective and non-selective non-steroidal anti-inflammatory drugs: nested case-control study. Lancet. Feb. 5-11. 2005;365(9458):475-81. X-4. [pmid: 15705456].
890 Graham DY, Agrawal NM, Campbell DR, et al. Ulcer prevention in long-term users of nonsteroidal anti-inflammatory drugs: results of a double-blind, randomized, multicenter, active- and placebo-controlled study of misoprostol vs lansoprazole. Arch Intern Med. Jan. 28. 2002;162(2):169-75. X-2, X-3, X-4. [pmid: 11802750].
891 Graham DY, Opekun AR, Willingham FF, et al. Visible small-intestinal mucosal injury in chronic NSAID users. Clin Gastroenterol Hepatol. Jan. 2005;3(1):55-9. X-2, X-4. [pmid: 15645405].
892 Graham EM, Atz AM, Gillis J, et al. Differential effects of aprotinin and tranexamic acid on outcomes and cytokine profiles in neonates undergoing cardiac surgery. J Thorac Cardiovasc Surg. May. 2012;143(5):1069-76. X-2, X-4. [pmid: 22075061].
893 Graser T, Koytchev R, Muller A, et al. Comparison of the efficacy and endometrial safety of two estradiol valerate/dienogest combinations and Kliogest for continuous combined hormone replacement therapy in postmenopausal women. Climacteric. Jun. 2000;3(2):109-18. X-4, X-7. [pmid: 11910651].
894 Greenberg JD, Bingham CO 3rd, Abramson SB, et al. Effect of cardiovascular comorbidities and concomitant aspirin use on selection of cyclooxygenase inhibitor among rheumatologists. Arthritis Rheum. Feb. 15. 2005;53(1):12-7. X-4. [pmid: 15696570].
895 Greenberg JD, Fisher MC, Kremer J, et al. The COX-2 inhibitor market withdrawals and prescribing patterns by rheumatologists in patients with gastrointestinal and cardiovascular risk. Clin Exp Rheumatol. May-Jun. 2009;27(3):395-401. X-3, X-4. [pmid: 19604430].
896 Greendale GA, Espeland M, Slone S, et al. Bone mass response to discontinuation of long-term hormone replacement therapy: results from the Postmenopausal Estrogen/Progestin Interventions (PEPI) Safety Follow-up Study. Arch Intern Med. Mar. 25. 2002;162(6):665-72. X-2, X-4. [pmid: 11911720].
897 Greendale GA, Reboussin BA, Sie A, et al. Effects of estrogen and estrogen-progestin on mammographic parenchymal density. Postmenopausal Estrogen/Progestin Interventions (PEPI) Investigators. Ann Intern Med. Feb. 16. 1999;130(4 Pt 1):262-9. X-2. [pmid: 10068383].
898 Greene GF, Millard OH, Norman RW, et al. Cystitis associated with tiaprofenic acid. J Urol. Oct. 1994;152(4):1101-2. X-2. [pmid: 8072073].
899 Greenson JK, Stern RA, Carpenter SL, et al. The clinical significance of focal active colitis. Hum Pathol. Jun. 1997;28(6):729-33. X-2. [pmid: 9191008].
900 Greer JB, Modugno F, Allen GO, et al. Androgenic progestins in oral contraceptives and the risk of epithelial ovarian cancer. Obstet Gynecol. Apr. 2005;105(4):731-40. X-2, X-3, X-4. [pmid: 15802398].
901 Griffin MR, Piper JM, Daugherty JR, et al. Nonsteroidal anti-inflammatory drug use and increased risk for peptic ulcer disease in elderly persons. Ann Intern Med. Feb. 15. 1991;114(4):257-63. X-7. [pmid: 1987872].
902 Griffin MR, Smalley WE. Drugs and ulcers: clues about mucosal protection from epidemiologic studies. J Clin Gastroenterol. Suppl 1. 1995;21:S113-9. X-4, X-5. [pmid: 8775002].
903 Grigorieva V, Chen-Mok M, Tarasova M, et al. Use of a levonorgestrel-releasing intrauterine system to treat bleeding related to uterine leiomyomas. Fertil Steril. May. 2003;79(5):1194-8. X-2, X-3, X-4. [pmid: 12738516].
904 Grimaldi-Bensouda L, Rossignol M, Danchin N, et al. Risk of ST versus non-ST elevation myocardial infarction associated with non-steroidal anti-inflammatory drugs. Heart. Nov. 2011;97(22):1834-40. X-4. [pmid: 21880652].
905 Grimmelt AC, Cohen CD, Fehr T, et al. Safety and tolerability of ferric carboxymaltose (FCM) for treatment of iron deficiency in patients with chronic kidney disease and in kidney transplant recipients. Clin Nephrol. Feb. 2009;71(2):125-9. X-2, X-4. [pmid: 19203504].
906 Grodstein F, Skarupski KA, Bienias JL, et al. Anti-inflammatory agents and cognitive decline in a bi-racial population. Neuroepidemiology. 2008;30(1):45-50. X-4, X-7. [pmid: 18259082].
907 Grohs JG, Schmidt M, Wanivenhaus A. Selective COX-2 inhibitor versus indomethacin for the prevention of heterotopic ossification after hip replacement: a double-blind randomized trial of 100 patients with 1-year follow-up. Acta Orthop. Feb. 2007;78(1):95-8. X-2, X-4. [pmid: 17453399].
908 Gronich N, Lavi I, Rennert G. Higher risk of venous thrombosis associated with drospirenone-containing oral contraceptives: a population-based cohort study. CMAJ. Dec. 13. 2011;183(18):E1319-25. X-4. [pmid: 22065352].
909 Grosset K, Needleman F, Macphee G, et al. Switching from ergot to nonergot dopamine agonists in Parkinson's disease: a clinical series and five-drug dose conversion table. Mov Disord. Nov. 2004;19(11):1370-4. X-2, X-4, X-8. [pmid: 15389984].
910 Grover R, Jones BM, Waterhouse N. The prevention of haematoma following rhytidectomy: a review of 1078 consecutive facelifts. Br J Plast Surg. Sep. 2001;54(6):481-6. X-2, X-3, X-4. [pmid: 11513508].
911 Grover SA, Coupal L, Zowall H. Treating osteoarthritis with cyclooxygenase-2-specific inhibitors: what are the benefits of avoiding blood pressure destabilization?. Hypertension. Jan. 2005;45(1):92-7. X-3, X-4. [pmid: 15545508].
912 Grover V, Usha R, Gupta U, et al. Management of cyclical menorrhagia with prostaglandin synthetase inhibitor. Asia Oceania J Obstet Gynaecol. Sep. 1990;16(3):255-9. X-2, X-3, X-4. [pmid: 2088249].
913 Grubb GS, Moore D, Anderson NG. Pre-introductory clinical trials of Norplant implants: a comparison of seventeen countries' experience. Contraception. Nov. 1995;52(5):287-96. X-3, X-4. [pmid: 8585885].
914 Gruber EM, Shukla AC, Reid RW, et al. Synthetic antifibrinolytics are not associated with an increased incidence of baffle fenestration closure after the modified Fontan procedure. J Cardiothorac Vasc Anesth. Jun. 2000;14(3):257-9. X-2, X-3, X-4. [pmid: 10890476].
915 Gu SJ, Du MK, Zhang LD, et al. A 5-year evaluation of NORPLANT contraceptive implants in China. Obstet Gynecol. May. 1994;83(5 Pt 1):673-8. X-4. [pmid: 8164924].
916 Guang-Sheng F, Mei-Lu B, Li-Nan C, et al. Efficacy and safety of the combined oral contraceptive ethinylestradiol/drospirenone (Yasmin) in healthy Chinese women: a randomized, open-label, controlled, multicentre trial. Clin Drug Investig. 2010;30(6):387-96. X-2, X-4. [pmid: 20201608].
917 Guazzelli CA, Barreiros FA, Barbosa R, et al. Extended regimens of the vaginal contraceptive ring: cycle control. Contraception. Nov. 2009;80(5):430-5. X-2, X-3, X-4. [pmid: 19835716].
918 Guazzelli CA, Jacobucci MS, Barbieri M, et al. Monthly injectable contraceptive use by adolescents in Brazil: evaluation of clinical aspects. Contraception. Jul. 2007;76(1):45-8. X-2, X-3, X-4. [pmid: 17586136].
919 Gudmundsdottir ES, Jonsson H. CPH 82 (Reumacon) in refractory inflammatory arthritis. Scand J Rheumatol. 2000;29(5):323-5. X-2, X-4. [pmid: 11093600].
920 Guess HA, West R, Strand LM, et al. Fatal upper gastrointestinal hemorrhage or perforation among users and nonusers of nonsteroidal anti-inflammatory drugs in Saskatchewan, Canada 1983. J Clin Epidemiol. 1988;41(1):35-45. X-4. [pmid: 3257254].
921 Gulliford M, Latinovic R. Mortality in type 2 diabetic subjects prescribed metformin and sulphonylurea drugs in combination: cohort study. Diabetes Metab Res Rev. May-Jun. 2004;20(3):239-45. X-3. [pmid: 15133756].
922 Gulmez SE, Droz-Perroteau C, Lassalle R, et al. Are traditional NSAIDs prescribed appropriately among French elderly with osteoarthritis? Results from the CADEUS cohort. Eur J Clin Pharmacol. Aug. 2011;67(8):833-8. X-4, X-8. [pmid: 21387168].
923 Guney M, Oral B, Karahan N, et al. Expression of leukaemia inhibitory factor (LIF) during the window of implantation in copper T380A intrauterine device users. Eur J Contracept Reprod Health Care. Sep. 2007;12(3):212-9. X-2, X-3, X-4. [pmid: 17763259].
924 Gunter MJ, Canzian F, Landi S, et al. Inflammation-related gene polymorphisms and colorectal adenoma. Cancer Epidemiol Biomarkers Prev. Jun. 2006;15(6):1126-31. X-2, X-3, X-4. [pmid: 16775170].
925 Gunthert AR, Faber M, Knappe G, et al. Early onset vulvar Lichen Sclerosus in premenopausal women and oral contraceptives. Eur J Obstet Gynecol Reprod Biol. Mar. 2008;137(1):56-60. X-2. [pmid: 18055095].
926 Gupta A, Daggett C, Ludwick J, et al. Ketorolac after congenital heart surgery: does it increase the risk of significant bleeding complications?. Paediatr Anaesth. Feb. 2005;15(2):139-42. X-2, X-4. [pmid: 15675931].
927 Gupta I, Mahajan U, Sawhney H. Concurrent copper T insertion with medical termination of pregnancy in women with previous caesarean section delivery. Indian J Med Res. May. 1988;87:450-2. X-4. [pmid: 3169901].
928 Gurwitz JH, Avorn J, Bohn RL, et al. Initiation of antihypertensive treatment during nonsteroidal anti-inflammatory drug therapy. JAMA. Sep. 14. 1994;272(10):781-6. X-4, X-7. [pmid: 8078142].
929 Gurwitz JH, Avorn J, Ross-Degnan D, et al. Nonsteroidal anti-inflammatory drug-associated azotemia in the very old. JAMA. Jul. 25. 1990;264(4):471-5. X-2. [pmid: 2366280].
930 Guslandi M, Foppa L, Fanti L, et al. Nonsteroidal anti-inflammatory drugs and gastric mucosal blood flow. J Clin Gastroenterol. Apr. 1999;28(3):258-60. X-2. [pmid: 10192617].
931 Gutthann SP, Garcia Rodriguez LA, Raiford DS. Individual nonsteroidal antiinflammatory drugs and other risk factors for upper gastrointestinal bleeding and perforation. Epidemiology. Jan. 1997;8(1):18-24. X-4. [pmid: 9116088].
932 Haag MD, Bos MJ, Hofman A, et al. Cyclooxygenase selectivity of nonsteroidal anti-inflammatory drugs and risk of stroke. Arch Intern Med. Jun. 9. 2008;168(11):1219-24. X-7. [pmid: 18541831].
933 Hagglund H, Remberger M, Klaesson S, et al. Norethisterone treatment, a major risk-factor for veno-occlusive disease in the liver after allogeneic bone marrow transplantation. Blood. Dec. 15. 1998;92(12):4568-72. X-2. [pmid: 9845522].
934 Hahn HS, Yoon SG, Hong JS, et al. Conservative treatment with progestin and pregnancy outcomes in endometrial cancer. Int J Gynecol Cancer. Aug. 2009;19(6):1068-73. X-2, X-3, X-4. [pmid: 19820370].
935 Haimov-Kochman R, Doviner V, Amsalem H, et al. Intraperitoneal levonorgestrel-releasing intrauterine device following uterine perforation: the role of progestins in adhesion formation. Hum Reprod. May. 2003;18(5):990-3. X-2. [pmid: 12721174].
936 Haines CJ, Chung TK, Lau TK. Sonographic measurement of endometrial thickness as a predictor of vaginal bleeding in women using continuous combined hormone replacement therapy. Gynecol Obstet Invest. 1997;44(3):187-90. X-3, X-4. [pmid: 9359646].
937 Hall P, Bahamondes L, Diaz J, et al. Introductory study of the once-a-month, injectable contraceptive Cyclofem in Brazil, Chile, Colombia, and Peru. Contraception. Dec. 1997;56(6):353-9. X-4. [pmid: 9494768].
938 Hall P, Maclachlan N, Thorn N, et al. Control of menorrhagia by the cyclo-oxygenase inhibitors naproxen sodium and mefenamic acid. Br J Obstet Gynaecol. Jun. 1987;94(6):554-8. X-2, X-3, X-4. [pmid: 3304401].
939 Hall R, Lonngren T, Tyden O, et al. The intrauterine contraceptive device, “Multiload Cu 250”: a regulatory problem. Regul Toxicol Pharmacol. Aug. 1991;14(1):41-7. X-1, X-2, X-4. [pmid: 1947244].
940 Hallas J, Lauritsen J, Villadsen HD, et al. Nonsteroidal anti-inflammatory drugs and upper gastrointestinal bleeding, identifying high-risk groups by excess risk estimates. Scand J Gastroenterol. May. 1995;30(5):438-44. X-4. [pmid: 7638569].
941 Halmesmaki KH, Paavonen JA, Tuppurainen MT, et al. Randomized controlled trial of the effect of hysterectomy or LNG-IUS use on bone mineral density: A five-year follow-up. Therapy. 2006;3(4):509-15. X-2.
942 Hamid S, Yakoob J, Jafri W, et al. Frequency of NSAID induced peptic ulcer disease. J Pak Med Assoc. May. 2006;56(5):218-22. X-2. [pmid: 16767948].
943 Hammad TA, Graham DJ, Staffa JA, et al. Onset of acute myocardial infarction after use of non-steroidal anti-inflammatory drugs. Pharmacoepidemiol Drug Saf. Apr. 2008;17(4):315-21. X-4. [pmid: 18302311].
944 Hammerman C, Glaser J, Kaplan M, et al. Indomethacin tocolysis increases postnatal patent ductus arteriosus severity. Pediatrics. Nov. 1998;102(5):E56. X-2, X-3, X-4. [pmid: 9794986].
945 Hammerstein J, Daume E, Simon A, et al. Influence of gestodene and desogestrel as components of low-dose oral contraceptives on the pharmacokinetics of ethinyl estradiol (EE2), on serum CBG and on urinary cortisol and 6 beta-hydroxycortisol. Contraception. Mar. 1993;47(3):263-81. X-2, X-3, X-4. [pmid: 8462317].
946 Hampton NR, Rees MC, Lowe DG, et al. Levonorgestrel intrauterine system (LNG-IUS) with conjugated oral equine estrogen: a successful regimen for HRT in perimenopausal women. Hum Reprod. Sep. 2005;20(9):2653-60. X-2, X-3, X-4. [pmid: 15905289].
947 Hanauer SB, Sandborn WJ, Kornbluth A, et al. Delayed-release oral mesalamine at 4.8 g/day (800 mg tablet) for the treatment of moderately active ulcerative colitis: the ASCEND II trial. Am J Gastroenterol. Nov. 2005;100(11):2478-85. X-2, X-3, X-4. [pmid: 16279903].
948 Hancock DB, Haberg SE, Furu K, et al. Oral contraceptive pill use before pregnancy and respiratory outcomes in early childhood. Pediatr Allergy Immunol. Aug. 2011;22(5):528-36. X-4. [pmid: 21294776].
949 Hancock DB, Martin ER, Stajich JM, et al. Smoking, caffeine, and nonsteroidal anti-inflammatory drugs in families with Parkinson disease. Arch Neurol. Apr. 2007;64(4):576-80. X-2, X-4. [pmid: 17420321].
950 Hanggi W, Bersinger N, Altermatt HJ, et al. Comparison of transvaginal ultrasonography and endometrial biopsy in endometrial surveillance in postmenopausal HRT users. Maturitas. Jun. 1997;27(2):133-43. X-2, X-4, X-7. [pmid: 9255748].
951 Hannaford P. Postmarketing surveillance study of Norplant in developing countries. Lancet. Jun. 9. 2001;357(9271):1815-6. X-1, X-4. [pmid: 11410183].
952 Hannaford PC, Kay CR, Vessey MP, et al. Combined oral contraceptives and liver disease. Contraception. Mar. 1997;55(3):145-51. X-4. [pmid: 9115002].
953 Hannibal CG, Jensen A, Sharif H, et al. Risk of thyroid cancer after exposure to fertility drugs: results from a large Danish cohort study. Hum Reprod. Feb. 2008;23(2):451-6. X-4. [pmid: 18065402].
954 Hannibal CG, Rossing MA, Wicklund KG, et al. Analgesic drug use and risk of epithelial ovarian cancer. Am J Epidemiol. Jun. 15. 2008;167(12):1430-7. X-2, X-4. [pmid: 18390840].
955 Hansen JM, Hallas J, Lauritsen JM, et al. Non-steroidal anti-inflammatory drugs and ulcer complications: a risk factor analysis for clinical decision-making. Scand J Gastroenterol. Feb. 1996;31(2):126-30. X-2, X-3, X-4. [pmid: 8658033].
956 Hansen KE, Cush J, Singhal A, et al. The safety and efficacy of leflunomide in combination with infliximab in rheumatoid arthritis. Arthritis Rheum. Apr. 15. 2004;51(2):228-32. X-2, X-4. [pmid: 15077264].
957 Hardo PG, Chalmers DM, Jakeways M, et al. Management of NSAIDs-related dyspepsia in the community. Br J Clin Pract. Sep-Oct. 1993;47(5):241-2. X-2, X-3, X-4. [pmid: 8292467].
958 Harel Z, Biro FM, Kollar LM. Depo-Provera in adolescents: effects of early second injection or prior oral contraception. J Adolesc Health. May. 1995;16(5):379-84. X-2. [pmid: 7662688].
959 Harel Z, Biro FM, Kollar LM, et al. Adolescents' reasons for and experience after discontinuation of the long-acting contraceptives Depo-Provera and Norplant. J Adolesc Health. Aug. 1996;19(2):118-23. X-2. [pmid: 8863083].
960 Harel Z, Johnson CC, Gold MA, et al. Recovery of bone mineral density in adolescents following the use of depot medroxyprogesterone acetate contraceptive injections. Contraception. Apr. 2010;81(4):281-91. X-2, X-4. [pmid: 20227543].
961 Harel Z, Wolter K, Gold MA, et al. Biopsychosocial variables associated with substantial bone mineral density loss during the use of depot medroxyprogesterone acetate in adolescents: adolescents who lost 5% or more from baseline vs. those who lost less than 5%. Contraception. Dec. 2010;82(6):503-12. X-2. [pmid: 21074012].
962 Harley C, Wagner S. The prevalence of cardiorenal risk factors in patients prescribed nonsteroidal anti-inflammatory drugs: data from managed care. Clin Ther. Jan. 2003;25(1):139-49. X-4. [pmid: 12637116].
963 Harley EH, Dattolo RA. Ibuprofen for tonsillectomy pain in children: efficacy and complications. Otolaryngol Head Neck Surg. Nov. 1998;119(5):492-6. X-2, X-4. [pmid: 9807075].
964 Harris CL, Raisch DW, Abhyankar U, et al. GI risk factors and use of GI protective agents among patients receiving nonsteroidal antiinflammatory drugs. Ann Pharmacother. Nov. 2006;40(11):1924-31. X-6. [pmid: 17047140].
965 Harris RE, Namboodiri KK, Farrar WB. Nonsteroidal antiinflammatory drugs and breast cancer. Epidemiology. Mar. 1996;7(2):203-5. X-4. [pmid: 8834563].
966 Harris TG, Miller L, Kulasingam SL, et al. Depot-medroxyprogesterone acetate and combined oral contraceptive use and cervical neoplasia among women with oncogenic human papillomavirus infection. Am J Obstet Gynecol. May. 2009;200(5):489 e1-8. X-2. [pmid: 19375566].
967 Harrison-Woolrych M, Ashton J, Coulter D. Insertion of the Multiload Cu375 intrauterine device; experience in over 16,000 New Zealand women. Contraception. Dec. 2002;66(6):387-91. X-4. [pmid: 12499029].
968 Harrison-Woolrych M, Ashton J, Coulter D. Uterine perforation on intrauterine device insertion: is the incidence higher than previously reported?. Contraception. Jan. 2003;67(1):53-6. X-4. [pmid: 12521659].
969 Harrison-Woolrych M, Herbison P, McLean R, et al. Incidence of thrombotic cardiovascular events in patients taking celecoxib compared with those taking rofecoxib: interim results from the New Zealand Intensive Medicines Monitoring Programme. Drug Saf. 2005;28(5):435-42. X-4. [pmid: 15853444].
970 Hart RG, Pearce LA, Rothbart RM, et al. Stroke with intermittent atrial fibrillation: incidence and predictors during aspirin therapy. Stroke Prevention in Atrial Fibrillation Investigators. J Am Coll Cardiol. Jan. 2000;35(1):183-7. X-2, X-3, X-4. [pmid: 10636278].
971 Hartnell NR, Wilson JP. Replication of the Weber effect using postmarketing adverse event reports voluntarily submitted to the United States Food and Drug Administration. Pharmacotherapy. Jun. 2004;24(6):743-9. X-2, X-3, X-4. [pmid: 15222664].
972 Harvey PW, Heywood PF, Nesheim MC, et al. The effect of iron therapy on malarial infection in Papua New Guinean schoolchildren. Am J Trop Med Hyg. Jan. 1989;40(1):12-8. X-3, X-4. [pmid: 2644855].
973 Hasan SS, Khan FH, Ahmed M. Comparison of ketorolac with morphine for intra-operative analgesia in patients undergoing total abdominal hysterectomy. J Pak Med Assoc. Oct. 2003;53(10):467-71. X-2, X-4. [pmid: 14696887].
974 Hassan EO, el-Nahal N, el-Hussein M. Acceptability of the once-a-month injectable contraceptives Cyclofem and Mesigyna in Egypt. Contraception. May. 1994;49(5):469-88. X-2, X-3, X-4. [pmid: 8045133].
975 Hassan EO, Kafafi L, el Husseini M, et al. The acceptability of Norplant in Egypt. Adv Contracept. Dec. 1992;8(4):331-48. X-3, X-4. [pmid: 1365819].
976 Hassanein M, Hanif W, Malik W, et al. Comparison of the dipeptidyl peptidase-4 inhibitor vildagliptin and the sulphonylurea gliclazide in combination with metformin, in Muslim patients with type 2 diabetes mellitus fasting during Ramadan: results of the VECTOR study. Curr Med Res Opin. Jul. 2011;27(7):1367-74. X-2, X-4. [pmid: 21568833].
977 Hauta-Aho M, Tirkkonen T, Vahlberg T, et al. The effect of drug interactions on bleeding risk associated with warfarin therapy in hospitalized patients. Ann Med. 2009;41(8):619-28. X-4. [pmid: 19711211].
978 Hawkey C, Kahan A, Steinbruck K, et al. Gastrointestinal tolerability of meloxicam compared to diclofenac in osteoarthritis patients. International MELISSA Study Group. Meloxicam Large-scale International Study Safety Assessment. Br J Rheumatol. Sep. 1998;37(9):937-45. X-3, X-4. [pmid: 9783757].
979 Hawkey C, Talley NJ, Yeomans ND, et al. Improvements with esomeprazole in patients with upper gastrointestinal symptoms taking non-steroidal antiinflammatory drugs, including selective COX-2 inhibitors. Am J Gastroenterol. May. 2005;100(5):1028-36. X-4. [pmid: 15842575].
980 Hawkey CJ. Naproxen sodium did not lead to substantially more upper gastrointestinal tract bleeding than ibuprofen during short term use as an analgesic. Gut. Sep. 1998;43(3):315. X-1, X-2, X-4. [pmid: 9863472].
981 Hawkey CJ. Risk of ulcer bleeding in patients infected with Helicobacter pylori taking non-steroidal anti-inflammatory drugs. Gut. Mar. 2000;46(3):310-1. X-2. [pmid: 10673289].
982 Hawkey CJ, Hawkey GM, Everitt S, et al. Increased risk of myocardial infarction as first manifestation of ischaemic heart disease and nonselective nonsteroidal anti-inflammatory drugs. Br J Clin Pharmacol. Jun. 2006;61(6):730-7. X-2. [pmid: 16722837].
983 Hawkey CJ, Naesdal J, Wilson I, et al. Relative contribution of mucosal injury and Helicobacter pylori in the development of gastroduodenal lesions in patients taking non-steroidal anti-inflammatory drugs. Gut. Sep. 2002;51(3):336-43. X-2, X-4. [pmid: 12171953].
984 Hayashi K, Walker AM. Japanese and American reports of randomized trials: differences in the reporting of adverse effects. Control Clin Trials. Apr. 1996;17(2):99-110. X-1, X-2, X-3, X-4. [pmid: 8860062].
985 Hayashi Y, Yamamoto H, Kita H, et al. Non-steroidal anti-inflammatory drug-induced small bowel injuries identified by double-balloon endoscopy. World J Gastroenterol. Aug. 21. 2005;11(31):4861-4. X-2. [pmid: 16097059].
986 Hayashi Y, Yamamoto H, Taguchi H, et al. Nonsteroidal anti-inflammatory drug-induced small-bowel lesions identified by double-balloon endoscopy: endoscopic features of the lesions and endoscopic treatments for diaphragm disease. J Gastroenterol. Suppl 19. 2009;44:57-63. X-2. [pmid: 19148795].
987 Haydardedeoglu B, Simsek E, Kilicdag EB, et al. Metabolic and endocrine effects of metformin and metformin plus cyclic medroxyprogesterone acetate in women with polycystic ovary syndrome. Int J Gynaecol Obstet. Apr. 2009;105(1):32-5. X-2. [pmid: 19155004].
988 Hayes E, Moroz L, Pizzi L, et al. A cost decision analysis of 4 tocolytic drugs. Am J Obstet Gynecol. Oct. 2007;197(4):383 e1-6. X-2, X-3, X-4. [pmid: 17904969].
989 Hayes JH, Anderson KE, Folsom AR. Association between nonsteroidal anti-inflammatory drug use and the incidence of lung cancer in the Iowa women's health study. Cancer Epidemiol Biomarkers Prev. Nov. 2006;15(11):2226-31. X-4. [pmid: 17119050].
990 Heaney M, Looney Y, McKinstry C, et al. Sequential clot strength analyses following diclofenac in pediatric adenotonsillectomy. Paediatr Anaesth. Nov. 2007;17(11):1078-82. X-2, X-3, X-4. [pmid: 17897274].
991 Hedderson MM, Ferrara A, Williams MA, et al. Androgenicity of progestins in hormonal contraceptives and the risk of gestational diabetes mellitus. Diabetes Care. May. 2007;30(5):1062-8. X-2. [pmid: 17303784].
992 Hedenmalm K, Samuelsson E. Fatal venous thromboembolism associated with different combined oral contraceptives: a study of incidences and potential biases in spontaneous reporting. Drug Saf. 2005;28(10):907-16. X-4. [pmid: 16180940].
993 Hedenmalm K, Samuelsson E, Spigset O. Pulmonary embolism associated with combined oral contraceptives: reporting incidences and potential risk factors for a fatal outcome. Acta Obstet Gynecol Scand. Jun. 2004;83(6):576-85. X-4. [pmid: 15144341].
994 Hedenmalm K, Spigset O. Agranulocytosis and other blood dyscrasias associated with dipyrone (metamizole). Eur J Clin Pharmacol. Jul. 2002;58(4):265-74. X-4. [pmid: 12136373].
995 Heerdink ER, Leufkens HG, Herings RM, et al. NSAIDs associated with increased risk of congestive heart failure in elderly patients taking diuretics. Arch Intern Med. May. 25. 1998;158(10):1108-12. X-4, X-7. [pmid: 9605782].
996 Heikkinen J, Vaheri R, Timonen U. A 10-year follow-up of postmenopausal women on long-term continuous combined hormone replacement therapy: Update of safety and quality-of-life findings. J Br Menopause Soc. Sep. 2006;12(3):115-25. X-2, X-4. [pmid: 16953985].
997 Heinemann LA, Kluft C, Spannagl M, et al. The association between extrinsic activated protein C resistance and venous thromboembolism in women. Contraception. Nov. 2002;66(5):297-304. X-2, X-4. [pmid: 12443958].
998 Helin-Salmivaara A, Huttunen T, Gronroos JM, et al. Risk of serious upper gastrointestinal events with concurrent use of NSAIDs and SSRIs: a case-control study in the general population. Eur J Clin Pharmacol. Apr. 2007;63(4):403-8. X-4. [pmid: 17347805].
999 Helin-Salmivaara A, Huupponen R, Virtanen A, et al. Frequent prescribing of drugs with potential gastrointestinal toxicity among continuous users of non-steroidal anti-inflammatory drugs. Eur J Clin Pharmacol. Jul. 2005;61(5-6):425-31. X-4. [pmid: 15952021].
1000 Helin-Salmivaara A, Klaukka T, Huupponen R. Heavy users of non-steroidal anti-inflammatory drugs: a nationwide prescription database study in Finland. Eur J Clin Pharmacol. Sep. 2003;59(5-6):477-82. X-3, X-4. [pmid: 12937872].
1001 Helin-Salmivaara A, Saarelainen S, Gronroos JM, et al. Risk of upper gastrointestinal events with the use of various NSAIDs: a case-control study in a general population. Scand J Gastroenterol. Aug. 2007;42(8):923-32. X-4. [pmid: 17613921].
1002 Helin-Salmivaara A, Virtanen A, Vesalainen R, et al. NSAID use and the risk of hospitalization for first myocardial infarction in the general population: a nationwide case-control study from Finland. Eur Heart J. Jul. 2006;27(14):1657-63. X-4. [pmid: 16731535].
1003 Heliovaara-Peippo S, Halmesmaki K, Hurskainen R, et al. The effect of hysterectomy or levonorgestrel-releasing intrauterine system on lower urinary tract symptoms: a 10-year follow-up study of a randomised trial. BJOG. Apr. 2010;117(5):602-9. X-2. [pmid: 20156209].
1004 Heliovaara-Peippo S, Oksjoki R, Halmesmaki K, et al. The effect of hysterectomy or levonorgestrel-releasing intrauterine system on cardiovascular disease risk factors in menorrhagia patients: a 10-year follow-up of a randomised trial. Maturitas. Aug. 2011;69(4):354-8. X-2, X-4. [pmid: 21684096].
1005 Helsper CW, Smeets HM, Numans ME, et al. Trends and determinants of adequate gastroprotection in patients chronically using NSAIDs. Pharmacoepidemiol Drug Saf. Sep. 2009;18(9):800-6. X-4. [pmid: 19572313].
1006 Hemmelgarn B, Levesque LE, Suissa S. Antidiabetic drug use and the risk of motor vehicle crash in the elderly. Can J Clin Pharmacol. Winter. 2006;13(1):e112-20. X-7. [pmid: 16585812].
1007 Henderson SO, Swadron S, Newton E. Comparison of intravenous ketorolac and meperidine in the treatment of biliary colic. J Emerg Med. Oct. 2002;23(3):237-41. X-2, X-4. [pmid: 12426013].
1008 Hendricks SK, Smith JR, Moore DE, et al. Oligohydramnios associated with prostaglandin synthetase inhibitors in preterm labour. Br J Obstet Gynaecol. Apr. 1990;97(4):312-6. X-2, X-4. [pmid: 2340255].
1009 Henker J, Muller S, Laass MW, et al. Probiotic Escherichia coli Nissle 1917 (EcN) for successful remission maintenance of ulcerative colitis in children and adolescents: an open-label pilot study. Z Gastroenterol. Sep. 2008;46(9):874-5. X-2, X-3, X-4. [pmid: 18810672].
1010 Hennekens CH, Borzak S. Cyclooxygenase-2 inhibitors and most traditional nonsteroidal anti-inflammatory drugs cause similar moderately increased risks of cardiovascular disease. J Cardiovasc Pharmacol Ther. Mar. 2008;13(1):41-50. X-1, X-2, X-3, X-4. [pmid: 18287589].
1011 Hennessy S, Kinman JL, Berlin JA, et al. Lack of hepatotoxic effects of parenteral ketorolac in the hospital setting. Arch Intern Med. Nov. 24. 1997;157(21):2510-4. X-4. [pmid: 9385304].
1012 Henriksson AE, Nilsson TK, Bergavist D. Bleeding time and concentrations of von Willebrand factor in patients with acute upper gastrointestinal bleeding. Eur J Surg. Aug. 1996;162(8):627-31. X-2, X-3, X-4. [pmid: 8891620].
1013 Henriksson P, Blomback M, Bratt G, et al. Effects of oestrogen therapy and orchidectomy on coagulation and prostanoid synthesis in patients with prostatic cancer. Med Oncol Tumor Pharmacother. 1989;6(3):219-25. X-2, X-4. [pmid: 2515399].
1014 Henriksson P, Edhag O, Eriksson A, et al. Patients at high risk of cardiovascular complications in oestrogen treatment of prostatic cancer. Br J Urol. Feb. 1989;63(2):186-90. X-2, X-6. [pmid: 2649197].
1015 Henry D, Dobson A, Turner C. Variability in the risk of major gastrointestinal complications from nonaspirin nonsteroidal anti-inflammatory drugs. Gastroenterology. Oct. 1993;105(4):1078-88. X-4. [pmid: 8405852].
1016 Henry D, Page J, Whyte I, et al. Consumption of non-steroidal anti-inflammatory drugs and the development of functional renal impairment in elderly subjects. Results of a case-control study. Br J Clin Pharmacol. Jul. 1997;44(1):85-90. X-2. [pmid: 9241101].
1017 Henry DA. Epidemiological assessment of the association between NSAIDS and peptic ulcer complications. Agents Actions Suppl. 1988;24:85-94. X-1. [pmid: 3263760].
1018 Henshaw C, Foreman D, Belcher J, et al. Can one induce premenstrual symptomatology in women with prior hysterectomy and bilateral oophorectomy?. J Psychosom Obstet Gynaecol. Mar. 1996;17(1):21-8. X-2, X-4. [pmid: 8860883].
1019 Henz S, Maeder MT, Huber S, et al. Influence of drugs and comorbidity on serum potassium in 15 000 consecutive hospital admissions. Nephrol Dial Transplant. Dec. 2008;23(12):3939-45. X-4. [pmid: 18614817].
1020 Heresbach D, Raoul JL, Bretagne JF, et al. Helicobacter pylori: a risk and severity factor of non-steroidal anti-inflammatory drug induced gastropathy. Gut. Dec. 1992;33(12):1608-11. X-2, X-3, X-4. [pmid: 1487160].
1021 Herings RM, Goettsch WG. Inadequate prevention of NSAID-induced gastrointestinal events. Ann Pharmacother. May. 2004;38(5):760-3. X-4. [pmid: 15031416].
1022 Hermansson M, Ekedahl A, Ranstam J, et al. Decreasing incidence of peptic ulcer complications after the introduction of the proton pump inhibitors, a study of the Swedish population from 1974-2002. BMC Gastroenterol. 2009;9:25. X-4. [pmid: 19379513].
1023 Hernan MA, Logroscino G, Garcia Rodriguez LA. Nonsteroidal anti-inflammatory drugs and the incidence of Parkinson disease. Neurology. Apr. 11. 2006;66(7):1097-9. X-4. [pmid: 16606925].
1024 Hernandez-Diaz S, Garcia Rodriguez LA. Cardioprotective aspirin users and their excess risk of upper gastrointestinal complications. BMC Med. 2006;4:22. X-3, X-4. [pmid: 16987411].
1025 Hernandez-Diaz S, Rodriguez LA. Steroids and risk of upper gastrointestinal complications. Am J Epidemiol. Jun. 1. 2001;153(11):1089-93. X-4. [pmid: 11390328].
1026 Herrera JA, Gonzalez M. Comparative evaluation of the effectiveness and tolerability of nimesulide versus rofecoxib taken once a day in the treatment of patients with knee osteoarthritis. Am J Ther. Nov-Dec. 2003;10(6):468-72. X-2, X-3, X-4. [pmid: 14624289].
1027 Herth FJ, Becker HD, Ernst A. Aspirin does not increase bleeding complications after transbronchial biopsy. Chest. Oct. 2002;122(4):1461-4. X-2, X-4. [pmid: 12377879].
1028 Hettinger ME, Gill DJ, Robin JB, et al. Evaluation of diclofenac sodium 0.1% ophthalmic solution in the treatment of ocular symptoms after bilateral radial keratotomy. Cornea. Jul. 1997;16(4):406-13. X-3, X-4. [pmid: 9220237].
1029 Heuser P, Tonga K, Hopkins R, et al. Specific oral contraceptive use and venous thromboembolism resulting in hospital admission. N Z Med J. Nov. 26. 2004;117(1206):U1176. X-2, X-4. [pmid: 15570345].
1030 Hickey M, Dwarte D, Fraser IS. Superficial endometrial vascular fragility in Norplant users and in women with ovulatory dysfunctional uterine bleeding. Hum Reprod. Jul. 2000;15(7):1509-14. X-2, X-3, X-4. [pmid: 10875858].
1031 Hickey M, Fraser IS. Surface vascularization and endometrial appearance in women with menorrhagia or using levonorgestrel contraceptive implants. Implications for the mechanisms of breakthrough bleeding. Hum Reprod. Sep. 2002;17(9):2428-34. X-2, X-3, X-4. [pmid: 12202436].
1032 Hickok DE, Hollenbach KA, Reilley SF, et al. The association between decreased amniotic fluid volume and treatment with nonsteroidal anti-inflammatory agents for preterm labor. Am J Obstet Gynecol. Jun. 1989;160(6):1525-30. discussion 30-1. X-2, X-4. [pmid: 2660576].
1033 Hidalgo M, Bahamondes L, Perrotti M, et al. Bleeding patterns and clinical performance of the levonorgestrel-releasing intrauterine system (Mirena) up to two years. Contraception. Feb. 2002;65(2):129-32. X-2. [pmid: 11927115].
1034 Higashi N, Taniguchi M, Mita H, et al. Clinical features of asthmatic patients with increased urinary leukotriene E4 excretion (hyperleukotrienuria): Involvement of chronic hyperplastic rhinosinusitis with nasal polyposis. J Allergy Clin Immunol. Feb. 2004;113(2):277-83. X-2, X-3, X-4. [pmid: 14767442].
1035 Higashi N, Taniguchi M, Mita H, et al. A comparative study of eicosanoid concentrations in sputum and urine in patients with aspirin-intolerant asthma. Clin Exp Allergy. Oct. 2002;32(10):1484-90. X-3, X-4. [pmid: 12372129].
1036 Higham CE, Chung TT, Lawrance J, et al. Long-term experience of pegvisomant therapy as a treatment for acromegaly. Clin Endocrinol (Oxf). Jul. 2009;71(1):86-91. X-2, X-4. [pmid: 19018786].
1037 Hilditch JR, Lewis J, Ross AH, et al. A comparison of the effects of oral conjugated equine estrogen and transdermal estradiol-17 beta combined with an oral progestin on quality of life in postmenopausal women. Maturitas. Jul. 1996;24(3):177-84. X-2, X-4. [pmid: 8844631].
1038 Hill GA, Wheeler JM. Incidence of breakthrough bleeding during oral contraceptive therapy. J Reprod Med. Apr. 1991;36(4 Suppl):334-9. X-4. [pmid: 2046082].
1039 Hill J, Bird H. Patient knowledge and misconceptions of osteoarthritis assessed by a validated self-completed knowledge questionnaire (PKQ-OA). Rheumatology (Oxford). May. 2007;46(5):796-800. X-2, X-3, X-4. [pmid: 17178737].
1040 Hillman AL, Bloom BS. Economic effects of prophylactic use of misoprostol to prevent gastric ulcer in patients taking nonsteroidal anti-inflammatory drugs. Arch Intern Med. Sep. 1989;149(9):2061-5. X-3, X-4. [pmid: 2505706].
1041 Hippisley-Cox J, Coupland C. Risk of myocardial infarction in patients taking cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs: population based nested case-control analysis. BMJ. Jun. 11. 2005;330(7504):1366. X-4. [pmid: 15947398].
1042 Hippisley-Cox J, Coupland C, Logan R. Risk of adverse gastrointestinal outcomes in patients taking cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs: population based nested case-control analysis. BMJ. Dec. 3. 2005;331(7528):1310-6. X-4. [pmid: 16322018].
1043 Hirneiss C, Neubauer AS, Kampik A, et al. Comparison of prednisolone 1%, rimexolone 1% and ketorolac tromethamine 0.5% after cataract extraction: a prospective, randomized, double-masked study. Graefes Arch Clin Exp Ophthalmol. Aug. 2005;243(8):768-73. X-2, X-4. [pmid: 15756571].
1044 Hite RC, Bannemerschult R, Fox-Kuchenbecker P, et al. Large observational trial of a new low-dose oral contraceptive containing 20 micrograms ethinylestradiol and 100 micrograms levonorgestrel (Miranova) in Germany. Eur J Contracept Reprod Health Care. Mar. 1999;4(1):7-13. X-4. [pmid: 10367190].
1045 Ho PC, Kwan MS. A prospective randomized comparison of levonorgestrel with the Yuzpe regimen in post-coital contraception. Hum Reprod. Mar. 1993;8(3):389-92. X-2, X-4. [pmid: 8473453].
1046 Hochain P, Berkelmans I, Czernichow P, et al. Which patients taking non-aspirin non-steroidal anti-inflammatory drugs bleed? A case-control study. Eur J Gastroenterol Hepatol. May. 1995;7(5):419-26. X-2, X-3, X-4. [pmid: 7614104].
1047 Hodis HN, Mack WJ, Azen SP, et al. Hormone therapy and the progression of coronary-artery atherosclerosis in postmenopausal women. N Engl J Med. Aug. 7. 2003;349(6):535-45. X-2, X-4. [pmid: 12904518].
1048 Hoer A, Gothe H, Schiffhorst G, et al. Comparison of the effects of diclofenac or other non-steroidal anti-inflammatory drugs (NSAIDs) and diclofenac or other NSAIDs in combination with proton pump inhibitors (PPI) on hospitalisation due to peptic ulcer disease. Pharmacoepidemiol Drug Saf. Aug. 2007;16(8):854-8. X-4. [pmid: 17323403].
1049 Hogan DB, Campbell NR, Crutcher R, et al. Prescription of nonsteroidal anti-inflammatory drugs for elderly people in Alberta. CMAJ. Aug. 1. 1994;151(3):315-22. X-4, X-7. [pmid: 8039085].
1050 Hoibraaten E, Mowinckel MC, de Ronde H, et al. Hormone replacement therapy and acquired resistance to activated protein C: results of a randomized, double-blind, placebo-controlled trial. Br J Haematol. Nov. 2001;115(2):415-20. X-2, X-4. [pmid: 11703344].
1051 Holdaway IM, Croxson MS, Ibbertson HK, et al. Cyproterone acetate as initial treatment and maintenance therapy for hirsutism. Acta Endocrinol (Copenh). Aug. 1985;109(4):522-9. X-2. [pmid: 2930987].
1052 Hollenz M, Stolte M, Leodolter A, et al. NSAID-associated dyspepsia and ulcers: a prospective cohort study in primary care. Dig Dis. 2006;24(1-2):189-94. X-2. [pmid: 16699277].
1053 Holma P. Long-term experience with Norplant contraceptive implants in Finland. Contraception. Mar. 1985;31(3):231-41. X-2, X-3, X-4. [pmid: 3922674].
1054 Holmberg L, Iversen OE, Rudenstam CM, et al. Increased risk of recurrence after hormone replacement therapy in breast cancer survivors. J Natl Cancer Inst. Apr. 2. 2008;100(7):475-82. X-2. [pmid: 18364505].
1055 Holt S, Rigoglioso V, Sidhu M, et al. Nonsteroidal antiinflammatory drugs and lower gastrointestinal bleeding. Dig Dis Sci. Sep. 1993;38(9):1619-23. X-2, X-4. [pmid: 8359073].
1056 Holt VL, Daling JR, McKnight B, et al. Functional ovarian cysts in relation to the use of monophasic and triphasic oral contraceptives. Obstet Gynecol. Apr. 1992;79(4):529-33. X-2, X-4. [pmid: 1553170].
1057 Holvoet J, Terriere L, Van Hee W, et al. Relation of upper gastrointestinal bleeding to non-steroidal anti-inflammatory drugs and aspirin: a case-control study. Gut. Jul. 1991;32(7):730-4. X-2. [pmid: 1855677].
1058 Homouda K. The effect on intrauterine device position and performance of a modified TCu380A insertion technique. Eur J Contracept Reprod Health Care. Mar. 2002;7(1):31-5. X-2, X-3, X-4. [pmid: 12041862].
1059 Hood HM, Wark C, Burgess PA, et al. Screening for Helicobacter pylori and nonsteroidal anti-inflammatory drug use in medicare patients hospitalized with peptic ulcer disease. Arch Intern Med. Jan. 25. 1999;159(2):149-54. X-3, X-4. [pmid: 9927097].
1060 Hook EB. Cardiovascular birth defects and prenatal exposure to female sex hormones: a reevaluation of data reanalysis from a large prospective study. Teratology. Mar. 1994;49(3):162-6. X-4. [pmid: 8059421].
1061 Hopkins C, Browne JP, Slack R, et al. The Lund-Mackay staging system for chronic rhinosinusitis: how is it used and what does it predict?. Otolaryngol Head Neck Surg. Oct. 2007;137(4):555-61. X-3, X-4. [pmid: 17903570].
1062 Hoppe G. Progestins and oral contraceptive-induced lipoprotein changes: a prospective study. Contraception. Mar. 1987;35(3):299-305. X-1. [pmid: 2956056].
1063 Hoppu K, Kettunen K, Remes R. Maternal drug treatment and human milk banking. Int J Clin Pharmacol Ther. Sep. 1994;32(9):488-90. X-2, X-3, X-4. [pmid: 7820332].
1064 Horackova M, Charvat J, Hasa J, et al. Life-threatening renal failure caused by vasomotor nephropathy associated with nonsteroidal anti-inflammatory drugs. Int J Clin Pharmacol Res. 2004;24(4):117-22. X-2, X-4. [pmid: 15754916].
1065 Horbach SJ, Lopes RD, da CGJC, et al. Naproxen as prophylaxis against atrial fibrillation after cardiac surgery: the NAFARM randomized trial. Am J Med. Nov. 2011;124(11):1036-42. X-2, X-3. [pmid: 22017782].
1066 Horlocker TT, Bajwa ZH, Ashraf Z, et al. Risk assessment of hemorrhagic complications associated with nonsteroidal antiinflammatory medications in ambulatory pain clinic patients undergoing epidural steroid injection. Anesth Analg. Dec. 2002;95(6):1691-7. table of contents. X-2, X-4. [pmid: 12456441].
1067 Horn PL, Wrona S, Beebe AC, et al. A retrospective quality improvement study of ketorolac use following spinal fusion in pediatric patients. Orthop Nurs. Sep-Oct. 2010;29(5):342-3. X-2, X-3, X-4. [pmid: 20856090].
1068 Horowitz J, Kukora JS, Ritchie WP Jr. All perforated ulcers are not alike. Ann Surg. Jun. 1989;209(6):693-6. discussion 6-7. X-2, X-3, X-4. [pmid: 2730181].
1069 Horsdal HT, Sondergaard F, Johnsen SP, et al. Antidiabetic treatments and risk of hospitalisation with myocardial infarction: a nationwide case-control study. Pharmacoepidemiol Drug Saf. Apr. 2011;20(4):331-7. X-3. [pmid: 21442682].
1070 Hosono S, Ohno T, Kimoto H, et al. Reduction in blood glucose values following indomethacin therapy for patent ductus arteriosus. Pediatr Int. Oct. 1999;41(5):525-8. X-2, X-4. [pmid: 10530066].
1071 Hosono S, Ohono T, Kimoto H, et al. Preventive management of hypoglycemia in very low-birthweight infants following indomethacin therapy for patent ductus arteriosus. Pediatr Int. Oct. 2001;43(5):465-8. X-2, X-3, X-4. [pmid: 11737706].
1072 Houck CS, Wilder RT, McDermott JS, et al. Safety of intravenous ketorolac therapy in children and cost savings with a unit dosing system. J Pediatr. Aug. 1996;129(2):292-6. X-4. [pmid: 8765630].
1073 Hov GG, Skjeldestad FE, Hilstad T. Use of IUD and subsequent fertility--follow-up after participation in a randomized clinical trial. Contraception. Feb. 2007;75(2):88-92. X-2, X-3, X-4. [pmid: 17241835].
1074 Howard BV, Hsia J, Ouyang P, et al. Postmenopausal hormone therapy is associated with atherosclerosis progression in women with abnormal glucose tolerance. Circulation. Jul. 13. 2004;110(2):201-6. X-2. [pmid: 15226212].
1075 Howard RL, Avery AJ, Howard PD, et al. Investigation into the reasons for preventable drug related admissions to a medical admissions unit: observational study. Qual Saf Health Care. Aug. 2003;12(4):280-5. X-4. [pmid: 12897361].
1076 Hoyo C, Cousins DS, Bisgrove EZ, et al. Depo medroxyprogesterone acetate (DMPA) and combined oral contraceptives and cervical carcinoma in-situ in women aged 50 years and under. West Indian Med J. Dec. 2004;53(6):406-12. X-2. [pmid: 15816269].
1077 Hritz I, Kuester D, Vieth M, et al. Secretory leukocyte protease inhibitor expression in various types of gastritis: a specific role of Helicobacter pylori infection. Eur J Gastroenterol Hepatol. Mar. 2006;18(3):277-82. X-2, X-3, X-4. [pmid: 16462541].
1078 Hsia J, Otvos JD, Rossouw JE, et al. Lipoprotein particle concentrations may explain the absence of coronary protection in the women's health initiative hormone trials. Arterioscler Thromb Vasc Biol. Sep. 2008;28(9):1666-71. X-4. [pmid: 18599797].
1079 Hsia J, Simon JA, Lin F, et al. Peripheral arterial disease in randomized trial of estrogen with progestin in women with coronary heart disease: the Heart and Estrogen/Progestin Replacement Study. Circulation. Oct. 31. 2000;102(18):2228-32. X-7. [pmid: 11056097].
1080 Hsiang KW, Chen TS, Lin HY, et al. Incidence and possible risk factors for clinical upper gastrointestinal events in patients taking selective cyclooxygenase-2 inhibitors: A prospective, observational, cohort study in Taiwan. Clin Ther. Jul. 2010;32(7):1294-303. X-2, X-4. [pmid: 20678677].
1081 Hsiao FY, Huang WF, Wen YW, et al. Thiazolidinediones and cardiovascular events in patients with type 2 diabetes mellitus: a retrospective cohort study of over 473,000 patients using the National Health Insurance database in Taiwan. Drug Saf. 2009;32(8):675-90. X-3. [pmid: 19591532].
1082 Hsiao FY, Tsai YW, Wen YW, et al. Relationship between cumulative dose of thiazolidinediones and clinical outcomes in type 2 diabetic patients with history of heart failure: a population-based cohort study in Taiwan. Pharmacoepidemiol Drug Saf. Aug. 2010;19(8):786-91. X-2, X-4. [pmid: 20607752].
1083 Hsu PI, Lai KH, Lo GH, et al. Risk factors for ulcer development in patients with non-ulcer dyspepsia: a prospective two year follow up study of 209 patients. Gut. Jul. 2002;51(1):15-20. X-2, X-3. [pmid: 12077085].
1084 Hsu PI, Lai KH, Tseng HH, et al. Risk factors for presentation with bleeding in patients with Helicobacter pylori-related peptic ulcer diseases. J Clin Gastroenterol. Jun. 2000;30(4):386-91. X-2, X-3, X-4. [pmid: 10875466].
1085 Huang ES, Strate LL, Ho WW, et al. Long-term use of aspirin and the risk of gastrointestinal bleeding. Am J Med. May. 2011;124(5):426-33. X-4. [pmid: 21531232].
1086 Huang WF, Hsiao FY, Wen YW, et al. Cardiovascular events associated with the use of four nonselective NSAIDs (etodolac, nabumetone, ibuprofen, or naproxen) versus a cyclooxygenase-2 inhibitor (celecoxib): a population-based analysis in Taiwanese adults. Clin Ther. Nov. 2006;28(11):1827-36. X-4. [pmid: 17213003].
1087 Huang YC, Tsai SK, Huang CH, et al. Intravenous tenoxicam reduces uterine cramps after Cesarean delivery. Can J Anaesth. Apr. 2002;49(4):384-7. X-2, X-3, X-4. [pmid: 11927478].
1088 Hubacher D, Chen PL, Park S. Side effects from the copper IUD: do they decrease over time?. Contraception. May. 2009;79(5):356-62. X-4. [pmid: 19341847].
1089 Hubacher D, Fortney J. Follow-up visits after IUD insertion. Are more better?. J Reprod Med. Sep. 1999;44(9):801-6. X-4. [pmid: 10509305].
1090 Hubacher D, Goco N, Gonzalez B, et al. Factors affecting continuation rates of DMPA. Contraception. Dec. 1999;60(6):345-51. X-2, X-3, X-4. [pmid: 10715369].
1091 Hubacher D, Lara-Ricalde R, Taylor DJ, et al. Use of copper intrauterine devices and the risk of tubal infertility among nulligravid women. N Engl J Med. Aug. 23. 2001;345(8):561-7. X-4. [pmid: 11529209].
1092 Hubbard R, Venn A, Smith C, et al. Exposure to commonly prescribed drugs and the etiology of cryptogenic fibrosing alveolitis: a case-control study. Am J Respir Crit Care Med. Mar. 1998;157(3 Pt 1):743-7. X-2, X-4. [pmid: 9517585].
1093 Hudic I, Szekeres-Bartho J, Fatusic Z, et al. Dydrogesterone supplementation in women with threatened preterm delivery--the impact on cytokine profile, hormone profile, and progesterone-induced blocking factor. J Reprod Immunol. Dec. 2011;92(1-2):103-7. X-2. [pmid: 22032897].
1094 Hudson M, Rahme E, Richard H, et al. Risk of congestive heart failure with nonsteroidal antiinflammatory drugs and selective Cyclooxygenase 2 inhibitors: a class effect?. Arthritis Rheum. Apr. 15. 2007;57(3):516-23. X-7. [pmid: 17394181].
1095 Hudson M, Richard H, Pilote L. Differences in outcomes of patients with congestive heart failure prescribed celecoxib, rofecoxib, or non-steroidal anti- inflammatory drugs: population based study. BMJ. Jun. 11. 2005;330(7504):1370. X-4, X-7. [pmid: 15947399].
1096 Huerta C, Castellsague J, Varas-Lorenzo C, et al. Nonsteroidal anti-inflammatory drugs and risk of ARF in the general population. Am J Kidney Dis. Mar. 2005;45(3):531-9. X-4. [pmid: 15754275].
1097 Huerta C, Varas-Lorenzo C, Castellsague J, et al. Non-steroidal anti-inflammatory drugs and risk of first hospital admission for heart failure in the general population. Heart. Nov. 2006;92(11):1610-5. X-7. [pmid: 16717069].
1098 Hug H, Bagatto D, Dannecker R, et al. ADRIS - The Adverse Drug Reactions Information Scheme. Clin Neuropharmacol. Jan-Feb. 2004;27(1):44-8. X-1. [pmid: 15090937].
1099 Huggins GR. IUD use and unexplained vaginal bleeding. Obstet Gynecol. Oct. 1981;58(4):409-16. X-4. [pmid: 7279336].
1100 Hui CK, Lai KC, Yuen MF, et al. Does withholding aspirin for one week reduce the risk of post-sphincterotomy bleeding?. Aliment Pharmacol Ther. May. 2002;16(5):929-36. X-2, X-4. [pmid: 11966501].
1101 Huic M, Mucolic V, Vrhovac B, et al. Adverse drug reactions resulting in hospital admission. Int J Clin Pharmacol Ther. Dec. 1994;32(12):675-82. X-4. [pmid: 7881707].
1102 Hulley S, Grady D, Bush T, et al. Randomized trial of estrogen plus progestin for secondary prevention of coronary heart disease in postmenopausal women. Heart and Estrogen/progestin Replacement Study (HERS) Research Group. JAMA. Aug. 19. 1998;280(7):605-13. X-7. [pmid: 9718051].
1103 Hurskainen R, Teperi J, Rissanen P, et al. Quality of life and cost-effectiveness of levonorgestrel-releasing intrauterine system versus hysterectomy for treatment of menorrhagia: a randomised trial. Lancet. Jan. 27. 2001;357(9252):273-7. X-2. [pmid: 11214131].
1104 Hussain N, Alsulaiman R, Burtin P, et al. The safety of endoscopic sphincterotomy in patients receiving antiplatelet agents: a case-control study. Aliment Pharmacol Ther. Mar. 1. 2007;25(5):579-84. X-2, X-4. [pmid: 17305758].
1105 Hwang H, Murphy JJ, Gow KW, et al. Are localized intestinal perforations distinct from necrotizing enterocolitis?. J Pediatr Surg. May. 2003;38(5):763-7. X-2, X-3, X-4. [pmid: 12720189].
1106 Hynes MC, Calder P, Rosenfeld P, et al. The use of tranexamic acid to reduce blood loss during total hip arthroplasty: an observational study. Ann R Coll Surg Engl. Mar. 2005;87(2):99-101. X-2, X-3, X-4. [pmid: 15826417].
1107 Hyvarinen H, Salmenkyla S, Sipponen P. Helicobacter pylori-negative duodenal and pyloric ulcer: role of NSAIDs. Digestion. 1996;57(5):305-9. X-2, X-3, X-4. [pmid: 8886573].
1108 Iamandescu IB. NSAIDs-induced asthma: peculiarities related to background and association with other drug or non-drugs etiological agents. Allergol Immunopathol (Madr). Nov-Dec. 1989;17(6):285-90. X-2, X-4. [pmid: 2635829].
1109 Iannucci TA, Besinger RE, Fisher SG, et al. Effect of dual tocolysis on the incidence of severe intraventricular hemorrhage among extremely low-birth-weight infants. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):1043-6. X-2, X-4. [pmid: 8885773].
1110 Ibanez L, Morlans M, Vidal X, et al. Case-control study of regular analgesic and nonsteroidal anti-inflammatory use and end-stage renal disease. Kidney Int. Jun. 2005;67(6):2393-8. X-4. [pmid: 15882284].
1111 Ibanez L, Vidal X, Ballarin E, et al. Population-based drug-induced agranulocytosis. Arch Intern Med. Apr. 25. 2005;165(8):869-74. X-4. [pmid: 15851637].
1112 Ibanez-Cuevas V, Lopez-Briz E, Guardiola-Chorro MT. Pharmacist intervention reduces gastropathy risk in patients using NSAIDs. Pharm World Sci. Dec. 2008;30(6):947-54. X-4. [pmid: 18932013].
1113 Ibraheim M, Ikomi A. An evaluation of troublesome inter-menstrual bleeding in menorrhagic users of the LNG-IUS. J Obstet Gynaecol. May. 2005;25(4):384-5. X-2. [pmid: 16091327].
1114 Idilman R, Bektas M, Cinar K, et al. The characteristics and clinical outcome of drug-induced liver injury: a single-center experience. J Clin Gastroenterol. Jul. 2010;44(6):e128-32. X-4. [pmid: 20551776].
1115 Iglehart IW 3rd, Edlow DW, Mills L Jr., et al. The presence of Campylobacter pylori in nonsteroidal antiinflammatory drug associated gastritis. J Rheumatol. May. 1989;16(5):599-603. X-2, X-3, X-4. [pmid: 2754664].
1116 Iitaka K, Ishidate T, Hojo M, et al. Idiopathic membranoproliferative glomerulonephritis in Japanese children. Pediatr Nephrol. Jun. 1995;9(3):272-7. X-2, X-3, X-4. [pmid: 7632509].
1117 Ike RW, Arnold WJ, Rothschild EW, et al. Tidal irrigation versus conservative medical management in patients with osteoarthritis of the knee: a prospective randomized study. Tidal Irrigation Cooperating Group. J Rheumatol. May. 1992;19(5):772-9. X-2, X-4. [pmid: 1613709].
1118 Ikechebelu JI, Onwusulu DN. Missing IUD string: prevalence, diagnosis and retrieval in Nnewi, Nigeria. Niger J Med. Jul-Sep. 2009;18(3):303-5. X-2, X-4. [pmid: 20120651].
1119 Ilkhanoff L, Lewis JD, Hennessy S, et al. Potential limitations of electronic database studies of prescription non-aspirin non-steroidal anti-inflammatory drugs (NANSAIDs) and risk of myocardial infarction (MI). Pharmacoepidemiol Drug Saf. Aug. 2005;14(8):513-22. X-3, X-4. [pmid: 15959879].
1120 Imhof M, Epstein S, Ohmann C, et al. Poor late prognosis of bleeding peptic ulcer. Langenbecks Arch Surg. Sep. 2007;392(5):587-91. X-2, X-3, X-4. [pmid: 17632731].
1121 Imperiale TF, Horwitz RI. Scientific standards and the design of case-control research. Biomed Pharmacother. 1989;43(3):187-96. X-1, X-2, X-3, X-4. [pmid: 2775855].
1122 Inki P, Hurskainen R, Palo P, et al. Comparison of ovarian cyst formation in women using the levonorgestrel-releasing intrauterine system vs. hysterectomy. Ultrasound Obstet Gynecol. Oct. 2002;20(4):381-5. X-2. [pmid: 12383322].
1123 Inman WH. Prescription-event monitoring. A preliminary study of benoxaprofen and fenbufen. Acta Med Scand Suppl. 1984;683:119-26. X-1, X-4. [pmid: 6234753].
1124 Inoue M, Caldarone CA, Frndova H, et al. Safety and efficacy of ketorolac in children after cardiac surgery. Intensive Care Med. Sep. 2009;35(9):1584-92. X-2, X-4. [pmid: 19562323].
1125 Insua J, Mavros P, Hunsche E, et al. Exposure to nonsteroidal anti-inflammatory drugs among older adult patients hospitalized for peptic ulcer disease in Argentina: A case-control study. Am J Geriatr Pharmacother. Sep. 2006;4(3):251-9. X-2. [pmid: 17062326].
1126 Inzucchi SE, Masoudi FA, Wang Y, et al. Insulin-sensitizing antihyperglycemic drugs and mortality after acute myocardial infarction: insights from the National Heart Care Project. Diabetes Care. Jul. 2005;28(7):1680-9. X-7. [pmid: 15983320].
1127 Irani J, Ravery V, Pariente JL, et al. Effect of nonsteroidal anti-inflammatory agents and finasteride on prostate cancer risk. J Urol. Nov. 2002;168(5):1985-8. X-2. [pmid: 12394690].
1128 Irvine GA, Campbell-Brown MB, Lumsden MA, et al. Randomised comparative trial of the levonorgestrel intrauterine system and norethisterone for treatment of idiopathic menorrhagia. Br J Obstet Gynaecol. Jun. 1998;105(6):592-8. X-2, X-3, X-4. [pmid: 9647148].
1129 Ishikawa N, Fuchigami T, Matsumoto T, et al. Helicobacter pylori infection in rheumatoid arthritis: effect of drugs on prevalence and correlation with gastroduodenal lesions. Rheumatology (Oxford). Jan. 2002;41(1):72-7. X-2, X-3, X-4. [pmid: 11792883].
1130 Ishikawa S, Inaba T, Mizuno M, et al. Incidence of serious upper gastrointestinal bleeding in patients taking non-steroidal anti-inflammatory drugs in Japan. Acta Med Okayama. Feb. 2008;62(1):29-36. X-4. [pmid: 18323869].
1131 Isidro ML, Penin MA, Nemina R, et al. Metformin reduces thyrotropin levels in obese, diabetic women with primary hypothyroidism on thyroxine replacement therapy. Endocrine. Aug. 2007;32(1):79-82. X-2. [pmid: 17992605].
1132 Isik B, Arslan M, Ozsoylar O, et al. Effects of preoperative lornoxicam versus tramadol on postoperative pain and adverse effects in adult tonsillectomy patients. Agri. Jul. 2009;21(3):113-20. X-2, X-4. [pmid: 19780002].
1133 Istre O, Trolle B. Treatment of menorrhagia with the levonorgestrel intrauterine system versus endometrial resection. Fertil Steril. Aug. 2001;76(2):304-9. X-2. [pmid: 11476777].
1134 Itsekson A, Lazarov A, Cordoba M, et al. Premenstrual syndrome and associated skin diseases related to hypersensitivity to female sex hormones. J Reprod Med. Mar. 2004;49(3):195-9. X-2. [pmid: 15098889].
1135 Izumi K, Kadono Y, Shima T, et al. Ethinylestradiol improves prostate-specific antigen levels in pretreated castration-resistant prostate cancer patients. Anticancer Res. Dec. 2010;30(12):5201-5. X-2, X-3, X-4. [pmid: 21187513].
1136 Jackson-Northey K, Evans MF. Taking NSAIDs during pregnancy. Is it safe?. Can Fam Physician. Mar. 2002;48:483-5. X-1, X-4. [pmid: 11935712].
1137 Jacob A, Matiello M, Weinshenker BG, et al. Treatment of neuromyelitis optica with mycophenolate mofetil: retrospective analysis of 24 patients. Arch Neurol. Sep. 2009;66(9):1128-33. X-2, X-3, X-4. [pmid: 19752302].
1138 Jacob AN, Salinas K, Adams-Huet B, et al. Weight gain in type 2 diabetes mellitus. Diabetes Obes Metab. May. 2007;9(3):386-93. X-2, X-3, X-4. [pmid: 17391167].
1139 Jacobs P, Fransman D, Coghlan P. Comparative bioavailability of ferric polymaltose and ferrous sulphate in iron-deficient blood donors. J Clin Apher. 1993;8(2):89-95. X-2, X-3, X-4. [pmid: 8226711].
1140 Jain JK, Ota F, Mishell DR. Comparison of ovarian follicular activity during treatment with a monthly injectable contraceptive and a low-dose oral contraceptive. Contraception. Mar. 2000;61(3):195-8. X-2. [pmid: 10827333].
1141 Jallad RS, Bronstein MD. Optimizing medical therapy of acromegaly: beneficial effects of cabergoline in patients uncontrolled with long-acting release octreotide. Neuroendocrinology. 2009;90(1):82-92. X-2, X-3. [pmid: 19439914].
1142 James MW, Chen CM, Goddard WP, et al. Risk factors for gastrointestinal malignancy in patients with iron-deficiency anaemia. Eur J Gastroenterol Hepatol. Nov. 2005;17(11):1197-203. X-2, X-3, X-4. [pmid: 16215432].
1143 Jamison RN, Raymond SA, Slawsby EA, et al. Opioid therapy for chronic noncancer back pain. A randomized prospective study. Spine (Phila Pa 1976). Dec. 1. 1998;23(23):2591-600. X-2, X-4. [pmid: 9854758].
1144 Jankovic SM, Aleksic J, Rakovic S, et al. Nonsteroidal antiinflammatory drugs and risk of gastrointestinal bleeding among patients on hemodialysis. J Nephrol. Jul-Aug. 2009;22(4):502-7. X-2. [pmid: 19662606].
1145 Janssen M, Dijkmans BA, Lamers CB, et al. A gastroscopic study of the predictive value of risk factors for non-steroidal anti-inflammatory drug-associated ulcer disease in rheumatoid arthritis patients. Br J Rheumatol. May. 1994;33(5):449-54. X-2, X-3, X-4. [pmid: 8173849].
1146 Jarernsiripornkul N, Chaisrisawadsuk S, Chaiyakum A, et al. Patient self-reporting of potential adverse drug reactions to non-steroidal anti-inflammatory drugs in Thailand. Pharm World Sci. Oct. 2009;31(5):559-64. X-3, X-4. [pmid: 19575308].
1147 Jaspersen D, Labenz J, Willich SN, et al. Long-term clinical course of extra-oesophageal manifestations in patients with gastro-oesophageal reflux disease. A prospective follow-up analysis based on the ProGERD study. Dig Liver Dis. Apr. 2006;38(4):233-8. X-4. [pmid: 16413233].
1148 Jaszewski R. Frequency of gastroduodenal lesions in asymptomatic patients on chronic aspirin or nonsteroidal antiinflammatory drug therapy. J Clin Gastroenterol. Feb. 1990;12(1):10-3. X-2. [pmid: 2303676].
1149 Jaszewski R, Calzada R, Dhar R. Persistence of gastric ulcers caused by plain aspirin or nonsteroidal antiinflammatory agents in patients treated with a combination of cimetidine, antacids, and enteric-coated aspirin. Dig Dis Sci. Sep. 1989;34(9):1361-4. X-2, X-3, X-4. [pmid: 2766902].
1150 Jaszewski R, Crane SA. The effect of 15(R)-15-methyl prostaglandin E2 (Arbacet) on the healing of aspirin or nonsteroidal antiinflammatory drug-induced gastric mucosal lesions: an endoscopic study. Am J Gastroenterol. Dec. 1987;82(12):1271-4. X-2, X-3, X-4. [pmid: 3318402].
1151 Jeanfils S, Joly P, Young P, et al. Indomethacin treatment of eighteen patients with Sweet's syndrome. J Am Acad Dermatol. Mar. 1997;36(3 Pt 1):436-9. X-2, X-3, X-4. [pmid: 9091476].
1152 Jedel E, Labrie F, Oden A, et al. Impact of electro-acupuncture and physical exercise on hyperandrogenism and oligo/amenorrhea in women with polycystic ovary syndrome: a randomized controlled trial. Am J Physiol Endocrinol Metab. Jan. 2011;300(1):E37-45. X-2, X-4. [pmid: 20943753].
1153 Jeffries MA, Scheiman JM, Fendrick AM. Helicobacter pylori eradication: kill the bug and save the pill?. Am J Gastroenterol. Jul. 1998;93(7):1183-4. X-1, X-2. [pmid: 9672364].
1154 Jenner PN. A 12-month postmarketing surveillance study of nabumetone. A preliminary report. Drugs. Suppl 5. 1990;40:80-6. X-4. [pmid: 2081502].
1155 Jenq CC, Tian YC, Wu HH, et al. Effectiveness of oral and intravenous iron therapy in haemodialysis patients. Int J Clin Pract. Mar. 2008;62(3):416-22. X-2, X-3, X-4. [pmid: 17511797].
1156 Jensen JT, Parke S, Mellinger U, et al. Effective treatment of heavy menstrual bleeding with estradiol valerate and dienogest: A randomized controlled trial. Obstetrics and Gynecology. 2011;117(4):777-87. X-2, X-3, X-4. [pmid: 21422847].
1157 Jeon SB, Song HS, Kim BJ, et al. Biochemical aspirin resistance and recurrent lesions in patients with acute ischemic stroke. Eur Neurol. 2010;64(1):51-7. X-2, X-3, X-4. [pmid: 20606449].
1158 Jespersen J, Endrikat J, Dusterberg B, et al. A 1-year study to compare the hemostatic effects of oral contraceptive containing 20 microg of ethinylestradiol and 100 microg of levonorgestrel with 30 microg of ethinylestradiol and 100 microg of levonorgestrel. Contraception. Aug. 2005;72(2):98-104. X-2, X-4. [pmid: 16022847].
1159 Jeyakumar A, Brickman TM, Williamson ME, et al. Nonsteroidal anti-inflammatory drugs and postoperative bleeding following adenotonsillectomy in pediatric patients. Arch Otolaryngol Head Neck Surg. Jan. 2008;134(1):24-7. X-2, X-4. [pmid: 18209131].
1160 Jick H, Jick SS, Gurewich V, et al. Risk of idiopathic cardiovascular death and nonfatal venous thromboembolism in women using oral contraceptives with differing progestagen components. Lancet. Dec. 16. 1995;346(8990):1589-93. X-4. [pmid: 7500750].
1161 Jick H, Kaye JA, Russmann S, et al. Nonsteroidal antiinflammatory drugs and acute myocardial infarction in patients with no major risk factors. Pharmacotherapy. Oct. 2006;26(10):1379-87. X-4. [pmid: 16999647].
1162 Jick H, Kaye JA, Vasilakis-Scaramozza C, et al. Risk of venous thromboembolism among users of third generation oral contraceptives compared with users of oral contraceptives with levonorgestrel before and after 1995: cohort and case-control analysis. BMJ. Nov. 11. 2000;321(7270):1190-5. X-4. [pmid: 11073511].
1163 Jick H, Myers MW, Dean AD. The risk of sulfasalazine- and mesalazine-associated blood disorders. Pharmacotherapy. Mar-Apr. 1995;15(2):176-81. X-4. [pmid: 7624265].
1164 Jick S, Kaye JA, Li L, et al. Further results on the risk of nonfatal venous thromboembolism in users of the contraceptive transdermal patch compared to users of oral contraceptives containing norgestimate and 35 microg of ethinyl estradiol. Contraception. Jul. 2007;76(1):4-7. X-2, X-4. [pmid: 17586129].
1165 Jick SS. The risk of gastrointestinal bleed, myocardial infarction, and newly diagnosed hypertension in users of meloxicam, diclofenac, naproxen, and piroxicam. Pharmacotherapy. Jul. 2000;20(7):741-4. X-4. [pmid: 10907963].
1166 Jick SS, Hagberg KW, Hernandez RK, et al. Postmarketing study of ORTHO EVRA and levonorgestrel oral contraceptives containing hormonal contraceptives with 30 mcg of ethinyl estradiol in relation to nonfatal venous thromboembolism. Contraception. Jan. 2010;81(1):16-21. X-4. [pmid: 20004268].
1167 Jick SS, Hernandez RK. Risk of non-fatal venous thromboembolism in women using oral contraceptives containing drospirenone compared with women using oral contraceptives containing levonorgestrel: case-control study using United States claims data. BMJ. 2011;342:d2151. X-2, X-4. [pmid: 21511805].
1168 Jick SS, Jick H. Cerebral venous sinus thrombosis in users of four hormonal contraceptives: levonorgestrel-containing oral contraceptives, norgestimate-containing oral contraceptives, desogestrel-containing oral contraceptives and the contraceptive patch. Contraception. Oct. 2006;74(4):290-2. X-4. [pmid: 16982227].
1169 Jick SS, Jick H. The contraceptive patch in relation to ischemic stroke and acute myocardial infarction. Pharmacotherapy. Feb. 2007;27(2):218-20. X-4. [pmid: 17253912].
1170 Jick SS, Kaye JA, Russmann S, et al. Risk of nonfatal venous thromboembolism with oral contraceptives containing norgestimate or desogestrel compared with oral contraceptives containing levonorgestrel. Contraception. Jun. 2006;73(6):566-70. X-2. [pmid: 16730485].
1171 Jimoh AA. Complications of intrauterine contraceptive device (IUD) use at the University of Ilorin Teaching Hospital, Ilorin. Niger J Med. Jul-Sep. 2004;13(3):244-9. X-2. [pmid: 15532225].
1172 Jindabanjerd K, Taneepanichskul S. The use of levonorgestrel - IUD in the treatment of uterine myoma in Thai women. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S147-51. X-2, X-3, X-4. [pmid: 17726816].
1173 Jobanputra P, Amarasena R, Maggs F, et al. Hepatotoxicity associated with sulfasalazine in inflammatory arthritis: A case series from a local surveillance of serious adverse events. BMC Musculoskelet Disord. 2008;9:48. X-2, X-4. [pmid: 18405372].
1174 Jockheck M, Willms R, Volkmann R, et al. Prevention of periarticular heterotopic ossification after endoprosthetic hip joint replacement by means of diclofenac. Arch Orthop Trauma Surg. 1998;117(6-7):337-40. X-2, X-4. [pmid: 9709846].
1175 Joeres-Nguyen-Xuan TH, Boehm SK, Joeres L, et al. Survival of the probiotic Escherichia coli Nissle 1917 (EcN) in the gastrointestinal tract given in combination with oral mesalamine to healthy volunteers. Inflamm Bowel Dis. Feb. 2010;16(2):256-62. X-2, X-3, X-4. [pmid: 19637333].
1176 Johannes CB, Koro CE, Quinn SG, et al. The risk of coronary heart disease in type 2 diabetic patients exposed to thiazolidinediones compared to metformin and sulfonylurea therapy. Pharmacoepidemiol Drug Saf. May. 2007;16(5):504-12. X-2, X-4. [pmid: 17245800].
1177 Johansson JE, Andersson SO, Holmberg L, et al. Primary orchiectomy versus estrogen therapy in advanced prostatic cancer--a randomized study: results after 7 to 10 years of followup. J Urol. Mar. 1991;145(3):519-22. discussion 22-3. X-2, X-4. [pmid: 1997702].
1178 John BK, Arramraju S, Shalomov A, et al. Antiplatelet agents do not impact the hospital course in patients with gastrointestinal bleeding. J Clin Gastroenterol. Aug. 2011;45(7):583-9. X-2, X-4. [pmid: 21293292].
1179 Johnsen SP, Larsson H, Tarone RE, et al. Risk of hospitalization for myocardial infarction among users of rofecoxib, celecoxib, and other NSAIDs: a population-based case-control study. Arch Intern Med. May. 9. 2005;165(9):978-84. X-4. [pmid: 15883235].
1180 Johnsen SP, Pedersen L, Friis S, et al. Nonaspirin nonsteroidal anti-inflammatory drugs and risk of hospitalization for intracerebral hemorrhage: a population-based case-control study. Stroke. Feb. 2003;34(2):387-91. X-4. [pmid: 12574547].
1181 Johnsen SP, Sorensen HT, Mellemkjoer L, et al. Hospitalisation for upper gastrointestinal bleeding associated with use of oral anticoagulants. Thromb Haemost. Aug. 2001;86(2):563-8. X-4. [pmid: 11522004].
1182 Johnsen V, Borg G, Trang LE, et al. Auranofin (SK&F) in early rheumatoid arthritis: results from a 24-month double-blind, placebo-controlled study. Effect on clinical and biochemical assessments. Scand J Rheumatol. 1989;18(5):251-60. X-2, X-4. [pmid: 2688083].
1183 Johnson DE, Babaian RJ, Swanson DA, et al. Medical castration using megestrol acetate and minidose estrogen. Urology. May. 1988;31(5):371-4. X-2, X-3, X-4. [pmid: 3284149].
1184 Johnson JA, Majumdar SR, Simpson SH, et al. Decreased mortality associated with the use of metformin compared with sulfonylurea monotherapy in type 2 diabetes. Diabetes Care. Dec. 2002;25(12):2244-8. X-3. [pmid: 12453968].
1185 Johnson KC, Margolis KL, Espeland MA, et al. A prospective study of the effect of hypertension and baseline blood pressure on cognitive decline and dementia in postmenopausal women: the Women's Health Initiative Memory Study. J Am Geriatr Soc. Aug. 2008;56(8):1449-58. X-3, X-4. [pmid: 18637980].
1186 Johnson KH, Millard PS. Oral contraceptives and breast cancer. J Fam Pract. Oct. 1996;43(4):340-1. X-1, X-4. [pmid: 8874363].
1187 Johnson M, Krosnick A, Carson P, et al. A retrospective chart review of uncontrolled use of metformin as an add-on therapy in type 2 diabetes. Clin Ther. Jul-Aug. 1998;20(4):691-8. X-2, X-3, X-4. [pmid: 9737829].
1188 Johnson RL, Hemington-Gorse SJ, Dhital SK. Do cosmetic surgeons consider estrogen-containing drugs to be of significant risk in the development of thromboembolism?. Aesthetic Plast Surg. Sep. 2008;32(5):743-7. X-2, X-4. [pmid: 18446403].
1189 Johnson ST, Fueger JT, Gottschall JL. One center's experience: the serology and drugs associated with drug-induced immune hemolytic anemia--a new paradigm. Transfusion. Apr. 2007;47(4):697-702. X-2, X-3, X-4. [pmid: 17381629].
1190 Jones CW. A post-marketing surveillance study of Voltarol 75 mg SR in the primary care setting. Br J Clin Pract. Oct-Nov. 1996;50(7):390-5. X-3, X-4. [pmid: 9015913].
1191 Jonsson PE, Olsson AM, Petersson BA, et al. Intravenous indomethacin and oxycone-papaverine in the treatment of acute renal colic. A double-blind study. Br J Urol. May. 1987;59(5):396-400. X-2, X-3, X-4. [pmid: 3297230].
1192 Jordan HL, Bruinsma FJ, Thomson RJ, et al. Adolescent exposure to high-dose estrogen and subsequent effects on lactation. Reprod Toxicol. Nov-Dec. 2007;24(3-4):397-402. X-2, X-4. [pmid: 17531440].
1193 Jordan HL, Hopper JL, Thomson RJ, et al. Influence of high-dose estrogen exposure during adolescence on mammographic density for age in adulthood. Cancer Epidemiol Biomarkers Prev. Jan. 2010;19(1):121-9. X-2, X-3, X-4. [pmid: 20056630].
1194 Jorn LP, Lindstrand A, Toksvig-Larsen S. Tourniquet release for hemostasis increases bleeding. A randomized study of 77 knee replacements. Acta Orthop Scand. Jun. 1999;70(3):265-7. X-2, X-3, X-4. [pmid: 10429602].
1195 Juby A, Davis P. Psychological profiles of patients with upper gastrointestinal symptomatology induced by non-steroidal anti-inflammatory drugs. Ann Rheum Dis. Apr. 1991;50(4):211-3. X-2, X-3, X-4. [pmid: 2029202].
1196 Julkunen HA. Oral contraceptives in systemic lupus erythematosus: side-effects and influence on the activity of SLE. Scand J Rheumatol. 1991;20(6):427-33. X-2. [pmid: 1771400].
1197 Juurlink DN, Mamdani MM, Kopp A, et al. Drug-induced lithium toxicity in the elderly: a population-based study. J Am Geriatr Soc. May. 2004;52(5):794-8. X-2, X-4. [pmid: 15086664].
1198 Kabadi UM. United Kingdom prospective diabetes study: a different perspective. Endocr Pract. Jan-Feb. 2002;8(1):61-4. X-1. [pmid: 11939763].
1199 Kaimal N, Schofield J, Zaki A, et al. Effects of exenatide in poorly controlled type 2 diabetes. QJM. Apr. 2012;105(4):321-6. X-2, X-3. [pmid: 22056400].
1200 Kalaichelvan V, Maw AA, Singh K. Actinomyces in cervical smears of women using the intrauterine device in Singapore. Contraception. Apr. 2006;73(4):352-5. X-2, X-4. [pmid: 16531165].
1201 Kaliterna V, Kucisec-Tepes N, Pejkovic L, et al. An intrauterine device as a possible cause of change in the microbial flora of the female genital system. J Obstet Gynaecol Res. Aug. 2011;37(8):1035-40. X-2. [pmid: 21481090].
1202 Kallio H, Paloheimo M, Maunuksela EL. Haemorrhage and risk factors associated with retrobulbar/peribulbar block: a prospective study in 1383 patients. Br J Anaesth. Nov. 2000;85(5):708-11. X-2, X-3, X-4. [pmid: 11094585].
1203 Kamber N, Davis WA, Bruce DG, et al. Metformin and lactic acidosis in an Australian community setting: the Fremantle Diabetes Study. Med J Aust. Apr. 21. 2008;188(8):446-9. X-2, X-4. [pmid: 18429709].
1204 Kanat-Pektas M, Ozat M, Gungor T. The effects of TCu-380A on cervicovaginal flora. Arch Gynecol Obstet. May. 2008;277(5):429-32. X-2, X-4. [pmid: 17972087].
1205 Kane LA, Sparrow MJ. Postcoital contraception: a family planning study. N Z Med J. Apr. 12. 1989;102(865):151-3. X-2, X-3, X-4. [pmid: 2649811].
1206 Kang NS, Yoo KH, Cheon H, et al. Indomethacin treatment decreases renal blood flow velocity in human neonates. Biol Neonate. Nov. 1999;76(5):261-5. X-2, X-4. [pmid: 10516392].
1207 Kang SB, Cho KJ, Moon KH, et al. Does low-dose aspirin increase blood loss after spinal fusion surgery?. Spine J. Apr. 2011;11(4):303-7. X-2, X-4. [pmid: 21474081].
1208 Kaplan B, Farris KB, Kirking DM. Assessing physician choice of nonsteroidal antiinflammatory drugs in a health maintenance organization. Ann Pharmacother. Nov. 1993;27(11):1393-9. X-3, X-4. [pmid: 8286817].
1209 Kaplan RC, Heckbert SR, Koepsell TD, et al. Risk factors for hospitalized gastrointestinal bleeding among older persons. Cardiovascular Health Study Investigators. J Am Geriatr Soc. Feb. 2001;49(2):126-33. X-7. [pmid: 11207865].
1210 Kaplan RC, Heckbert SR, Psaty BM. Risk factors for hospitalized upper or lower gastrointestinal tract bleeding in treated hypertensives. Prev Med. Apr. 2002;34(4):455-62. X-2. [pmid: 11914052].
1211 Kapoor DA, Weitzel S, Mowad JJ, et al. Use of indomethacin suppositories in the prophylaxis of recurrent ureteral colic. J Urol. Dec. 1989;142(6):1428-30. X-2, X-3, X-4. [pmid: 2685362].
1212 Karakus S, Kiran G, Ciralik H. Efficacy of micronised vaginal progesterone versus oral dydrogestrone in the treatment of irregular dysfunctional uterine bleeding: a pilot randomised controlled trial. Aust N Z J Obstet Gynaecol. Dec. 2009;49(6):685-8. X-2, X-3, X-4. [pmid: 20070724].
1213 Karkouti K, Wijeysundera DN, Yau TM, et al. The risk-benefit profile of aprotinin versus tranexamic acid in cardiac surgery. Anesth Analg. Jan. 1. 2010;110(1):21-9. X-3. [pmid: 19910626].
1214 Kars M, Delgado V, Holman ER, et al. Aortic valve calcification and mild tricuspid regurgitation but no clinical heart disease after 8 years of dopamine agonist therapy for prolactinoma. J Clin Endocrinol Metab. Sep. 2008;93(9):3348-56. X-2. [pmid: 18559921].
1215 Karsay K. The relationship between vascular headaches and low-dose oral contraceptives. Ther Hung. 1990;38(4):181-5. X-1, X-2, X-3, X-4. [pmid: 2094059].
1216 Kasemsarn P, Kulthanan K, Tuchinda P, et al. Cutaneous reactions to non-steroidal anti-inflammatory drugs. J Drugs Dermatol. Oct. 2011;10(10):1160-7. X-2. [pmid: 21968666].
1217 Katic BJ, Golden W, Cady RK, et al. GERD prevalence in migraine patients and the implication for acute migraine treatment. J Headache Pain. Feb. 2009;10(1):35-43. X-4. [pmid: 19009231].
1218 Katschinski BD, Logan RF. Changes in birth-cohort pattern of peptic ulcer mortality in England and Wales. Postgrad Med J. Sep. 1991;67(791):825-8. X-4. [pmid: 1946128].
1219 Katsinelos P, Christodoulou K, Pilpilidis I, et al. Colopathy associated with the systemic use of nonsteroidal antiinflammatory medications. An underestimated entity. Hepatogastroenterology. Mar-Apr. 2002;49(44):345-8. X-2. [pmid: 11995447].
1220 Kaufman DW, Kelly JP. Acetylsalicylic acid and other salicylates in relation to Stevens-Johnson syndrome and toxic epidermal necrolysis. Br J Clin Pharmacol. Feb. 2001;51(2):174-6. X-2, X-4. [pmid: 11259991].
1221 Kaufman DW, Kelly JP, Sheehan JE, et al. Nonsteroidal anti-inflammatory drug use in relation to major upper gastrointestinal bleeding. Clin Pharmacol Ther. Apr. 1993;53(4):485-94. X-4. [pmid: 8477566].
1222 Kaufman DW, Kelly JP, Wiholm BE, et al. The risk of acute major upper gastrointestinal bleeding among users of aspirin and ibuprofen at various levels of alcohol consumption. Am J Gastroenterol. Nov. 1999;94(11):3189-96. X-4. [pmid: 10566713].
1223 Kaunitz AM, Bissonnette F, Monteiro I, et al. Levonorgestrel-releasing intrauterine system or medroxyprogesterone for heavy menstrual bleeding: a randomized controlled trial. Obstet Gynecol. Sep. 2010;116(3):625-32. X-2, X-4. [pmid: 20733445].
1224 Kaunitz AM, Miller PD, Rice VM, et al. Bone mineral density in women aged 25-35 years receiving depot medroxyprogesterone acetate: recovery following discontinuation. Contraception. Aug. 2006;74(2):90-9. X-2. [pmid: 16860045].
1225 Kaunitz AM, Portman DJ, Hait H, et al. Adding low-dose estrogen to the hormone-free interval: impact on bleeding patterns in users of a 91-day extended regimen oral contraceptive. Contraception. May. 2009;79(5):350-5. X-2, X-4. [pmid: 19341846].
1226 Kawasaki T, Kurosawa H, Ikeda H, et al. Additive effects of glucosamine or risedronate for the treatment of osteoarthritis of the knee combined with home exercise: a prospective randomized 18-month trial. J Bone Miner Metab. 2008;26(3):279-87. X-2, X-3, X-4. [pmid: 18470670].
1227 Kawase Y, Ishii T, Arai H, et al. Gastrointestinal perforation in very low-birthweight infants. Pediatr Int. Dec. 2006;48(6):599-603. X-2. [pmid: 17168981].
1228 Kay RM, Directo MP, Leathers M, et al. Complications of ketorolac use in children undergoing operative fracture care. J Pediatr Orthop. Oct-Nov. 2010;30(7):655-8. X-2, X-4. [pmid: 20864848].
1229 Kay RM, Leathers M, Directo MP, et al. Perioperative ketorolac use in children undergoing lower extremity osteotomies. J Pediatr Orthop. Oct-Nov. 2011;31(7):783-6. X-2, X-3, X-4. [pmid: 21926877].
1230 Keating J, Chandran H. Antiinflammatory drugs and emergency surgery for peptic ulcers in the Waikato. N Z Med J. Apr. 8. 1992;105(931):127-9. X-2, X-3. [pmid: 1560923].
1231 Keder LM, Rulin MC, Gruss J. Compliance with depot medroxyprogesterone acetate: a randomized, controlled trial of intensive reminders. Am J Obstet Gynecol. Sep. 1998;179(3 Pt 1):583-5. X-3, X-4. [pmid: 9757955].
1232 Keim SA, Klebanoff MA. Aspirin use and miscarriage risk. Epidemiology. Jul. 2006;17(4):435-9. X-4. [pmid: 16755260].
1233 Kekkonen R, Lahteenmaki P, Luukkainen T, et al. Sequential regimen of the antiprogesterone RU486 and synthetic progestin for contraception. Fertil Steril. Oct. 1993;60(4):610-5. X-2, X-3, X-4. [pmid: 8405512].
1234 Keles GT, Topcu I, Ekici Z, et al. Evaluation of piroxicam-beta-cyclodextrin as a preemptive analgesic in functional endoscopic sinus surgery. Braz J Med Biol Res. Aug. 2010;43(8):806-11. X-2, X-4. [pmid: 20602016].
1235 Keljo DJ, Sugerman KS. Pancreatitis in patients with inflammatory bowel disease. J Pediatr Gastroenterol Nutr. Jul. 1997;25(1):108-12. X-2. [pmid: 9226539].
1236 Kellner H, Bornholdt K, Hein G. Leflunomide in the treatment of patients with early rheumatoid arthritis--results of a prospective non-interventional study. Clin Rheumatol. Aug. 2010;29(8):913-20. X-2, X-4. [pmid: 20496042].
1237 Kelly JP, Kaufman DW, Jurgelon JM, et al. Risk of aspirin-associated major upper-gastrointestinal bleeding with enteric-coated or buffered product. Lancet. Nov. 23. 1996;348(9039):1413-6. X-2, X-3, X-4. [pmid: 8937281].
1238 Kemmeren JM, Tanis BC, van den Bosch MA, et al. Risk of Arterial Thrombosis in Relation to Oral Contraceptives (RATIO) study: oral contraceptives and the risk of ischemic stroke. Stroke. May. 2002;33(5):1202-8. X-2. [pmid: 11988591].
1239 Kemppainen H, Raiha I, Sourander L. Clinical presentation of bleeding peptic ulcer in the elderly. Aging (Milano). Jun. 1996;8(3):184-8. X-2. [pmid: 8862193].
1240 Kenangil G, Ozekmekci S, Koldas L, et al. Assessment of valvulopathy in Parkinson's disease patients on pergolide and/or cabergoline. Clin Neurol Neurosurg. May. 2007;109(4):350-3. X-2. [pmid: 17307289].
1241 Kennedy AD, Sculpher MJ, Coulter A, et al. Effects of decision aids for menorrhagia on treatment choices, health outcomes, and costs: a randomized controlled trial. JAMA. Dec. 4. 2002;288(21):2701-8. X-2, X-3, X-4. [pmid: 12460093].
1242 Kepczyk T, Kadakia SC. Prospective evaluation of gastrointestinal tract in patients with iron-deficiency anemia. Dig Dis Sci. Jun. 1995;40(6):1283-9. X-2, X-3, X-4. [pmid: 7781448].
1243 Kerr SJ, Rowett DS, Sayer GP, et al. All-cause mortality of elderly Australian veterans using COX-2 selective or non-selective NSAIDs: a longitudinal study. Br J Clin Pharmacol. Jun. 2011;71(6):936-42. X-4, X-6. [pmid: 21276041].
1244 Kerstens PJ, Boerbooms AM, Jeurissen ME, et al. Radiological and clinical results of longterm treatment of rheumatoid arthritis with methotrexate and azathioprine. J Rheumatol. May. 2000;27(5):1148-55. X-2, X-3, X-4. [pmid: 10813280].
1245 Kessing LV, Nilsson FM. Increased risk of developing dementia in patients with major affective disorders compared to patients with other medical illnesses. J Affect Disord. Feb. 2003;73(3):261-9. X-2, X-3, X-4. [pmid: 12547295].
1246 Kessler WF, Shires GT 3rd, Fahey TJ 3rd. Surgical complications of nonsteroidal antiinflammatory drug-induced small bowel ulceration. J Am Coll Surg. Sep. 1997;185(3):250-4. X-2. [pmid: 9291402].
1247 Kewitz H. Rare but serious risks associated with non-narcotic analgesics: clinical experience. Med Toxicol. Suppl 1. 1986;1:86-92. X-4. [pmid: 3821433].
1248 Keyl C, Uhl R, Beyersdorf F, et al. High-dose tranexamic acid is related to increased risk of generalized seizures after aortic valve replacement. Eur J Cardiothorac Surg. May. 2011;39(5):e114-21. X-2. [pmid: 21295991].
1249 Khalafallah A, Dennis A, Bates J, et al. A prospective randomized, controlled trial of intravenous versus oral iron for moderate iron deficiency anaemia of pregnancy. J Intern Med. Sep. 2010;268(3):286-95. X-2, X-3, X-4. [pmid: 20546462].
1250 Khalid SK, Lane J, Navarro V, et al. Use of over-the-counter analgesics is not associated with acute decompensation in patients with cirrhosis. Clin Gastroenterol Hepatol. Sep. 2009;7(9):994-9. quiz 13-4. X-2. [pmid: 19394441].
1251 Khan FM. A six-month parallel group comparison of fenbufen and naproxen in the treatment of rheumatoid arthritis. Clin Ther. 1983;5(5):483-7. X-2, X-3, X-4. [pmid: 6352034].
1252 Khan HA, Amitava AK. Topical diclofenac versus dexamethasone after strabismus surgery: a double-blind randomized clinical trial of anti-inflammatory effect and ocular hypertensive response. Indian J Ophthalmol. Jul-Aug. 2007;55(4):271-5. X-2, X-3, X-4. [pmid: 17595475].
1253 Kharlip J, Salvatori R, Yenokyan G, et al. Recurrence of hyperprolactinemia after withdrawal of long-term cabergoline therapy. J Clin Endocrinol Metab. Jul. 2009;94(7):2428-36. X-2, X-3. [pmid: 19336508].
1254 Khattab S, Mohsen IA, Aboul Foutouh I, et al. Can metformin reduce the incidence of gestational diabetes mellitus in pregnant women with polycystic ovary syndrome? Prospective cohort study. Gynecol Endocrinol. Oct. 2011;27(10):789-93. X-2, X-3. [pmid: 21247239].
1255 Khomassuridze AG, Tsertsvadze GL, Tsereteli TG. Intrauterine device and pelvic inflammatory disease. Adv Contracept. Mar. 1997;13(1):71-8. X-2, X-4. [pmid: 9181187].
1256 Khoo SK, Coglan MJ, Wright GR, et al. Hormone therapy in women in the menopause transition. Randomised, double-blind, placebo-controlled trial of effects on body weight, blood pressure, lipoprotein levels, antithrombin III activity, and the endometrium. Med J Aust. Mar. 2. 1998;168(5):216-20. X-2, X-4. [pmid: 9539899].
1257 Kidon MI, Liew WK, Chiang WC, et al. Hypersensitivity to paracetamol in Asian children with early onset of nonsteroidal anti-inflammatory drug allergy. Int Arch Allergy Immunol. 2007;144(1):51-6. X-2, X-3, X-4. [pmid: 17505137].
1258 Kierkegaard A. Side and site of deep vein thrombosis in women using oral contraceptives. Acta Obstet Gynecol Scand. 1985;64(5):399-402. X-2. [pmid: 4061060].
1259 Kiilholma P, Tuimala R, Kivinen S, et al. Comparison of the gonadotropin-releasing hormone agonist goserelin acetate alone versus goserelin combined with estrogen-progestogen add-back therapy in the treatment of endometriosis. Fertil Steril. Nov. 1995;64(5):903-8. X-2, X-3, X-4. [pmid: 7589632].
1260 Kim J, Lee KH, Yoo S, et al. Clinical characteristics and risk factors of colistin-induced nephrotoxicity. Int J Antimicrob Agents. Nov. 2009;34(5):434-8. X-2. [pmid: 19726164].
1261 Kim JG, Graham DY. Helicobacter pylori infection and development of gastric or duodenal ulcer in arthritic patients receiving chronic NSAID therapy. The Misoprostol Study Group. Am J Gastroenterol. Feb. 1994;89(2):203-7. X-2, X-3, X-4. [pmid: 8304304].
1262 Kim JH, Park BL, Cheong HS, et al. Genome-wide and follow-up studies identify CEP68 gene variants associated with risk of aspirin-intolerant asthma. PLoS One. 2010;5(11):e13818. X-2, X-3, X-4. [pmid: 21072201].
1263 Kim JT, Sherman O, Cuff G, et al. A double-blind prospective comparison of rofecoxib vs ketorolac in reducing postoperative pain after arthroscopic knee surgery. J Clin Anesth. Sep. 2005;17(6):439-43. X-2, X-3, X-4. [pmid: 16171664].
1264 Kim S, Martin C, Galanko J, et al. Use of nonsteroidal antiinflammatory drugs and distal large bowel cancer in whites and African Americans. Am J Epidemiol. Dec. 1. 2008;168(11):1292-300. X-4. [pmid: 18945689].
1265 Kim SH, Choi JH, Lee KW, et al. The human leucocyte antigen-DRB1*1302-DQB1*0609-DPB1*0201 haplotype may be a strong genetic marker for aspirin-induced urticaria. Clin Exp Allergy. Mar. 2005;35(3):339-44. X-2, X-3, X-4. [pmid: 15784113].
1266 Kim SH, Kang YM, Cho BY, et al. Histamine N-methyltransferase 939A>G polymorphism affects mRNA stability in patients with acetylsalicylic acid-intolerant chronic urticaria. Allergy. Feb. 2009;64(2):213-21. X-3, X-4. [pmid: 19178400].
1267 Kim SH, Nam EJ, Kim YK, et al. Functional variability of the adenosine A3 receptor (ADORA3) gene polymorphism in aspirin-induced urticaria. Br J Dermatol. Nov. 2010;163(5):977-85. X-2, X-3, X-4. [pmid: 20716228].
1268 Kim SH, Son JK, Yang EM, et al. A functional promoter polymorphism of the human IL18 gene is associated with aspirin-induced urticaria. Br J Dermatol. Nov. 2011;165(5):976-84. X-2, X-4. [pmid: 21692767].
1269 Kim SH, Ye YM, Lee SK, et al. Association of TNF-alpha genetic polymorphism with HLA DPB1*0301. Clin Exp Allergy. Oct. 2006;36(10):1247-53. X-2, X-3, X-4. [pmid: 17014432].
1270 Kim SJ, Lo WR, Hubbard GB 3rd, et al. Topical ketorolac in vitreoretinal surgery: a prospective, randomized, placebo-controlled, double-masked trial. Arch Ophthalmol. Sep. 2008;126(9):1203-8. X-2, X-3, X-4. [pmid: 18779478].
1271 Kimmel SE, Berlin JA, Reilly M, et al. Patients exposed to rofecoxib and celecoxib have different odds of nonfatal myocardial infarction. Ann Intern Med. Feb. 1. 2005;142(3):157-64. X-4. [pmid: 15684203].
1272 Kimmerle R, Weiss R, Berger M, et al. Effectiveness, safety, and acceptability of a copper intrauterine device (CU Safe 300) in type I diabetic women. Diabetes Care. Sep. 1993;16(9):1227-30. X-2, X-4. [pmid: 8404424].
1273 Kirkman RJ, Bromham DR, O'Connor TP, et al. Prospective multicentre study comparing levonorgestrel implants with a combined contraceptive pill: final results. Br J Fam Plann. Jul. 1999;25(2):36-40. X-2, X-3, X-4. [pmid: 10454652].
1274 Kirshon B, Poindexter AN 3rd. Contraception: a risk factor for endometriosis. Obstet Gynecol. Jun. 1988;71(6 Pt 1):829-31. X-2, X-4. [pmid: 3368167].
1275 Kitchen PA, Levi AJ, Domizio P, et al. Microscopic colitis: the tip of the iceberg?. Eur J Gastroenterol Hepatol. Nov. 2002;14(11):1199-204. X-2. [pmid: 12439114].
1276 Kivijarvi A, Gronroos M. Positional factors of the uterus play a contributing part in IUD failure. Acta Obstet Gynecol Scand. 1983;62(1):67-70. X-3, X-4. [pmid: 6858628].
1277 Kjaersgaard-Andersen P, Frich LH, Sojbjerg JO, et al. Heterotopic bone formation following total shoulder arthroplasty. J Arthroplasty. 1989;4(2):99-104. X-2, X-4. [pmid: 2501455].
1278 Kjos SL, Ballagh SA, La Cour M, et al. The copper T380A intrauterine device in women with type II diabetes mellitus. Obstet Gynecol. Dec. 1994;84(6):1006-9. X-2, X-4. [pmid: 7970454].
1279 Kjos SL, Peters RK, Xiang A, et al. Contraception and the risk of type 2 diabetes mellitus in Latina women with prior gestational diabetes mellitus. JAMA. Aug. 12. 1998;280(6):533-8. X-2. [pmid: 9707143].
1280 Kjos SL, Shoupe D, Douyan S, et al. Effect of low-dose oral contraceptives on carbohydrate and lipid metabolism in women with recent gestational diabetes: results of a controlled, randomized, prospective study. Am J Obstet Gynecol. Dec. 1990;163(6 Pt 1):1822-7. X-2, X-4. [pmid: 2256489].
1281 Kjotrod SB, von During V, Carlsen SM. Metformin treatment before IVF/ICSI in women with polycystic ovary syndrome; a prospective, randomized, double blind study. Hum Reprod. Jun. 2004;19(6):1315-22. X-2, X-3, X-4. [pmid: 15117902].
1282 Klavon SL, Grubb GS. Insertion site complications during the first year of NORPLANT use. Contraception. Jan. 1990;41(1):27-37. X-4. [pmid: 2105871].
1283 Klein BE, Klein R, Lee KE, et al. Drug use and five-year incidence of age-related cataracts: The Beaver Dam Eye Study. Ophthalmology. Sep. 2001;108(9):1670-4. X-4. [pmid: 11535471].
1284 Klein WA, Krevsky B, Klepper L, et al. Nonsteroidal antiinflammatory drugs and upper gastrointestinal hemorrhage in an urban hospital. Dig Dis Sci. Nov. 1993;38(11):2049-55. X-2, X-3, X-4. [pmid: 8223081].
1285 Kleinhans M, Linzbach L, Zedlitz S, et al. Positive patch test reactions to celecoxib may be due to irritation and do not correlate with the results of oral provocation. Contact Dermatitis. Aug. 2002;47(2):100-2. X-2, X-3, X-4. [pmid: 12423408].
1286 Kleinknecht D, Landais P, Goldfarb B. Drug-associated acute renal failure. A prospective collaborative study of 81 biopsied patients. Adv Exp Med Biol. 1987;212:125-8. X-2. [pmid: 3618352].
1287 Kleinstein J. Efficacy and tolerability of vaginal progesterone capsules (Utrogest 200) compared with progesterone gel (Crinone 8%) for luteal phase support during assisted reproduction. Fertil Steril. Jun. 2005;83(6):1641-9. X-2, X-3, X-4. [pmid: 15950631].
1288 Kleynhans L, Du Plessis N, Black GF, et al. Medroxyprogesterone acetate alters Mycobacterium bovis BCG-induced cytokine production in peripheral blood mononuclear cells of contraceptive users. PLoS One. 2011;6(9):e24639. X-2. [pmid: 21931790].
1289 Kluft C, Endrikat J, Mulder SM, et al. A prospective study on the effects on hemostasis of two oral contraceptives containing drospirenone in combination with either 30 or 20 microg ethinyl estradiol and a reference containing desogestrel and 30 microg ethinyl estradiol. Contraception. Apr. 2006;73(4):336-43. X-2, X-4. [pmid: 16531162].
1290 Knapp P, Gardner PH, Carrigan N, et al. Perceived risk of medicine side effects in users of a patient information website: a study of the use of verbal descriptors, percentages and natural frequencies. Br J Health Psychol. Sep. 2009;14(Pt 3):579-94. X-2, X-3, X-4. [pmid: 18992183].
1291 Kneer W, Rother I, Rother M, et al. A multiple-dose, open-label, safety, compliance, and usage evaluation study of epicutaneously applied Diractin (ketoprofen in Transfersome) in joint/musculoskeletal pain or soft tissue inflammation. Curr Drug Saf. Jan. 2009;4(1):5-10. X-2, X-4. [pmid: 19149519].
1292 Knijff-Dutmer EA, Postma MJ, van der Palen J, et al. Incremental cost-effectiveness of cyclooxygenase 2-selective versus nonselective nonsteroidal anti-inflammatory drugs in a cohort of coumarin users: a pharmacoeconomic analysis linked to a case-control study. Clin Ther. Jul. 2004;26(7):1160-7. X-4. [pmid: 15336481].
1293 Knijff-Dutmer EA, Schut GA, van de Laar MA. Concomitant coumarin-NSAID therapy and risk for bleeding. Ann Pharmacother. Jan. 2003;37(1):12-6. X-4. [pmid: 12503926].
1294 Knijff-Dutmer EA, Van der Palen J, Schut G, et al. The influence of cyclo-oxygenase specificity of non-steroidal anti-inflammatory drugs on bleeding complications in concomitant coumarine users. QJM. Jul. 2003;96(7):513-20. X-2, X-3, X-4. [pmid: 12881594].
1295 Kocak I, Yalvac IS, Kocak A, et al. Comparison of the anti-inflammatory effects of diclofenac and flurbiprofen eye drops after cataract extraction. Acta Ophthalmol Scand. Jun. 1998;76(3):343-5. X-2, X-4. [pmid: 9686850].
1296 Koch M, Dezi A, Tarquini M, et al. Prevention of non-steroidal anti-inflammatory drug-induced gastrointestinal mucosal injury: risk factors for serious complications. Dig Liver Dis. Mar. 2000;32(2):138-51. X-4. [pmid: 10975790].
1297 Koetsawang S, Charoenvisal C, Banharnsupawat L, et al. Multicenter trial of two monophasic oral contraceptives containing 30 mcg ethinylestradiol and either desogestrel or gestodene in Thai women. Contraception. Apr. 1995;51(4):225-9. X-2, X-3, X-4. [pmid: 7796587].
1298 Kohli HS. NSAIDs and bleeding ulcers. Natl Med J India. Nov-Dec. 1994;7(6):278-9. X-1, X-4. [pmid: 7841880].
1299 Kohne CH, De Greve J, Hartmann JT, et al. Irinotecan combined with infusional 5-fluorouracil/folinic acid or capecitabine plus celecoxib or placebo in the first-line treatment of patients with metastatic colorectal cancer. EORTC study 40015. Ann Oncol. May. 2008;19(5):920-6. X-2, X-3, X-4. [pmid: 18065406].
1300 Kokki H, Kokki M. Ketoprofen versus paracetamol (acetaminophen) or ibuprofen in the management of fever: results of two randomized, double-blind, double-dummy, parallel-group, repeated-dose, multicentre, phase III studies in children. Clin Drug Investig. 2010;30(6):375-86. X-4. [pmid: 20380479].
1301 Kokki H, Nikanne E, Ahonen R. The feasibility of pain treatment at home after adenoidectomy with ketoprofen tablets in small children. Paediatr Anaesth. 2000;10(5):531-5. X-2, X-4. [pmid: 11012958].
1302 Kokki H, Nikanne E, Tuovinen K. I.v. intraoperative ketoprofen in small children during adenoidectomy: a dose-finding study. Br J Anaesth. Dec. 1998;81(6):870-4. X-2, X-4. [pmid: 10211011].
1303 Kokki H, Salonen A, Nikanne E. Perioperative intravenous ketoprofen neither prolongs operation time nor delays discharge after adenoidectomy in children. Paediatr Anaesth. Jan. 2001;11(1):59-64. X-2, X-3, X-4. [pmid: 11123733].
1304 Kolt SD, Kronborg IJ, Yeomans ND. High prevalence of duodenal ulcer in Indochinese immigrants attending an Australian university hospital. J Gastroenterol Hepatol. Mar-Apr. 1993;8(2):128-32. X-4. [pmid: 8471749].
1305 Komericki P, Arbab E, Grims R, et al. Tryptase as severity marker in drug provocation tests. Int Arch Allergy Immunol. 2006;140(2):164-9. X-2, X-3, X-4. [pmid: 16601354].
1306 Koncz TA, Lister SP, Makinson GT. Gastroprotection in patients prescribed non-selective NSAIDs, and the risk of related hospitalization. Curr Med Res Opin. Dec. 2008;24(12):3405-12. X-4. [pmid: 19032122].
1307 Koninckx PR, Spielmann D. A comparative 2-year study of the effects of sequential regimens of 1 mg 17beta-estradiol and trimegestone with a regimen containing estradiol valerate and norethisterone on the bleeding profile and endometrial safety in postmenopausal women. Gynecol Endocrinol. Aug. 2005;21(2):82-9. X-2, X-3, X-4. [pmid: 16294460].
1308 Koro CE, Bowlin SJ, Weiss SR. Antidiabetic therapy and the risk of heart failure in type 2 diabetic patients: an independent effect or confounding by indication. Pharmacoepidemiol Drug Saf. Oct. 2005;14(10):697-703. X-3. [pmid: 15654719].
1309 Koseoglu BG, Ozturk S, Kocak H, et al. The effects of etodolac, nimesulid and naproxen sodium on the frequency of sister chromatid exchange after enclused third molars surgery. Yonsei Med J. Oct. 31. 2008;49(5):742-7. X-2, X-3. [pmid: 18972594].
1310 Kossoff EH, Mankad DN. Medication-overuse headache in children: is initial preventive therapy necessary?. J Child Neurol. Jan. 2006;21(1):45-8. X-2, X-3, X-4. [pmid: 16551452].
1311 Kotzan J, Wade W, Yu HH. Assessing NSAID prescription use as a predisposing factor for gastroesophageal reflux disease in a Medicaid population. Pharm Res. Sep. 2001;18(9):1367-72. X-4. [pmid: 11683254].
1312 Kouides PA, Byams VR, Philipp CS, et al. Multisite management study of menorrhagia with abnormal laboratory haemostasis: a prospective crossover study of intranasal desmopressin and oral tranexamic acid. Br J Haematol. Apr. 2009;145(2):212-20. X-2, X-3. [pmid: 19236375].
1313 Kovo M, Weissman A, Gur D, et al. Neonatal outcome in polycystic ovarian syndrome patients treated with metformin during pregnancy. J Matern Fetal Neonatal Med. Jul. 2006;19(7):415-9. X-2. [pmid: 16923696].
1314 Koyama H, Tominaga T, Asaishi K, et al. A randomized controlled comparative study of oral medroxyprogesterone acetate 1,200 and 600 mg in patients with advanced or recurrent breast cancer. Oncology. 1999;56(4):283-90. X-2, X-4. [pmid: 10343191].
1315 Kozer E, Barr J, Bulkowstein M, et al. A prospective study of multiple supratherapeutic acetaminophen doses in febrile children. Vet Hum Toxicol. Apr. 2002;44(2):106-9. X-2, X-4. [pmid: 11931497].
1316 Kozlowski KJ, Rickert VI, Hendon A, et al. Adolescents and Norplant: preliminary findings of side effects. J Adolesc Health. May. 1995;16(5):373-8. X-2, X-4. [pmid: 7662687].
1317 Kraag GR, Gordon DA, Menard HA, et al. Patient compliance with tenoxicam in family practice. Clin Ther. May-Jun. 1994;16(3):581-93. X-3, X-4. [pmid: 7923322].
1318 Kremer JM, Malamood H, Maliakkal B, et al. Fish oil dietary supplementation for prevention of indomethacin induced gastric and small bowel toxicity in healthy volunteers. J Rheumatol. Oct. 1996;23(10):1770-3. X-3, X-4. [pmid: 8895156].
1319 Kresanov I, Nikkanen V, Klemi P. Disturbances of the endometrium in the luteal phase of cycles stimulated for in vitro fertilization and of normal cycles treated with vaginal progesterone. Ann Chir Gynaecol Suppl. 1994;208:33-9. X-2, X-3, X-4. [pmid: 8092768].
1320 Kriplani A, Kulshrestha V, Agarwal N, et al. Role of tranexamic acid in management of dysfunctional uterine bleeding in comparison with medroxyprogesterone acetate. J Obstet Gynaecol. Oct. 2006;26(7):673-8. X-2. [pmid: 17071438].
1321 Kriplani A, Singh BM, Lal S, et al. Efficacy, acceptability and side effects of the levonorgestrel intrauterine system for menorrhagia. Int J Gynaecol Obstet. Jun. 2007;97(3):190-4. X-2, X-4. [pmid: 17382331].
1322 Krunic A, Ciurea A, Scheman A. Efficacy and tolerance of acne treatment using both spironolactone and a combined contraceptive containing drospirenone. J Am Acad Dermatol. Jan. 2008;58(1):60-2. X-2, X-3, X-4. [pmid: 17964689].
1323 Kruse W, Eggert-Kruse W, Rampmaier J, et al. Compliance with short-term high-dose ethinyl oestradiol in young patients with primary infertility. New insights from the use of electronic devices. Agents Actions Suppl. 1990;29:105-15. X-2, X-3, X-4. [pmid: 2316431].
1324 Kruse W, Eggert-Kruse W, Rampmaier J, et al. Compliance and adverse drug reactions: a prospective study with ethinylestradiol using continuous compliance monitoring. Clin Investig. Jun. 1993;71(6):483-7. X-2, X-4. [pmid: 8353409].
1325 Krysiak R, Gdula-Dymek A, Okopien B. Effect of simvastatin and fenofibrate on cytokine release and systemic inflammation in type 2 diabetes mellitus with mixed dyslipidemia. Am J Cardiol. Apr. 1. 2011;107(7):1010-8 e1. X-2, X-3, X-4. [pmid: 21276586].
1326 Kubicsek T, Kazy Z, Czeizel AE. Teratogenic potential of tribenoside, a drug for the treatment of haemorrhoids and varicose veins--a population-based case--control study. Reprod Toxicol. May. 2011;31(4):464-9. X-4. [pmid: 21182931].
1327 Kubota K, Kubota N, Pearce GL, et al. Signalling drug-induced rash with 36 drugs recently marketed in the United Kingdom and studied by Prescription-Event Monitoring. Int J Clin Pharmacol Ther. Apr. 1995;33(4):219-25. X-4. [pmid: 7620692].
1328 Kucuk T, Ertan K. Continuous oral or intramuscular medroxyprogesterone acetate versus the levonorgestrel releasing intrauterine system in the treatment of perimenopausal menorrhagia: a randomized, prospective, controlled clinical trial in female smokers. Clin Exp Obstet Gynecol. 2008;35(1):57-60. X-2, X-3. [pmid: 18390083].
1329 Kuehl K, Carr W, Yanchick J, et al. Analgesic efficacy and safety of the diclofenac epolamine topical patch 1.3% (DETP) in minor soft tissue injury. Int J Sports Med. Aug. 2011;32(8):635-43. X-2, X-3. [pmid: 21563042].
1330 Kulkarni J, Liew J, Garland KA. Depression associated with combined oral contraceptives--a pilot study. Aust Fam Physician. Nov. 2005;34(11):990. X-2. [pmid: 16299641].
1331 Kulkarni SG, Parikh SS, Shankhpal PD, et al. Gastric emptying of solids in long-term NSAID users: correlation with endoscopic findings and Helicobacter pylori status. Am J Gastroenterol. Feb. 1999;94(2):382-6. X-2. [pmid: 10022633].
1332 Kulnigg S, Stoinov S, Simanenkov V, et al. A novel intravenous iron formulation for treatment of anemia in inflammatory bowel disease: the ferric carboxymaltose (FERINJECT) randomized controlled trial. Am J Gastroenterol. May. 2008;103(5):1182-92. X-2, X-3, X-4. [pmid: 18371137].
1333 Kumar Nair PA, Pai MG, Gazal HA, et al. Indomethacin prophylaxis for intraventricular hemorrhage in very low birth weight babies. Indian Pediatr. Jun. 2004;41(6):551-8. X-2, X-4. [pmid: 15235161].
1334 Kumar RK, Yu VY. Prolonged low-dose indomethacin therapy for patent ductus arteriosus in very low birthweight infants. J Paediatr Child Health. Feb. 1997;33(1):38-41. X-2, X-4. [pmid: 9069042].
1335 Kuo HW, Tsai SS, Tiao MM, et al. Analgesic use and the risk for progression of chronic kidney disease. Pharmacoepidemiol Drug Saf. Jul. 2010;19(7):745-51. X-4. [pmid: 20582905].
1336 Kupczyk M, Kuprys I, Gorski P, et al. Aspirin intolerance and allergy to house dust mites: important factors associated with development of severe asthma. Ann Allergy Asthma Immunol. Apr. 2004;92(4):453-8. X-2, X-3, X-4. [pmid: 15104198].
1337 Kupczyk M, Kurmanowska Z, Kuprys-Lipinska I, et al. Mediators of inflammation in nasal lavage from aspirin intolerant patients after aspirin challenge. Respir Med. Oct. 2010;104(10):1404-9. X-2, X-4. [pmid: 20452758].
1338 Kuptniratsaikul V, Pinthong T, Bunjob M, et al. Efficacy and safety of Derris scandens Benth extracts in patients with knee osteoarthritis. J Altern Complement Med. Feb. 2011;17(2):147-53. X-2, X-3, X-4. [pmid: 21309709].
1339 Kurahara K, Matsumoto T, Iida M, et al. Clinical and endoscopic features of nonsteroidal anti-inflammatory drug-induced colonic ulcerations. Am J Gastroenterol. Feb. 2001;96(2):473-80. X-4. [pmid: 11232693].
1340 Kurata JH, Nogawa AN, Noritake D. NSAIDs increase risk of gastrointestinal bleeding in primary care patients with dyspepsia. J Fam Pract. Sep. 1997;45(3):227-35. X-2. [pmid: 9300002].
1341 Kurth T, Glynn RJ, Walker AM, et al. Inhibition of clinical benefits of aspirin on first myocardial infarction by nonsteroidal antiinflammatory drugs. Circulation. Sep. 9. 2003;108(10):1191-5. X-4. [pmid: 12939216].
1342 Kurth T, Glynn RJ, Walker AM, et al. Analgesic use and change in kidney function in apparently healthy men. Am J Kidney Dis. Aug. 2003;42(2):234-44. X-4, X-6. [pmid: 12900803].
1343 Kurth T, Hennekens CH, Sturmer T, et al. Analgesic use and risk of subsequent hypertension in apparently healthy men. Arch Intern Med. Sep. 12. 2005;165(16):1903-9. X-6. [pmid: 16157836].
1344 Kushnir A, Pinheiro JM. Comparison of renal effects of ibuprofen versus indomethacin during treatment of patent ductus arteriosus in contiguous historical cohorts. BMC Clin Pharmacol. 2011;11:8. X-2. [pmid: 21718490].
1345 Kyriakidis AV, Perysinakis I, Alexandris I, et al. Parecoxib sodium in the treatment of postoperative pain after Lichtenstein tension-free mesh inguinal hernia repair. Hernia. Feb. 2011;15(1):59-64. X-2, X-3, X-4. [pmid: 20957399].
1346 La Vecchia C, Parazzini F, Negri E, et al. Breast cancer and combined oral contraceptives: an Italian case-control study. Eur J Cancer Clin Oncol. Nov. 1989;25(11):1613-8. X-4. [pmid: 2591454].
1347 Laan W, Selten JP, Grobbee DE, et al. Non-steroidal anti-inflammatory drugs and the risk of psychosis. Eur Neuropsychopharmacol. Mar. 2007;17(4):309-11. X-2, X-3, X-4. [pmid: 17097858].
1348 Labenz J, Peitz U, Kohl H, et al. Helicobacter pylori increases the risk of peptic ulcer bleeding: a case-control study. Ital J Gastroenterol Hepatol. Mar. 1999;31(2):110-5. X-2, X-3, X-4. [pmid: 10363194].
1349 Lachance K, Savoie M, Bernard M, et al. Oral ferrous sulfate does not increase preoperative hemoglobin in patients scheduled for hip or knee arthroplasty. Ann Pharmacother. Jun. 2011;45(6):764-70. X-2, X-3, X-4. [pmid: 21666087].
1350 LaCivita C, Funkhouser E, Miller MJ, et al. Patient-reported communications with pharmacy staff at community pharmacies: the Alabama NSAID Patient Safety Study, 2005-2007. J Am Pharm Assoc (2003). Sep-Oct. 2009;49(5):e110-7. X-2, X-3. [pmid: 20797933].
1351 Lacroix I, Lapeyre-Mestre M, Bagheri H, et al. Nonsteroidal anti-inflammatory drug-induced liver injury: a case-control study in primary care. Fundam Clin Pharmacol. Apr. 2004;18(2):201-6. X-2. [pmid: 15066135].
1352 LaDuca JR, Bouman PH, Gaspari AA. Nonsteroidal antiinflammatory drug-induced pseudoporphyria: a case series. J Cutan Med Surg. Jul-Aug. 2002;6(4):320-6. X-2, X-3. [pmid: 12118363].
1353 Lafrance JP, Miller DR. Selective and non-selective non-steroidal anti-inflammatory drugs and the risk of acute kidney injury. Pharmacoepidemiol Drug Saf. Oct. 2009;18(10):923-31. X-6, X-7. [pmid: 19585463].
1354 Laharie D, Droz-Perroteau C, Benichou J, et al. Hospitalizations for gastrointestinal and cardiovascular events in the CADEUS cohort of traditional or Coxib NSAID users. Br J Clin Pharmacol. Mar. 2010;69(3):295-302. X-4. [pmid: 20233201].
1355 Laharie D, Seneschal J, Schaeverbeke T, et al. Assessment of liver fibrosis with transient elastography and FibroTest in patients treated with methotrexate for chronic inflammatory diseases: a case-control study. J Hepatol. Dec. 2010;53(6):1035-40. X-2, X-4. [pmid: 20801541].
1356 Lahteenmaki P, Bardin CW, Elomaa K, et al. Selection and performance of the levonorgestrel-releasing intrauterine system. Acta Obstet Gynecol Scand Suppl. 1997;164:69-74. X-2, X-3, X-4. [pmid: 9225643].
1357 Lahteenmaki P, Haukkamaa M, Puolakka J, et al. Open randomised study of use of levonorgestrel releasing intrauterine system as alternative to hysterectomy. BMJ. Apr. 11. 1998;316(7138):1122-6. X-2, X-3, X-4. [pmid: 9552948].
1358 Lai KC, Chu KM, Hui WM, et al. Celecoxib compared with lansoprazole and naproxen to prevent gastrointestinal ulcer complications. Am J Med. Nov. 2005;118(11):1271-8. X-2, X-3, X-4. [pmid: 16271912].
1359 Lai KC, Lam SK, Chu KM, et al. Lansoprazole reduces ulcer relapse after eradication of Helicobacter pylori in nonsteroidal anti-inflammatory drug users--a randomized trial. Aliment Pharmacol Ther. Oct. 15. 2003;18(8):829-36. X-2, X-3, X-4. [pmid: 14535877].
1360 Lai KC, Lam SK, Chu KM, et al. Lansoprazole for the prevention of recurrences of ulcer complications from long-term low-dose aspirin use. N Engl J Med. Jun. 27. 2002;346(26):2033-8. X-2, X-3, X-4. [pmid: 12087138].
1361 Laibovitz RA, Koester J, Schaich L, et al. Safety and efficacy of diclofenac sodium 0.1% ophthalmic solution in acute seasonal allergic conjunctivitis. J Ocul Pharmacol Ther. Fall. 1995;11(3):361-8. X-2, X-3, X-4. [pmid: 8590268].
1362 Laine L. NSAID-induced gastroduodenal injury: what's the score?. Gastroenterology. Aug. 1991;101(2):555-7. X-1, X-2. [pmid: 2065932].
1363 Laine L, Connors LG, Reicin A, et al. Serious lower gastrointestinal clinical events with nonselective NSAID or coxib use. Gastroenterology. Feb. 2003;124(2):288-92. X-4. [pmid: 12557133].
1364 Laine L, Curtis SP, Cryer B, et al. Risk factors for NSAID-associated upper GI clinical events in a long-term prospective study of 34 701 arthritis patients. Aliment Pharmacol Ther. Nov. 2010;32(10):1240-8. X-4. [pmid: 20955443].
1365 Laine L, Curtis SP, Langman M, et al. Lower gastrointestinal events in a double-blind trial of the cyclo-oxygenase-2 selective inhibitor etoricoxib and the traditional nonsteroidal anti-inflammatory drug diclofenac. Gastroenterology. Nov. 2008;135(5):1517-25. X-4. [pmid: 18823986].
1366 Laine L, Goldkind L, Curtis SP, et al. How common is diclofenac-associated liver injury? Analysis of 17,289 arthritis patients in a long-term prospective clinical trial. Am J Gastroenterol. Feb. 2009;104(2):356-62. X-4, X-7. [pmid: 19174782].
1367 Laine L, Sloane R, Ferretti M, et al. A randomized double-blind comparison of placebo, etodolac, and naproxen on gastrointestinal injury and prostaglandin production. Gastrointest Endosc. Nov. 1995;42(5):428-33. X-2. [pmid: 8566633].
1368 Laine L, Wogen J, Yu H. Gastrointestinal health care resource utilization with chronic use of COX-2-specific inhibitors versus traditional NSAIDs. Gastroenterology. Aug. 2003;125(2):389-95. X-4. [pmid: 12891540].
1369 Laine LA, Bentley E, Chandrasoma P. Effect of oral iron therapy on the upper gastrointestinal tract. A prospective evaluation. Dig Dis Sci. Feb. 1988;33(2):172-7. X-2, X-4. [pmid: 3257437].
1370 Lal S, Kriplani A, Kulshrestha V, et al. Efficacy of mifepristone in reducing intermenstrual vaginal bleeding in users of the levonorgestrel intrauterine system. Int J Gynaecol Obstet. May. 2010;109(2):128-30. X-2, X-3, X-4. [pmid: 20223454].
1371 Lalau JD, Race JM. Lactic acidosis in metformin therapy. Drugs. Suppl 1. 1999;58:55-60. discussion 75-82. X-1, X-4. [pmid: 10576527].
1372 Lanas A, Bajador E, Serrano P, et al. Effects of nitrate and prophylactic aspirin on upper gastrointestinal bleeding: a retrospective case-control study. J Int Med Res. Jun-Jul. 1998;26(3):120-8. X-2, X-4. [pmid: 9718466].
1373 Lanas A, Bajador E, Serrano P, et al. Nitrovasodilators, low-dose aspirin, other nonsteroidal antiinflammatory drugs, and the risk of upper gastrointestinal bleeding. N Engl J Med. Sep. 21. 2000;343(12):834-9. X-4. [pmid: 10995862].
1374 Lanas A, Fuentes J, Benito R, et al. Helicobacter pylori increases the risk of upper gastrointestinal bleeding in patients taking low-dose aspirin. Aliment Pharmacol Ther. Apr. 2002;16(4):779-86. X-2, X-4. [pmid: 11929396].
1375 Lanas A, Garcia-Rodriguez LA, Arroyo MT, et al. Effect of antisecretory drugs and nitrates on the risk of ulcer bleeding associated with nonsteroidal anti-inflammatory drugs, antiplatelet agents, and anticoagulants. Am J Gastroenterol. Mar. 2007;102(3):507-15. X-4. [pmid: 17338735].
1376 Lanas A, Garcia-Rodriguez LA, Arroyo MT, et al. Risk of upper gastrointestinal ulcer bleeding associated with selective cyclo-oxygenase-2 inhibitors, traditional non-aspirin non-steroidal anti-inflammatory drugs, aspirin and combinations. Gut. Dec. 2006;55(12):1731-8. X-4. [pmid: 16687434].
1377 Lanas A, Garcia-Tell G, Armada B, et al. Prescription patterns and appropriateness of NSAID therapy according to gastrointestinal risk and cardiovascular history in patients with diagnoses of osteoarthritis. BMC Med. 2011;9:38. X-4. [pmid: 21489310].
1378 Lanas A, Hirschowitz BI. Significant role of aspirin use in patients with esophagitis. J Clin Gastroenterol. Dec. 1991;13(6):622-7. X-2, X-3, X-4. [pmid: 1761835].
1379 Lanas A, Remacha B, Sainz R, et al. Study of outcome after targeted intervention for peptic ulcer resistant to acid suppression therapy. Am J Gastroenterol. Feb. 2000;95(2):513-9. X-2. [pmid: 10685760].
1380 Lanas A, Rodrigo L, Marquez JL, et al. Low frequency of upper gastrointestinal complications in a cohort of high-risk patients taking low-dose aspirin or NSAIDS and omeprazole. Scand J Gastroenterol. Jul. 2003;38(7):693-700. X-2, X-4. [pmid: 12889553].
1381 Lanas A, Sekar MC, Hirschowitz BI. Objective evidence of aspirin use in both ulcer and nonulcer upper and lower gastrointestinal bleeding. Gastroenterology. Sep. 1992;103(3):862-9. X-2, X-4. [pmid: 1499936].
1382 Lanas A, Serrano P, Bajador E, et al. Risk of upper gastrointestinal bleeding associated with non-aspirin cardiovascular drugs, analgesics and nonsteroidal anti-inflammatory drugs. Eur J Gastroenterol Hepatol. Feb. 2003;15(2):173-8. X-4. [pmid: 12560762].
1383 Lang BA, Finlayson LA. Naproxen-induced pseudoporphyria in patients with juvenile rheumatoid arthritis. J Pediatr. Apr. 1994;124(4):639-42. X-2. [pmid: 8151484].
1384 Lange R, Lentz R. Comparison ketoprofen, ibuprofen and naproxen sodium in the treatment of tension-type headache. Drugs Exp Clin Res. 1995;21(3):89-96. X-2, X-4. [pmid: 7555617].
1385 Langeveld JW, Lycklama a Nijeholt AA, Jonas U. Oestrogen in the treatment of prostatic carcinoma. What is the safe and effective dose of ethinyloestradiol?. Br J Urol. Jan. 1989;63(1):76-9. X-2, X-4. [pmid: 2920266].
1386 Langman M, Kahler KH, Kong SX, et al. Drug switching patterns among patients taking non-steroidal anti-inflammatory drugs: a retrospective cohort study of a general practitioners database in the United Kingdom. Pharmacoepidemiol Drug Saf. Oct-Nov. 2001;10(6):517-24. X-3, X-4. [pmid: 11828834].
1387 Langman M, Kong SX, Zhang Q, et al. Safety and patient tolerance of standard and slow-release formulations of NSAIDs. Pharmacoepidemiol Drug Saf. Jan-Feb. 2003;12(1):61-6. X-4. [pmid: 12616849].
1388 Langman MJ. Anti-inflammatory drug intake and the risk of ulcer complications. Med Toxicol. Suppl 1. 1986;1:34-8. X-1, X-2, X-3, X-4. [pmid: 3493403].
1389 Langman MJ. Ulcer complications associated with anti-inflammatory drug use. What is the extent of the disease burden?. Pharmacoepidemiol Drug Saf. Jan-Feb. 2001;10(1):13-9. X-7. [pmid: 11417061].
1390 Langman MJ, Weil J, Wainwright P, et al. Risks of bleeding peptic ulcer associated with individual non-steroidal anti-inflammatory drugs. Lancet. Apr. 30. 1994;343(8905):1075-8. X-7. [pmid: 7909103].
1391 Lanza LL, Walker AM, Bortnichak EA, et al. Peptic ulcer and gastrointestinal hemorrhage associated with nonsteroidal anti-inflammatory drug use in patients younger than 65 years. A large health maintenance organization cohort study. Arch Intern Med. Jul. 10. 1995;155(13):1371-7. X-4. [pmid: 7794085].
1392 Lao CS. Application of CUSUM technique and beta-binomial model in monitoring adverse drug reactions. J Biopharm Stat. May. 1997;7(2):227-39. X-4. [pmid: 9136066].
1393 Lapane KL, Spooner JJ, Mucha L, et al. Effect of nonsteroidal anti-inflammatory drug use on the rate of gastrointestinal hospitalizations among people living in long-term care. J Am Geriatr Soc. May. 2001;49(5):577-84. X-7. [pmid: 11380750].
1394 Lapane KL, Spooner JJ, Pettitt D. The effect of nonsteroidal anti-inflammatory drugs on the use of gastroprotective medication in people with arthritis. Am J Manag Care. Apr. 2001;7(4):402-8. X-3, X-4. [pmid: 11310194].
1395 Lapeyre-Mestre M, de Castro AM, Bareille MP, et al. Non-steroidal anti-inflammatory drug-related hepatic damage in France and Spain: analysis from national spontaneous reporting systems. Fundam Clin Pharmacol. Aug. 2006;20(4):391-5. X-4. [pmid: 16867024].
1396 Laporte JR, Carne X, Vidal X, et al. Upper gastrointestinal bleeding in relation to previous use of analgesics and non-steroidal anti-inflammatory drugs. Catalan Countries Study on Upper Gastrointestinal Bleeding. Lancet. Jan. 12. 1991;337(8733):85-9. X-4. [pmid: 1670734].
1397 Laporte JR, Ibanez L, Vidal X, et al. Upper gastrointestinal bleeding associated with the use of NSAIDs: newer versus older agents. Drug Saf. 2004;27(6):411-20. X-4. [pmid: 15144234].
1398 Larsen A, Kvien TK, Schattenkirchner M, et al. Slowing of disease progression in rheumatoid arthritis patients during long-term treatment with leflunomide or sulfasalazine. Scand J Rheumatol. 2001;30(3):135-42. X-2, X-3, X-4. [pmid: 11469522].
1399 Larsen K, Tos M. A long-term follow-up study of nasal polyp patients after simple polypectomies. Eur Arch Otorhinolaryngol. Suppl 1. 1997;254:S85-8. X-2, X-3. [pmid: 9065636].
1400 Larsson B, Hagstrom B, Viberg L, et al. Long-term clinical experience with the Cu-7-IUD. Evaluation of a prospective study. Contraception. Apr. 1981;23(4):387-97. X-2, X-4. [pmid: 7273759].
1401 Lassen A, Hallas J, Schaffalitzky de Muckadell OB. Complicated and uncomplicated peptic ulcers in a Danish county 1993-2002: a population-based cohort study. Am J Gastroenterol. May. 2006;101(5):945-53. X-4. [pmid: 16573778].
1402 Lassise DL, Savitz DA, Hamman RF, et al. Invasive cervical cancer and intrauterine device use. Int J Epidemiol. Dec. 1991;20(4):865-70. X-2, X-4. [pmid: 1800424].
1403 Lassner KJ, Chen CH, Kropsch LA, et al. Comparative study of safety and efficacy of IUD insertions by physicians and nursing personnel in Brazil. Bull Pan Am Health Organ. Sep. 1995;29(3):206-15. X-3, X-4. [pmid: 8520606].
1404 Laszlo A, Kelly JP, Kaufman DE, et al. Clinical aspects of upper gastrointestinal bleeding associated with the use of nonsteroidal antiinflammatory drugs. Am J Gastroenterol. May. 1998;93(5):721-5. X-2, X-4. [pmid: 9625116].
1405 Lawrenson R, Todd JC, Leydon GM, et al. Validation of the diagnosis of venous thromboembolism in general practice database studies. Br J Clin Pharmacol. Jun. 2000;49(6):591-6. X-2, X-3, X-4. [pmid: 10848723].
1406 Layton D, Heeley E, Hughes K, et al. Comparison of the incidence rates of selected gastrointestinal events reported for patients prescribed rofecoxib and meloxicam in general practice in England using prescription-event monitoring data. Rheumatology (Oxford). May. 2003;42(5):622-31. X-2, X-4. [pmid: 12709537].
1407 Layton D, Heeley E, Shakir SA. Identification and evaluation of a possible signal of exacerbation of colitis during rofecoxib treatment, using Prescription-Event Monitoring data. J Clin Pharm Ther. Apr. 2004;29(2):171-81. X-4. [pmid: 15068407].
1408 Layton D, Hughes K, Harris S, et al. Comparison of the incidence rates of selected gastrointestinal events reported for patients prescribed celecoxib and meloxicam in general practice in England using prescription-event monitoring (PEM) data. Rheumatology (Oxford). Nov. 2003;42(11):1332-41. X-4. [pmid: 12810929].
1409 Layton D, Riley J, Wilton LV, et al. Safety profile of rofecoxib as used in general practice in England: results of a prescription-event monitoring study. Br J Clin Pharmacol. Feb. 2003;55(2):166-74. X-4. [pmid: 12580988].
1410 Layton D, Souverein PC, Heerdink ER, et al. Evaluation of risk profiles for gastrointestinal and cardiovascular adverse effects in nonselective NSAID and COX-2 inhibitor users: a cohort study using pharmacy dispensing data in The Netherlands. Drug Saf. 2008;31(2):143-58. X-4. [pmid: 18217790].
1411 Lebbe M, Hubinont C, Bernard P, et al. Outcome of 100 pregnancies initiated under treatment with cabergoline in hyperprolactinaemic women. Clin Endocrinol (Oxf). Aug. 2010;73(2):236-42. X-2. [pmid: 20455894].
1412 Lee CH, Wang JD, Chen PC. Increased risk of hospitalization for acute hepatitis in patients with previous exposure to NSAIDs. Pharmacoepidemiol Drug Saf. Jul. 2010;19(7):708-14. X-4. [pmid: 20582911].
1413 Lee J, Rajadurai VS, Tan KW, et al. Randomized trial of prolonged low-dose versus conventional-dose indomethacin for treating patent ductus arteriosus in very low birth weight infants. Pediatrics. Aug. 2003;112(2):345-50. X-2, X-3, X-4. [pmid: 12897285].
1414 Lee MC, Lee S, Suh DC, et al. A cross-sectional retrospective assessment of anti-arthritic drugs in patients with arthritis in Korea. Curr Med Res Opin. 2003;19(7):597-602. X-2, X-3, X-4. [pmid: 14606981].
1415 Lee SC, Rha DW, Chang WH. Rapid analgesic onset of intra-articular hyaluronic acid with ketorolac in osteoarthritis of the knee. J Back Musculoskelet Rehabil. 2011;24(1):31-8. X-2, X-3, X-4. [pmid: 21248398].
1416 Lee SH, Han CD, Yang IH, et al. Prescription pattern of NSAIDs and the prevalence of NSAID-induced gastrointestinal risk factors of orthopaedic patients in clinical practice in Korea. J Korean Med Sci. Apr. 2011;26(4):561-7. X-4. [pmid: 21468265].
1417 Lee TA, Bartle B, Weiss KB. Impact of NSAIDS on mortality and the effect of preexisting coronary artery disease in US veterans. Am J Med. Jan. 2007;120(1):98 e9-16. X-4, X-6. [pmid: 17208086].
1418 Lee TY, Yang YS, Tseng LH, et al. Norplant-2 subdermal contraceptive system: experience in Taiwan. J Formos Med Assoc. May. 1993;92(5):446-50. X-2, X-4. [pmid: 8104598].
1419 Leeyaphan C, Kulthanan K, Jongjarearnprasert K, et al. Drug-induced angioedema without urticaria: prevalence and clinical features. J Eur Acad Dermatol Venereol. Jun. 2010;24(6):685-91. X-4. [pmid: 19925599].
1420 Legeby M, Sandelin K, Wickman M, et al. Analgesic efficacy of diclofenac in combination with morphine and paracetamol after mastectomy and immediate breast reconstruction. Acta Anaesthesiol Scand. Oct. 2005;49(9):1360-6. X-2, X-3, X-4. [pmid: 16146476].
1421 Legras A, Giraudeau B, Jonville-Bera AP, et al. A multicentre case-control study of nonsteroidal anti-inflammatory drugs as a risk factor for severe sepsis and septic shock. Crit Care. 2009;13(2):R43. X-2, X-4. [pmid: 19331665].
1422 Lehtinen K, Kaarela K, Ahonen M, et al. A six-month follow-up study of a slow-release indomethacin tablet in rheumatic diseases. Clin Rheumatol. Dec. 1987;6(4):606-7. X-1. [pmid: 3329590].
1423 LeLorier J. Patterns of prescription of nonsteroidal antiinflammatory drugs and gastroprotective agents. J Rheumatol Suppl. Feb. 1995;43:26-7. X-4, X-7. [pmid: 7752128].
1424 Lemberg A, Fernandez MA, Coll C, et al. Reyes's syndrome, encephalopathy, hyperammonemia and acetyl salicylic acid ingestion in a city hospital of Buenos Aires, Argentina. Curr Drug Saf. Jan. 2009;4(1):17-21. X-2, X-3, X-4. [pmid: 19149521].
1425 Lemmel EM, Leeb B, De Bast J, et al. Patient and physician satisfaction with aceclofenac: results of the European Observational Cohort Study (experience with aceclofenac for inflammatory pain in daily practice). Aceclofenac is the treatment of choice for patients and physicians in the management of inflammatory pain. Curr Med Res Opin. 2002;18(3):146-53. X-3, X-4. [pmid: 12094824].
1426 Leonardi C, Strober B, Gottlieb AB, et al. Long-term safety and efficacy of etanercept in patients with psoriasis: an open-label study. J Drugs Dermatol. Aug. 2010;9(8):928-37. X-2, X-3, X-4. [pmid: 20684143].
1427 Leonhardt A, Strehl R, Barth H, et al. High efficacy and minor renal effects of indomethacin treatment during individualized fluid intake in premature infants with patent ductus arteriosus. Acta Paediatr. Feb. 2004;93(2):233-40. X-2, X-4. [pmid: 15046280].
1428 Lera G, Vaamonde J, Rodriguez M, et al. Cabergoline in Parkinson's disease: long-term follow-up. Neurology. Dec. 1993;43(12):2587-90. X-2. [pmid: 7902970].
1429 Leroy S, Marc E, Bavoux F, et al. Hospitalization for severe bacterial infections in children after exposure to NSAIDs: a prospective adverse drug reaction reporting study. Clin Drug Investig. 2010;30(3):179-85. X-2. [pmid: 20155990].
1430 Lesko SM, Louik C, Vezina RM, et al. Asthma morbidity after the short-term use of ibuprofen in children. Pediatrics. Feb. 2002;109(2):E20. X-4. [pmid: 11826230].
1431 Lesko SM, O'Brien KL, Schwartz B, et al. Invasive group A streptococcal infection and nonsteroidal antiinflammatory drug use among children with primary varicella. Pediatrics. May. 2001;107(5):1108-15. X-2. [pmid: 11331694].
1432 Lete I, del Carme Cuesta M, Marin JM, et al. Acceptability of the levonorgestrel intrauterine system in the long-term treatment of heavy menstrual bleeding: how many women choose to use a second device?. Eur J Obstet Gynecol Reprod Biol. Jan. 2011;154(1):67-70. X-2, X-3. [pmid: 20728261].
1433 Lete I, Obispo C, Izaguirre F, et al. The levonorgestrel intrauterine system (Mirena) for treatment of idiopathic menorrhagia. Assessment of quality of life and satisfaction. Eur J Contracept Reprod Health Care. Sep. 2008;13(3):231-7. X-2, X-4. [pmid: 18609346].
1434 Levi Z, Rozen P, Hazazi R, et al. Sensitivity, but not specificity, of a quantitative immunochemical fecal occult blood test for neoplasia is slightly increased by the use of low-dose aspirin, NSAIDs, and anticoagulants. Am J Gastroenterol. Apr. 2009;104(4):933-8. X-2, X-3. [pmid: 19293792].
1435 Levine RA, Petokas S, Nandi J, et al. Effects of nonsteroidal, antiinflammatory drugs on gastrointestinal injury and prostanoid generation in healthy volunteers. Dig Dis Sci. Jun. 1988;33(6):660-6. X-2, X-4. [pmid: 3371138].
1436 Levy R, Matitiau A, Ben Arie A, et al. Indomethacin and corticosteroids: an additive constrictive effect on the fetal ductus arteriosus. Am J Perinatol. 1999;16(8):379-83. X-2, X-3, X-4. [pmid: 10772195].
1437 Lewis JD, Schinnar R, Bilker WB, et al. Validation studies of the health improvement network (THIN) database for pharmacoepidemiology research. Pharmacoepidemiol Drug Saf. Apr. 2007;16(4):393-401. X-2, X-3, X-4. [pmid: 17066486].
1438 Lewis JD, Strom BL, Localio AR, et al. Moderate and high affinity serotonin reuptake inhibitors increase the risk of upper gastrointestinal toxicity. Pharmacoepidemiol Drug Saf. Apr. 2008;17(4):328-35. X-2, X-3, X-4. [pmid: 18188866].
1439 Lewis MA, Spitzer WO, Heinemann LA, et al. Third generation oral contraceptives and risk of myocardial infarction: an international case-control study. Transnational Research Group on Oral Contraceptives and the Health of Young Women. BMJ. Jan. 13. 1996;312(7023):88-90. X-2, X-4. [pmid: 8555936].
1440 Li CF, Lee SS, Pun TC. A pilot study on the acceptability of levonorgestrel-releasing intrauterine device by young, single, nulliparous Chinese females following surgical abortion. Contraception. Mar. 2004;69(3):247-50. X-2, X-3, X-4. [pmid: 14969674].
1441 Li CF, Wong CY, Chan CP, et al. A study of co-treatment of nonsteroidal anti-inflammatory drugs (NSAIDs) with misoprostol for cervical priming before suction termination of first trimester pregnancy. Contraception. Feb. 2003;67(2):101-5. X-2. [pmid: 12586320].
1442 Li CH, Chang WH, Shih SC, et al. Perforated peptic ulcer in southeastern Taiwan. J Gastroenterol Hepatol. Sep. 2010;25(9):1530-6. X-2, X-3, X-4. [pmid: 20796151].
1443 Li CI, Beaber EF, Tang MT, et al. Effect of depo-medroxyprogesterone acetate on breast cancer risk among women 20 to 44 years of age. Cancer Res. Apr. 15. 2012;72(8):2028-35. X-2. [pmid: 22369929].
1444 Li DK, Liu L, Odouli R. Exposure to non-steroidal anti-inflammatory drugs during pregnancy and risk of miscarriage: population based cohort study. BMJ. Aug. 16. 2003;327(7411):368. X-2. [pmid: 12919986].
1445 Li L. A conditional sequential sampling procedure for drug safety surveillance. Stat Med. Nov. 10. 2009;28(25):3124-38. X-1, X-2. [pmid: 19691034].
1446 Li Voti G, Acierno C, Tulone V, et al. Relationship between upper gastrointestinal bleeding and non steroidal anti-inflammatory drugs in children. Pediatr Surg Int. Apr. 1997;12(4):264-5. X-2. [pmid: 9099642].
1447 Li Y, Chen F, Zhou L, et al. COC use, ACE/AGT gene polymorphisms, and risk of stroke. Pharmacogenet Genomics. May. 2010;20(5):298-306. X-2, X-4. [pmid: 20300047].
1448 Liao EY, Luo XH, Deng XG, et al. The effect of low dose nylestriol-levonorgestrel replacement therapy on bone mineral density in women with postmenopausal osteoporosis. Endocr Res. May. 2003;29(2):217-26. X-2, X-4. [pmid: 12856809].
1449 Liao WC, Hou MC, Chang CJ, et al. Potential precipitating factors of esophageal variceal bleeding: a case-control study. Am J Gastroenterol. Jan. 2011;106(1):96-103. X-2, X-3, X-4. [pmid: 20823836].
1450 Licata A, Calvaruso V, Cappello M, et al. Clinical course and outcomes of drug-induced liver injury: nimesulide as the first implicated medication. Dig Liver Dis. Feb. 2010;42(2):143-8. X-2, X-4. [pmid: 19625223].
1451 Lidegaard O. The influence of thrombotic risk factors when oral contraceptives are prescribed. A control-only study. Acta Obstet Gynecol Scand. Mar. 1997;76(3):252-60. X-2. [pmid: 9093141].
1452 Lidegaard O, Kreiner S. Cerebral thrombosis and oral contraceptives. A case-control study. Contraception. May. 1998;57(5):303-14. X-2. [pmid: 9673837].
1453 Lidegaard O, Lokkegaard E, Svendsen AL, et al. Hormonal contraception and risk of venous thromboembolism: national follow-up study. BMJ. 2009;339:b2890. X-4. [pmid: 19679613].
1454 Liguori L. Iron protein succinylate in the treatment of iron deficiency: controlled, double-blind, multicenter clinical trial on over 1,000 patients. Int J Clin Pharmacol Ther Toxicol. Mar. 1993;31(3):103-23. X-2, X-3, X-4. [pmid: 8468108].
1455 Lim CH, Heatley RV. Prospective study of acute gastrointestinal bleeding attributable to anti-inflammatory drug ingestion in the Yorkshire region of the United Kingdom. Postgrad Med J. Apr. 2005;81(954):252-4. X-2. [pmid: 15811890].
1456 Lindegard B, Hillbom M, Brody S. High-dose estrogen-progestagen oral contraceptives: a risk factor for aneurysmal subarachnoid hemorrhage?. Acta Neurol Scand. Jul. 1987;76(1):37-45. X-4. [pmid: 3630643].
1457 Lindh I, Ellstrom AA, Milsom I. The long-term influence of combined oral contraceptives on body weight. Hum Reprod. Jul. 2011;26(7):1917-24. X-2. [pmid: 21507999].
1458 Lindoff C, Rybo G, Astedt B. Treatment with tranexamic acid during pregnancy, and the risk of thromboembolic complications. Thromb Haemost. Aug. 2. 1993;70(2):238-40. X-8. [pmid: 8236125].
1459 Lindquist M, Pettersson M, Edwards IR, et al. How does cystitis affect a comparative risk profile of tiaprofenic acid with other non-steroidal antiinflammatory drugs? An international study based on spontaneous reports and drug usage data. ADR Signals Analysis Project (ASAP) Team. Pharmacol Toxicol. May. 1997;80(5):211-7. X-2, X-4. [pmid: 9181599].
1460 Lindvall G, Sartipy U, Ivert T, et al. Aprotinin is not associated with postoperative renal impairment after primary coronary surgery. Ann Thorac Surg. Jul. 2008;86(1):13-9. X-2, X-3, X-4. [pmid: 18573391].
1461 Liossis SN, Bounas A, Andonopoulos AP. Mycophenolate mofetil as first-line treatment improves clinically evident early scleroderma lung disease. Rheumatology (Oxford). Aug. 2006;45(8):1005-8. X-2, X-3, X-4. [pmid: 16490756].
1462 Lipscomb GR, Campbell F, Rees WD. The influence of age, gender, Helicobacter pylori and smoking on gastric mucosal adaptation to non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. Oct. 1997;11(5):907-12. X-2. [pmid: 9354199].
1463 Lipscomb GR, Rees WD. Gastric mucosal injury and adaptation to oral and rectal administration of naproxen. Aliment Pharmacol Ther. Apr. 1996;10(2):133-8. X-2, X-4. [pmid: 8730240].
1464 Lipson A, Stoy DB, LaRosa JC, et al. Progestins and oral contraceptive-induced lipoprotein changes: a prospective study. Contraception. Aug. 1986;34(2):121-34. X-2, X-4. [pmid: 3096633].
1465 Lipworth L, Friis S, Blot WJ, et al. A population-based cohort study of mortality among users of ibuprofen in Denmark. Am J Ther. May-Jun. 2004;11(3):156-63. X-4. [pmid: 15133529].
1466 Lisse J, Espinoza L, Zhao SZ, et al. Functional status and health-related quality of life of elderly osteoarthritic patients treated with celecoxib. J Gerontol A Biol Sci Med Sci. Mar. 2001;56(3):M167-75. X-2, X-4. [pmid: 11253158].
1467 Lisse JR, Perlman M, Johansson G, et al. Gastrointestinal tolerability and effectiveness of rofecoxib versus naproxen in the treatment of osteoarthritis: a randomized, controlled trial. Ann Intern Med. Oct. 7. 2003;139(7):539-46. X-4. [pmid: 14530224].
1468 Liu MY, Lin HH, Chen PC. Duodenal ulcer hemorrhage with and without dyspepsia. Am J Gastroenterol. Oct. 1990;85(10):1343-5. X-2, X-3, X-4. [pmid: 2220727].
1469 Liu NJ, Lee CS, Tang JH, et al. Outcomes of bleeding peptic ulcers: a prospective study. J Gastroenterol Hepatol. Aug. 2008;23(8 Pt 2):e340-7. X-2, X-4. [pmid: 17944885].
1470 Livesey JR, Watson MG, Kelly PJ, et al. Do patients with epistaxis have drug-induced platelet dysfunction?. Clin Otolaryngol Allied Sci. Oct. 1995;20(5):407-10. X-2. [pmid: 8582070].
1471 Ljung R, Lu Y, Lagergren J. High concomitant use of interacting drugs and low use of gastroprotective drugs among NSAID users in an unselected elderly population: a nationwide register-based study. Drugs Aging. Jun. 1. 2011;28(6):469-76. X-4. [pmid: 21639406].
1472 Llorente Melero MJ, Tenias Burillo JM, Del Val Antonana A, et al. Influence of nonsteroidal anti-inflammatory drugs on clinical course in upper gastrointestinal tract bleeding. Rev Esp Enferm Dig. Jul. 1999;91(7):497-507. X-2. [pmid: 10477368].
1473 Llorente Melero MJ, Tenias Burillo JM, Zaragoza Marcet A. Comparative incidence of upper gastrointestinal bleeding associated with individual non-steroidal anti-inflammatory drugs. Rev Esp Enferm Dig. Jan. 2002;94(1):7-18. X-4. [pmid: 12073673].
1474 Lockhat FB, Emembolu JO, Konje JC. The evaluation of the effectiveness of an intrauterine-administered progestogen (levonorgestrel) in the symptomatic treatment of endometriosis and in the staging of the disease. Hum Reprod. Jan. 2004;19(1):179-84. X-2, X-3, X-4. [pmid: 14688179].
1475 Lockhat FB, Emembolu JO, Konje JC. The efficacy, side-effects and continuation rates in women with symptomatic endometriosis undergoing treatment with an intra-uterine administered progestogen (levonorgestrel): a 3 year follow-up. Hum Reprod. Mar. 2005;20(3):789-93. X-2, X-4. [pmid: 15608040].
1476 Lockie LM. Tolerability and efficacy of long-term daily administration of indomethacin for moderate to severe chronic arthritic disorders. Clin Ther. 1986;8(4):398-405. X-2, X-4. [pmid: 3731210].
1477 Loebstein R, Dushinat M, Vesterman-Landes J, et al. Database evaluation of the effects of long-term rosiglitazone treatment on cardiovascular outcomes in patients with type 2 diabetes. J Clin Pharmacol. Feb. 2011;51(2):173-80. X-3. [pmid: 20484611].
1478 Lombroso GL, vicariotto F, Quaranta S, et al. Study of a new intrauterine device, the multiload 250 CU. Acta Eur Fertil. Sep. 1980;11(3):221-4. X-2, X-3, X-4. [pmid: 7468105].
1479 Loperfido S, Monica F, Maifreni L, et al. Bleeding peptic ulcer occurring in hospitalized patients: analysis of predictive and risk factors and comparison with out-of-hospital onset of hemorrhage. Dig Dis Sci. Apr. 1994;39(4):698-705. X-2. [pmid: 8149834].
1480 Lopez G, Rodriguez A, Rengifo J, et al. Two-year prospective study in Colombia of Norplant implants. Obstet Gynecol. Aug. 1986;68(2):204-8. X-2, X-4. [pmid: 3090492].
1481 Loughlin J, Seeger JD, Eng PM, et al. Risk of hyperkalemia in women taking ethinylestradiol/drospirenone and other oral contraceptives. Contraception. Nov. 2008;78(5):377-83. X-4. [pmid: 18929734].
1482 Luchese S, Manica JL, Zielinsky P. Intrauterine ductus arteriosus constriction: analysis of a historic cohort of 20 cases. Arq Bras Cardiol. Oct. 2003;81(4):405-10. 399. 404. X-2, X-3, X-4. [pmid: 14666282].
1483 Lucky AW, Henderson TA, Olson WH, et al. Effectiveness of norgestimate and ethinyl estradiol in treating moderate acne vulgaris. J Am Acad Dermatol. Nov. 1997;37(5 Pt 1):746-54. X-2, X-3, X-4. [pmid: 9366821].
1484 Ludwig M, Schwartz P, Babahan B, et al. Luteal phase support using either Crinone 8% or Utrogest: results of a prospective, randomized study. Eur J Obstet Gynecol Reprod Biol. Jun. 10. 2002;103(1):48-52. X-2, X-3, X-4. [pmid: 12039463].
1485 Luisi S, Razzi S, Lazzeri L, et al. Efficacy of vaginal danazol treatment in women with menorrhagia during fertile age. Fertil Steril. Oct. 2009;92(4):1351-4. X-2, X-4. [pmid: 18930222].
1486 Lukes AS, Moore KA, Muse KN, et al. Tranexamic acid treatment for heavy menstrual bleeding: a randomized controlled trial. Obstet Gynecol. Oct. 2010;116(4):865-75. X-2. [pmid: 20859150].
1487 Lund SS, Tarnow L, Stehouwer CD, et al. Targeting hyperglycaemia with either metformin or repaglinide in non-obese patients with type 2 diabetes: results from a randomized crossover trial. Diabetes Obes Metab. May. 2007;9(3):394-407. X-2, X-3, X-4. [pmid: 17391168].
1488 Lundberg GD. Esomeprazole prevents aspirin-induced ulcers. Medscape J Med. 2008;10(12):285. X-4. [pmid: 19242591].
1489 Lundgren R, Sundin T, Colleen S, et al. Cardiovascular complications of estrogen therapy for nondisseminated prostatic carcinoma. A preliminary report from a randomized multicenter study. Scand J Urol Nephrol. 1986;20(2):101-5. X-2, X-4. [pmid: 3529368].
1490 Lundstrom E, Christow A, Kersemaekers W, et al. Effects of tibolone and continuous combined hormone replacement therapy on mammographic breast density. Am J Obstet Gynecol. Apr. 2002;186(4):717-22. X-2, X-4. [pmid: 11967497].
1491 Lundstrom E, Wilczek B, von Palffy Z, et al. Mammographic breast density during hormone replacement therapy: effects of continuous combination, unopposed transdermal and low-potency estrogen regimens. Climacteric. Mar. 2001;4(1):42-8. X-2. [pmid: 11379377].
1492 Luo JC, Lin HY, Chang FY, et al. Occurrence of peptic ulcer disease in connective tissue disease patients associated with xerostomia. Aliment Pharmacol Ther. Jan. 2003;17(2):217-24. X-2. [pmid: 12534406].
1493 Lurie G, Thompson P, McDuffie KE, et al. Association of estrogen and progestin potency of oral contraceptives with ovarian carcinoma risk. Obstet Gynecol. Mar. 2007;109(3):597-607. X-4. [pmid: 17329510].
1494 Luthra UK, Mitra AB, Prabhakar AK, et al. Copper containing intrauterine devices and cervical carcinogenesis--48 months follow up. Indian J Med Res. Nov. 1980;72:659-64. X-4. [pmid: 7203566].
1495 Luyckx AS, Gaspard UJ, Romus MA, et al. Carbohydrate metabolism in women who used oral contraceptives containing levonorgestrel or desogestrel: a 6-month prospective study. Fertil Steril. May. 1986;45(5):635-42. X-2, X-3, X-4. [pmid: 2938985].
1496 Lyytinen HK, Dyba T, Ylikorkala O, et al. A case-control study on hormone therapy as a risk factor for breast cancer in Finland: Intrauterine system carries a risk as well. Int J Cancer. Jan. 15. 2010;126(2):483-9. X-7. [pmid: 19588504].
1497 Maca SM, Amon M, Findl O, et al. Efficacy and tolerability of preservative-free and preserved diclofenac and preserved ketorolac eyedrops after cataract surgery. Am J Ophthalmol. May. 2010;149(5):777-84. X-2, X-3, X-4. [pmid: 20152959].
1498 MacDonald MR, Eurich DT, Majumdar SR, et al. Treatment of type 2 diabetes and outcomes in patients with heart failure: a nested case-control study from the U.K. General Practice Research Database. Diabetes Care. Jun. 2010;33(6):1213-8. X-3. [pmid: 20299488].
1499 MacDonald TM, Morant SV, Goldstein JL, et al. Channelling bias and the incidence of gastrointestinal haemorrhage in users of meloxicam, coxibs, and older, non-specific non-steroidal anti-inflammatory drugs. Gut. Sep. 2003;52(9):1265-70. X-4. [pmid: 12912856].
1500 MacDonald TM, Morant SV, Robinson GC, et al. Association of upper gastrointestinal toxicity of non-steroidal anti-inflammatory drugs with continued exposure: cohort study. BMJ. Nov. 22. 1997;315(7119):1333-7. X-7. [pmid: 9402773].
1501 Machado RB, de Melo NR, Maia H Jr., et al. Effect of a continuous regimen of contraceptive combination of ethinylestradiol and drospirenone on lipid, carbohydrate and coagulation profiles. Contraception. Feb. 2010;81(2):102-6. X-2. [pmid: 20103445].
1502 Madan J, Fiascone J, Balasubramanian V, et al. Predictors of ductal closure and intestinal complications in very low birth weight infants treated with indomethacin. Neonatology. 2008;94(1):45-51. X-2, X-3, X-4. [pmid: 18196930].
1503 Maddali MM, Rajakumar MC. Tranexamic acid and primary coronary artery bypass surgery: a prospective study. Asian Cardiovasc Thorac Ann. Aug. 2007;15(4):313-9. X-2, X-3, X-4. [pmid: 17664205].
1504 Mafuva C, Djarova T, Matarira HT. Influence of combined oral contraceptives on the onset of cervical intraepithelial neoplasia. Afr J Health Sci. Jul-Dec. 2002;9(3-4):129-37. X-2. [pmid: 17298156].
1505 Magos AL, Brewster E, Singh R, et al. The effects of norethisterone in postmenopausal women on oestrogen replacement therapy: a model for the premenstrual syndrome. Br J Obstet Gynaecol. Dec. 1986;93(12):1290-6. X-2, X-3, X-4. [pmid: 3801360].
1506 Mahmood M, Malone DC, Skrepnek GH, et al. Potential drug-drug interactions within Veterans Affairs medical centers. Am J Health Syst Pharm. Jul. 15. 2007;64(14):1500-5. X-3, X-4. [pmid: 17617500].
1507 Maia H Jr., Casoy J, Correia T, et al. Activation of NF-kappaB and COX-2 expression is associated with breakthrough bleeding in patients using oral contraceptives in extended regimens. Gynecol Endocrinol. Apr. 2010;26(4):265-9. X-2, X-4, X-5. [pmid: 19757243].
1508 Maiden L, Thjodleifsson B, Seigal A, et al. Long-term effects of nonsteroidal anti-inflammatory drugs and cyclooxygenase-2 selective agents on the small bowel: a cross-sectional capsule enteroscopy study. Clin Gastroenterol Hepatol. Sep. 2007;5(9):1040-5. X-2. [pmid: 17625980].
1509 Maieron R, Stimac D, Avellini C, et al. Acute gastrointestinal bleeding due to Meckel's diverticulum heterotopic gastric mucosa. Ital J Gastroenterol. May. 1996;28(4):225-8. X-2. [pmid: 8842839].
1510 Maj S, Centkowski P. A prospective study of the incidence of agranulocytosis and aplastic anemia associated with the oral use of metamizole sodium in Poland. Med Sci Monit. Sep. 2004;10(9):PI93-5. X-3, X-4. [pmid: 15328493].
1511 Maj S, Lis Y. The incidence of metamizole sodium-induced agranulocytosis in Poland. J Int Med Res. Sep-Oct. 2002;30(5):488-95. X-4. [pmid: 12449518].
1512 Major CA, Lewis DF, Harding JA, et al. Tocolysis with indomethacin increases the incidence of necrotizing enterocolitis in the low-birth-weight neonate. Am J Obstet Gynecol. Jan. 1994;170(1 Pt 1):102-6. X-2, X-4. [pmid: 8296809].
1513 Malgarinos G, Gikas A, Delicha E, et al. Pregnancy and inflammatory bowel disease: a prospective case-control study. Rev Med Chir Soc Med Nat Iasi. Jul-Sep. 2007;111(3):613-9. X-2, X-3, X-4. [pmid: 18293689].
1514 Malhotra S, Jain S, Pandhi P. Drug-related visits to the medical emergency department: a prospective study from India. Int J Clin Pharmacol Ther. Jan. 2001;39(1):12-8. X-4. [pmid: 11204932].
1515 Malik MH, Gray J, Kay PR. Early aseptic loosening of cemented total hip arthroplasty: the influence of non-steroidal anti-inflammatory drugs and smoking. Int Orthop. Aug. 2004;28(4):211-3. X-2, X-4. [pmid: 15048587].
1516 Mamdani M, Juurlink DN, Lee DS, et al. Cyclo-oxygenase-2 inhibitors versus non-selective non-steroidal anti-inflammatory drugs and congestive heart failure outcomes in elderly patients: a population-based cohort study. Lancet. May. 29. 2004;363(9423):1751-6. X-4. [pmid: 15172772].
1517 Mamdani M, Rochon P, Juurlink DN, et al. Effect of selective cyclooxygenase 2 inhibitors and naproxen on short-term risk of acute myocardial infarction in the elderly. Arch Intern Med. Feb. 24. 2003;163(4):481-6. X-7. [pmid: 12588209].
1518 Mamdani M, Rochon PA, Juurlink DN, et al. Observational study of upper gastrointestinal haemorrhage in elderly patients given selective cyclo-oxygenase-2 inhibitors or conventional non-steroidal anti-inflammatory drugs. BMJ. Sep. 21. 2002;325(7365):624. X-7. [pmid: 12242172].
1519 Mamdani M, Warren L, Kopp A, et al. Changes in rates of upper gastrointestinal hemorrhage after the introduction of cyclooxygenase-2 inhibitors in British Columbia and Ontario. CMAJ. Dec. 5. 2006;175(12):1535-8. X-4, X-7. [pmid: 17146090].
1520 Man CY, Cheung IT, Cameron PA, et al. Comparison of oral prednisolone/paracetamol and oral indomethacin/paracetamol combination therapy in the treatment of acute goutlike arthritis: a double-blind, randomized, controlled trial. Ann Emerg Med. May. 2007;49(5):670-7. X-2, X-4. [pmid: 17276548].
1521 Manas MD, Domper A, Albillos A, et al. Endoscopic follow-up of gastric ulcer in a population at intermediate risk for gastric cancer. Rev Esp Enferm Dig. May. 2009;101(5):317-24. X-2, X-3, X-4. [pmid: 19527077].
1522 Mangan SA, Larsen PG, Hudson S. Overweight teens at increased risk for weight gain while using depot medroxyprogesterone acetate. J Pediatr Adolesc Gynecol. Apr. 2002;15(2):79-82. X-2. [pmid: 12057528].
1523 Mangano DT, Tudor IC, Dietzel C. The risk associated with aprotinin in cardiac surgery. N Engl J Med. Jan. 26. 2006;354(4):353-65. X-3. [pmid: 16436767].
1524 Mangoni AA, Woodman RJ, Gaganis P, et al. Use of non-steroidal anti-inflammatory drugs and risk of incident myocardial infarction and heart failure, and all-cause mortality in the Australian veteran community. Br J Clin Pharmacol. Jun. 2010;69(6):689-700. X-7. [pmid: 20565461].
1525 Mangoni AA, Woodman RJ, Gilbert AL, et al. Use of non-steroidal anti-inflammatory drugs and risk of ischemic and hemorrhagic stroke in the Australian veteran community. Pharmacoepidemiol Drug Saf. May. 2010;19(5):490-8. X-4, X-7. [pmid: 20437458].
1526 Manguso F, Riccio E, Nucci G, et al. Helicobacter pylori infection in bleeding peptic ulcer patients after non-steroidal antiinflammatory drug consumption. World J Gastroenterol. Oct. 28. 2011;17(40):4509-16. X-2. [pmid: 22110282].
1527 Manicourt DH, Bevilacqua M, Righini V, et al. Comparative effect of nimesulide and ibuprofen on the urinary levels of collagen type II C-telopeptide degradation products and on the serum levels of hyaluronan and matrix metalloproteinases-3 and -13 in patients with flare-up of osteoarthritis. Drugs R D. 2005;6(5):261-71. X-2. [pmid: 16128596].
1528 Manji RA, Grocott HP, Leake J, et al. Seizures following cardiac surgery: the impact of tranexamic acid and other risk factors. Can J Anaesth. Jan. 2012;59(1):6-13. X-8. [pmid: 22065333].
1529 Manning BJ, O'Brien N, Aravindan S, et al. The effect of aspirin on blood loss and transfusion requirements in patients with femoral neck fractures. Injury. Feb. 2004;35(2):121-4. X-2, X-4. [pmid: 14736467].
1530 Mansfield JC, Greenaway JR, Contractor BR, et al. Open access gastroscopy findings are unrelated to the use of aspirin and non-steroidal anti-inflammatory drugs. Br J Gen Pract. Dec. 1997;47(425):825-6. X-4. [pmid: 9463986].
1531 Manson JE, Hsia J, Johnson KC, et al. Estrogen plus progestin and the risk of coronary heart disease. N Engl J Med. Aug. 7. 2003;349(6):523-34. X-7. [pmid: 12904517].
1532 Mao K, Guillebaud J. Influence of removal of intrauterine contraceptive devices on colonisation of the cervix by actinomyces-like organisms. Contraception. Dec. 1984;30(6):535-44. X-2, X-4. [pmid: 6529911].
1533 Maoz KB, Brenner S. Drug rash with eosinophilia and systemic symptoms syndrome: sex and the causative agent. Skinmed. Nov-Dec. 2007;6(6):271-3. X-2, X-3, X-4. [pmid: 17975358].
1534 Marini H, Bitto A, Altavilla D, et al. Breast safety and efficacy of genistein aglycone for postmenopausal bone loss: a follow-up study. J Clin Endocrinol Metab. Dec. 2008;93(12):4787-96. X-2, X-4. [pmid: 18796517].
1535 Marini H, Bitto A, Altavilla D, et al. Efficacy of genistein aglycone on some cardiovascular risk factors and homocysteine levels: A follow-up study. Nutr Metab Cardiovasc Dis. Jun. 2010;20(5):332-40. X-2, X-4. [pmid: 19631515].
1536 Marks M, Gravitt PE, Gupta SB, et al. Combined oral contraceptive use increases HPV persistence but not new HPV detection in a cohort of women from Thailand. J Infect Dis. Nov. 15. 2011;204(10):1505-13. X-2. [pmid: 21964399].
1537 Marpeau L, Bouillie J, Barrat J, et al. Obstetrical advantages and perinatal risks of indomethacin: a report of 818 cases. Fetal Diagn Ther. Mar-Apr. 1994;9(2):110-5. X-2, X-4. [pmid: 8185837].
1538 Marshall SF, Bernstein L, Anton-Culver H, et al. Nonsteroidal anti-inflammatory drug use and breast cancer risk by stage and hormone receptor status. J Natl Cancer Inst. Jun. 1. 2005;97(11):805-12. X-4. [pmid: 15928301].
1539 Marteau P, Tennenbaum R, Elefant E, et al. Foetal outcome in women with inflammatory bowel disease treated during pregnancy with oral mesalazine microgranules. Aliment Pharmacol Ther. Nov. 1998;12(11):1101-8. X-2, X-3, X-4. [pmid: 9845399].
1540 Martin BK, Szekely C, Brandt J, et al. Cognitive function over time in the Alzheimer's Disease Anti-inflammatory Prevention Trial (ADAPT): results of a randomized, controlled trial of naproxen and celecoxib. Arch Neurol. Jul. 2008;65(7):896-905. X-7. [pmid: 18474729].
1541 Martin HL Jr., Nyange PM, Richardson BA, et al. Hormonal contraception, sexually transmitted diseases, and risk of heterosexual transmission of human immunodeficiency virus type 1. J Infect Dis. Oct. 1998;178(4):1053-9. X-8. [pmid: 9806034].
1542 Martin K, Breuer T, Gertler R, et al. Tranexamic acid versus varepsilon-aminocaproic acid: efficacy and safety in paediatric cardiac surgery. Eur J Cardiothorac Surg. Jun. 2011;39(6):892-7. X-2. [pmid: 21115357].
1543 Martin K, Knorr J, Breuer T, et al. Seizures after open heart surgery: comparison of epsilon-aminocaproic acid and tranexamic acid. J Cardiothorac Vasc Anesth. Feb. 2011;25(1):20-5. X-2. [pmid: 21272777].
1544 Martin K, Wiesner G, Breuer T, et al. The risks of aprotinin and tranexamic acid in cardiac surgery: a one-year follow-up of 1188 consecutive patients. Anesth Analg. Dec. 2008;107(6):1783-90. X-2. [pmid: 19020118].
1545 Martin RM, Biswas P, Mann RD. The incidence of adverse events and risk factors for upper gastrointestinal disorders associated with meloxicam use amongst 19,087 patients in general practice in England: cohort study. Br J Clin Pharmacol. Jul. 2000;50(1):35-42. X-4. [pmid: 10886116].
1546 Martinez-Ramirez HR, Jalomo-Martinez B, Cortes-Sanabria L, et al. Renal function preservation in type 2 diabetes mellitus patients with early nephropathy: a comparative prospective cohort study between primary health care doctors and a nephrologist. Am J Kidney Dis. Jan. 2006;47(1):78-87. X-2, X-3, X-4. [pmid: 16377388].
1547 Martini AC, Molina RI, Tissera AD, et al. Analysis of semen from patients chronically treated with low or moderate doses of aspirin-like drugs. Fertil Steril. Jul. 2003;80(1):221-2. X-2, X-6. [pmid: 12849830].
1548 Maru S, Koch GG, Stender M, et al. Antidiabetic drugs and heart failure risk in patients with type 2 diabetes in the U.K. primary care setting. Diabetes Care. Jan. 2005;28(1):20-6. X-3. [pmid: 15616228].
1549 Maruo T, Mishell DR, Ben-Chetrit A, et al. Vaginal rings delivering progesterone and estradiol may be a new method of hormone replacement therapy. Fertil Steril. Nov. 2002;78(5):1010-6. X-2, X-3, X-4. [pmid: 12413986].
1550 Mascarenhas L, van Beek A, Bennink HC, et al. A 2-year comparative study of endometrial histology and cervical cytology of contraceptive implant users in Birmingham, UK. Hum Reprod. Nov. 1998;13(11):3057-60. X-2, X-3, X-4. [pmid: 9853856].
1551 Massai MR, Diaz S, Quinteros E, et al. Contraceptive efficacy and clinical performance of Nestorone implants in postpartum women. Contraception. Dec. 2001;64(6):369-76. X-2, X-4. [pmid: 11834236].
1552 Massai MR, Pavez M, Fuentealba B, et al. Effect of intermittent treatment with mifepristone on bleeding patterns in Norplant implant users. Contraception. Jul. 2004;70(1):47-54. X-2, X-3, X-4. [pmid: 15208052].
1553 Massaro M, Di Carlo C, Gargano V, et al. Effects of the contraceptive patch and the vaginal ring on bone metabolism and bone mineral density: a prospective, controlled, randomized study. Contraception. Mar. 2010;81(3):209-14. X-2, X-4. [pmid: 20159176].
1554 Masse PG, Livingstone MM, Duguay C, et al. Testing the tyrosine/catecholamine hypothesis of oral contraceptive-induced psychological side-effects: a controlled study on triphasil. Ann Nutr Metab. 2001;45(3):102-9. X-2. [pmid: 11423701].
1555 Massimo Claar G, Monaco S, Del Veccho Blanco C, et al. Omeprazole 20 or 40 mg daily for healing gastroduodenal ulcers in patients receiving non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. May. 1998;12(5):463-8. X-2, X-3, X-4. [pmid: 9663727].
1556 Masso Gonzalez EL, Garcia Rodriguez LA. Proton pump inhibitors reduce the long-term risk of recurrent upper gastrointestinal bleeding: an observational study. Aliment Pharmacol Ther. Sep. 1. 2008;28(5):629-37. X-2, X-3, X-4. [pmid: 18616644].
1557 Mastalerz L, Sanak M, Gawlewicz-Mroczka A, et al. Prostaglandin E2 systemic production in patients with asthma with and without aspirin hypersensitivity. Thorax. Jan. 2008;63(1):27-34. X-3, X-4. [pmid: 17584993].
1558 Masters T, Everett S, May M, et al. Outcomes at 1 year for the first 200 patients fitted with GyneFix at Margaret Pyke Centre. Eur J Contracept Reprod Health Care. Jun. 2002;7(2):65-70. X-2, X-4. [pmid: 12201324].
1559 Matikainen M, Kangas E. Relation of the use of analgesics and non-steroidal anti-inflammatory drugs (NSAIDs) to upper gastrointestinal bleeding: a preliminary report of a Finnish case-control prospective study. Pharmacol Toxicol. Suppl 2. 1994;75:51-2. X-2. [pmid: 7816782].
1560 Matikainen M, Kangas E. Is there a relationship between the use of analgesics and non-steroidal anti- inflammatory drugs and acute upper gastrointestinal bleeding? A Finnish case-control prospective study. Scand J Gastroenterol. Sep. 1996;31(9):912-6. X-2, X-4. [pmid: 8888440].
1561 Matson SC, Henderson KA, McGrath GJ. Physical findings and symptoms of depot medroxyprogesterone acetate use in adolescent females. J Pediatr Adolesc Gynecol. Feb. 1997;10(1):18-23. X-2. [pmid: 9061630].
1562 Matsumoto T, Esaki M, Kurahara K, et al. Double-contrast barium enteroclysis as a patency tool for nonsteroidal anti-inflammatory drug-induced enteropathy. Dig Dis Sci. Nov. 2011;56(11):3247-53. X-2, X-3, X-4. [pmid: 21567189].
1563 Matsumoto T, Iida M, Matsui T, et al. Non-specific multiple ulcers of the small intestine unrelated to non-steroidal anti-inflammatory drugs. J Clin Pathol. Nov. 2004;57(11):1145-50. X-2, X-3, X-4. [pmid: 15509673].
1564 Matsumoto T, Nakamura S, Esaki M, et al. Endoscopic features of chronic nonspecific multiple ulcers of the small intestine: comparison with nonsteroidal anti-inflammatory drug-induced enteropathy. Dig Dis Sci. Aug. 2006;51(8):1357-63. X-2, X-3, X-4. [pmid: 16868823].
1565 Matsuno K, Kunihiro E, Yamatoya O, et al. Surveillance of adverse reactions due to ciprofloxacin in Japan. Drugs. Suppl 2. 1995;49:495-6. X-4. [pmid: 8549413].
1566 Matteson EL, Yachyshyn V, Yachyshyn J, et al. Trends in hospitalizations for gastrointestinal bleeding among patients with rheumatoid arthritis in Rochester, Minnesota, 1950-1991. J Rheumatol. Aug. 1995;22(8):1471-7. X-2, X-3, X-4. [pmid: 7473468].
1567 Matthewson K, Pugh S, Northfield TC. Which peptic ulcer patients bleed?. Gut. Jan. 1988;29(1):70-4. X-2, X-3. [pmid: 3343016].
1568 Matthieu L, Meuleman L, Van Hecke E, et al. Contact and photocontact allergy to ketoprofen. The Belgian experience. Contact Dermatitis. Apr. 2004;50(4):238-41. X-2, X-4. [pmid: 15186381].
1569 May FW, Rowett DS, Gilbert AL, et al. Outcomes of an educational-outreach service for community medical practitioners: non-steroidal anti-inflammatory drugs. Med J Aust. May. 17. 1999;170(10):471-4. X-2, X-3, X-4. [pmid: 10376022].
1570 Mazzuca SA, Brandt KD, Katz BP, et al. Comparison of general internists, family physicians, and rheumatologists managing patients with symptoms of osteoarthritis of the knee. Arthritis Care Res. Oct. 1997;10(5):289-99. X-2, X-3, X-4. [pmid: 9362595].
1571 McAdams M, Staffa JA, Dal Pan GJ. The concomitant prescribing of ethinyl estradiol/drospirenone and potentially interacting drugs. Contraception. Oct. 2007;76(4):278-81. X-4. [pmid: 17900437].
1572 McAfee AT, Koro C, Landon J, et al. Coronary heart disease outcomes in patients receiving antidiabetic agents. Pharmacoepidemiol Drug Saf. Jul. 2007;16(7):711-25. X-3. [pmid: 17551989].
1573 McAlister FA, Eurich DT, Majumdar SR, et al. The risk of heart failure in patients with type 2 diabetes treated with oral agent monotherapy. Eur J Heart Fail. Jul. 2008;10(7):703-8. X-3. [pmid: 18571471].
1574 McAlister FA, Ghali WA, Gong Y, et al. Aspirin use and outcomes in a community-based cohort of 7352 patients discharged after first hospitalization for heart failure. Circulation. Jun. 6. 2006;113(22):2572-8. X-4. [pmid: 16735672].
1575 McCarthy CJ, McDermott M, Hourihane D, et al. Chemical gastritis induced by naproxen in the absence of Helicobacter pylori infection. J Clin Pathol. Jan. 1995;48(1):61-3. X-2, X-4. [pmid: 7706522].
1576 McCarthy T, Ramachandran L, Huang HS, et al. Postabortion insertion of the Nova T and MLCu250: preliminary results of a comparative study. Adv Contracept. Jun. 1985;1(2):161-5. X-2, X-4. [pmid: 3842217].
1577 McFarlane-Anderson PE, Bazuaye N, Jackson MD, et al. Cervical dysplasia and cancer and the use of hormonal contraceptives in Jamaican women. BMC Womens Health. 2008;8:9. X-2. [pmid: 18513406].
1578 McGavigan CJ, Dockery P, Metaxa-Mariatou V, et al. Hormonally mediated disturbance of angiogenesis in the human endometrium after exposure to intrauterine levonorgestrel. Hum Reprod. Jan. 2003;18(1):77-84. X-2, X-3, X-4. [pmid: 12525444].
1579 McGettigan P, Han P, Henry D. Cyclooxygenase-2 inhibitors and coronary occlusion--exploring dose-response relationships. Br J Clin Pharmacol. Sep. 2006;62(3):358-65. X-2, X-4. [pmid: 16934052].
1580 McGettigan P, Han P, Jones L, et al. Selective COX-2 inhibitors, NSAIDs and congestive heart failure: differences between new and recurrent cases. Br J Clin Pharmacol. Jun. 2008;65(6):927-34. X-2, X-3, X-4. [pmid: 18384446].
1581 McGonigle KF, Karlan BY, Barbuto DA, et al. Development of endometrial cancer in women on estrogen and progestin hormone replacement therapy. Gynecol Oncol. Oct. 1994;55(1):126-32. X-2, X-4. [pmid: 7959253].
1582 McGough P, Bigrigg A. Effect of depot medroxyprogesterone acetate on bone density in a Scottish industrial city. Eur J Contracept Reprod Health Care. Sep. 2007;12(3):253-9. X-2. [pmid: 17763264].
1583 McGwin G Jr., Sims RV, Pulley L, et al. Relations among chronic medical conditions, medications, and automobile crashes in the elderly: a population-based case-control study. Am J Epidemiol. Sep. 1. 2000;152(5):424-31. X-2, X-3, X-4. [pmid: 10981455].
1584 McKenna PJ, Mylotte MJ. Laparoscopic removal of translocated intrauterine contraceptives devices. Br J Obstet Gynaecol. Feb. 1982;89(2):163-5. X-2, X-3, X-4. [pmid: 6461352].
1585 McKenna TJ, Cunningham SK. A role for a non-androgenic anovulant in the management of hirsutism. Ir J Med Sci. Jul. 1991;160(7):194-6. X-2, X-3, X-4. [pmid: 1757211].
1586 McLaurin VL, Dunson BA, Dunson TR. A comparative study of 35 mcg and 50 mcg combined oral contraceptives: results from a multicenter clinical trial. Contraception. Nov. 1991;44(5):489-503. X-4. [pmid: 1797464].
1587 McLeod RS, Wolff BG, Steinhart AH, et al. Prophylactic mesalamine treatment decreases postoperative recurrence of Crohn's disease. Gastroenterology. Aug. 1995;109(2):404-13. X-2, X-3, X-4. [pmid: 7615189].
1588 McMahon AD. Observation and experiment with the efficacy of drugs: a warning example from a cohort of nonsteroidal anti-inflammatory and ulcer-healing drug users. Am J Epidemiol. Sep. 15. 2001;154(6):557-62. X-4. [pmid: 11549561].
1589 McMahon AD, Evans JM, MacDonald TM. Hypersensitivity reactions associated with exposure to naproxen and ibuprofen: a cohort study. J Clin Epidemiol. Dec. 2001;54(12):1271-4. X-4. [pmid: 11750197].
1590 McPherson C, Gal P, Ransom JL, et al. Indomethacin pharmacodynamics are altered by surfactant: a possible challenge to current indomethacin dosing guidelines created before surfactant availability. Pediatr Cardiol. May. 2010;31(4):505-10. X-2, X-3, X-4. [pmid: 20063159].
1591 Meeker ND, Goldsby R, Terrill KR, et al. Dapsone therapy for children with immune thrombocytopenic purpura. J Pediatr Hematol Oncol. Feb. 2003;25(2):173-5. X-1, X-2, X-3, X-4. [pmid: 12571474].
1592 Mehta S, Dasarathy S, Tandon RK, et al. A prospective randomized study of the injurious effects of aspirin and naproxen on the gastroduodenal mucosa in patients with rheumatoid arthritis. Am J Gastroenterol. Aug. 1992;87(8):996-1000. X-2. [pmid: 1642224].
1593 Mehta S, Lang B. Long-term followup of naproxen-induced pseudoporphyria in juvenile rheumatoid arthritis. Arthritis Rheum. Oct. 1999;42(10):2252-4. X-2. [pmid: 10524703].
1594 Meirik O, Farley TM, Sivin I. Safety and efficacy of levonorgestrel implant, intrauterine device, and sterilization. Obstet Gynecol. Apr. 2001;97(4):539-47. X-4. [pmid: 11275025].
1595 Meirik O, Rowe PJ, Peregoudov A, et al. The frameless copper IUD (GyneFix) and the TCu380A IUD: results of an 8-year multicenter randomized comparative trial. Contraception. Aug. 2009;80(2):133-41. X-4. [pmid: 19631788].
1596 Meisel AD. Clinical benefits and comparative safety of piroxicam. Analysis of worldwide clinical trials data. Am J Med. Nov. 28. 1986;81(5B):15-21. X-1, X-4. [pmid: 3538866].
1597 Mejersjo C, Wenneberg B. Diclofenac sodium and occlusal splint therapy in TMJ osteoarthritis: a randomized controlled trial. J Oral Rehabil. Oct. 2008;35(10):729-38. X-2, X-3, X-4. [pmid: 18482350].
1598 Mellemkjaer L, Blot WJ, Sorensen HT, et al. Upper gastrointestinal bleeding among users of NSAIDs: a population-based cohort study in Denmark. Br J Clin Pharmacol. Feb. 2002;53(2):173-81. X-4. [pmid: 11851641].
1599 Meloni A, Melis M, Alba E, et al. Medical therapy in the management of preterm birth. J Matern Fetal Neonatal Med. Suppl 3. 2009;22:72-6. X-1. [pmid: 19925364].
1600 Mendoza N, Pison JA, Fernandez M, et al. Prospective, randomised study with three HRT regimens in postmenopausal women with an intact uterus. Maturitas. Apr. 25. 2002;41(4):289-98. X-2. [pmid: 12034516].
1601 Menges M, Chan CC, Zeitz M, et al. Higher concentration of matrix-metalloproteinase 1 (interstitial collagenase) in H. pylori-compared to NSAID-induced gastric ulcers. Z Gastroenterol. Nov. 2000;38(11):887-91. X-2, X-3, X-4. [pmid: 11132534].
1602 Menniti-Ippolito F, Sagliocca L, Da Cas R, et al. Niflumic acid and cutaneous reactions in children. Arch Dis Child. May. 2001;84(5):430-1. X-4. [pmid: 11316692].
1603 Ment LR, Oh W, Ehrenkranz RA, et al. Low-dose indomethacin and prevention of intraventricular hemorrhage: a multicenter randomized trial. Pediatrics. Apr. 1994;93(4):543-50. X-2, X-3, X-4. [pmid: 8134206].
1604 Ment LR, Vohr B, Allan W, et al. Outcome of children in the indomethacin intraventricular hemorrhage prevention trial. Pediatrics. Mar. 2000;105(3 Pt 1):485-91. X-2, X-4. [pmid: 10699097].
1605 Mercadante S, David F, Riina S, et al. Injustifiable use of gastroprotection in advanced cancer patients. Palliat Med. Oct. 2007;21(7):631-3. X-2, X-3, X-4. [pmid: 17942503].
1606 Mercadante S, Fusco F, Valle A, et al. Factors involved in gastrointestinal bleeding in advanced cancer patients followed at home. Support Care Cancer. Feb. 2004;12(2):95-8. X-2, X-3. [pmid: 14673626].
1607 Merki-Feld GS, Gosewinkel A, Imthurn B, et al. Tubal pathology: the role of hormonal contraception, intrauterine device use and Chlamydia trachomatis infection. Gynecol Obstet Invest. 2007;63(2):114-20. X-2, X-4. [pmid: 17095873].
1608 Merki-Feld GS, Neff M, Keller PJ. A 2-year prospective study on the effects of depot medroxyprogesterone acetate on bone mass-response to estrogen and calcium therapy in individual users. Contraception. Feb. 2003;67(2):79-86. X-2. [pmid: 12586317].
1609 Merki-Feld GS, Rosselli M, Dubey RK, et al. Long-term effects of combined oral contraceptives on markers of endothelial function and lipids in healthy premenopausal women. Contraception. Mar. 2002;65(3):231-6. X-2, X-4. [pmid: 11929645].
1610 Merki-Feld GS, Schwarz D, Imthurn B, et al. Partial and complete expulsion of the Multiload 375 IUD and the levonorgestrel-releasing IUD after correct insertion. Eur J Obstet Gynecol Reprod Biol. Mar. 2008;137(1):92-6. X-2. [pmid: 17353086].
1611 Merry AF, Sidebotham DA, Middleton NG, et al. Tenoxicam 20 mg or 40 mg after thoracotomy: a prospective, randomized, double-blind, placebo-controlled study. Anaesth Intensive Care. Apr. 2002;30(2):160-6. X-2, X-4. [pmid: 12002922].
1612 Mertens JC, Willemsen G, Van Saase JL, et al. Polymyalgia rheumatica and temporal arteritis: a retrospective study of 111 patients. Clin Rheumatol. Nov. 1995;14(6):650-5. X-2, X-4. [pmid: 8608683].
1613 Mesker T, van Rheenen PF, Norbruis OF, et al. Pediatric Crohn's disease activity at diagnosis, its influence on pediatrician's prescribing behavior, and clinical outcome 5 years later. Inflamm Bowel Dis. Nov. 2009;15(11):1670-7. X-2, X-3, X-4. [pmid: 19418567].
1614 Messeri A, Busoni P, Noccioli B, et al. Analgesic efficacy and tolerability of ketoprofen lysine salt vs paracetamol in common paediatric surgery. A randomized, single-blind, parallel, multicentre trial. Paediatr Anaesth. Sep. 2003;13(7):574-8. X-2, X-3, X-4. [pmid: 12950856].
1615 Metzner JE, Frank T, Kunz I, et al. Study on the pharmacokinetics of synthetic genistein after multiple oral intake in post-menopausal women. Arzneimittelforschung. 2009;59(10):513-20. X-2, X-3, X-4. [pmid: 19998579].
1616 Meunier A, Aspenberg P, Good L. Celecoxib does not appear to affect prosthesis fixation in total knee replacement: A randomized study using radiostereometry in 50 patients. Acta Orthop. Feb. 2009;80(1):46-50. X-2, X-3, X-4. [pmid: 19234885].
1617 Meunier A, Lisander B, Good L. Effects of celecoxib on blood loss, pain, and recovery of function after total knee replacement: a randomized placebo-controlled trial. Acta Orthop. Oct. 2007;78(5):661-7. X-2, X-3, X-4. [pmid: 17966026].
1618 Meyer AM, Ramzan NN, Heigh RI, et al. Relapse of inflammatory bowel disease associated with use of nonsteroidal anti-inflammatory drugs. Dig Dis Sci. Jan. 2006;51(1):168-72. X-2. [pmid: 16416231].
1619 Michaelis J, Michaelis H, Gluck E, et al. Prospective study of suspected associations between certain drugs administered during early pregnancy and congenital malformations. Teratology. Feb. 1983;27(1):57-64. X-4. [pmid: 6845218].
1620 Micu MC, Micu R, Ostensen M. Luteinized unruptured follicle syndrome increased by inactive disease and selective cyclooxygenase 2 inhibitors in women with inflammatory arthropathies. Arthritis Care Res (Hoboken). Sep. 2011;63(9):1334-8. X-2, X-3. [pmid: 21618455].
1621 Mikaeloff Y, Kezouh A, Suissa S. Nonsteroidal anti-inflammatory drug use and the risk of severe skin and soft tissue complications in patients with varicella or zoster disease. Br J Clin Pharmacol. Feb. 2008;65(2):203-9. X-4. [pmid: 18251759].
1622 Mikos M, Grzanka P, Sladek K, et al. High-resolution computed tomography evaluation of peripheral airways in asthma patients: comparison of focal and diffuse air trapping. Respiration. 2009;77(4):381-8. X-2, X-3, X-4. [pmid: 18577849].
1623 Milam MR, Pollock JW, Nick AM, et al. The effect of hormonal contraception on the adequacy of colposcopic examination of the cervix. Am J Obstet Gynecol. May. 2005;192(5):1368-9. X-2, X-3, X-4. [pmid: 15902111].
1624 Milano M. Increased risk for dental caries in asthmatic children. Tex Dent J. Sep. 1999;116(9):35-42. X-2. [pmid: 10860081].
1625 Miller K. Effect of gastric mucosal protection in nonrheumatoid patients with short-term nonsteroidal anti-inflammatory drug therapy: a prospective randomized multicenter study. Hepatogastroenterology. May-Jun. 1997;44(15):872-9. X-2, X-3, X-4. [pmid: 9222707].
1626 Miller L, Patton DL, Meier A, et al. Depomedroxyprogesterone-induced hypoestrogenism and changes in vaginal flora and epithelium. Obstet Gynecol. Sep. 2000;96(3):431-9. X-2. [pmid: 10960638].
1627 Millican S, Cottrell N, Green B. Do risk factors for lactic acidosis influence dosing of metformin?. J Clin Pharm Ther. Oct. 2004;29(5):449-54. X-2, X-4. [pmid: 15482389].
1628 Min KA, Zhu X, Oh JM, et al. Effect of oxolamine on anticoagulant effect of warfarin. Am J Health Syst Pharm. Jan. 15. 2006;63(2):153-6. X-4. [pmid: 16390929].
1629 Miner P, Hanauer S, Robinson M, et al. Safety and efficacy of controlled-release mesalamine for maintenance of remission in ulcerative colitis. Pentasa UC Maintenance Study Group. Dig Dis Sci. Feb. 1995;40(2):296-304. X-2, X-3, X-4. [pmid: 7851193].
1630 Minocha A, Greenbaum DS, Gardiner J. Effect of non-steroidal anti-inflammatory drugs on formation of gallbladder stones. Vet Hum Toxicol. Dec. 1994;36(6):514-6. X-2, X-4. [pmid: 7900267].
1631 Mira M, McNeil D, Fraser IS, et al. Mefenamic acid in the treatment of premenstrual syndrome. Obstet Gynecol. Sep. 1986;68(3):395-8. X-2, X-3, X-4. [pmid: 3526218].
1632 Mishell DR Jr., Roy S. Copper intrauterine contraceptive device event rates following insertion 4 to 8 weeks post partum. Am J Obstet Gynecol. May. 1. 1982;143(1):29-35. X-2, X-3, X-4. [pmid: 7081309].
1633 Misra JS, Engineer AD, Das K, et al. Cervical carcinogenesis and contraception. Diagn Cytopathol. 1991;7(4):346-52. X-3. [pmid: 1935511].
1634 Misra JS, Engineer AD, Tandon P. Cervical cytology associated with levonorgestrel contraception. Acta Cytol. Jan-Feb. 1995;39(1):45-9. X-2. [pmid: 7847008].
1635 Misra JS, Tandon P, Srivastava A, et al. Cervical cytological studies in women inserted with Norplant-I contraceptive. Diagn Cytopathol. Sep. 2003;29(3):136-9. X-2, X-4. [pmid: 12951680].
1636 Mita H, Higashi N, Taniguchi M, et al. Increase in urinary leukotriene B4 glucuronide concentration in patients with aspirin-intolerant asthma after intravenous aspirin challenge. Clin Exp Allergy. Aug. 2004;34(8):1262-9. X-2, X-3, X-4. [pmid: 15298568].
1637 Miyake K, Ueki N, Suzuki K, et al. Preventive therapy for non-steroidal anti-inflammatory drug-induced ulcers in Japanese patients with rheumatoid arthritis: the current situation and a prospective controlled-study of the preventive effects of lansoprazole or famotidine. Aliment Pharmacol Ther. Jun. Suppl 2. 2005;21:67-72. X-2, X-3, X-4. [pmid: 15943850].
1638 Mockenhaupt M, Kelly JP, Kaufman D, et al. The risk of Stevens-Johnson syndrome and toxic epidermal necrolysis associated with nonsteroidal antiinflammatory drugs: a multinational perspective. J Rheumatol. Oct. 2003;30(10):2234-40. X-4. [pmid: 14528522].
1639 Moffett BS, Wann TI, Carberry KE, et al. Safety of ketorolac in neonates and infants after cardiac surgery. Paediatr Anaesth. Apr. 2006;16(4):424-8. X-2, X-3, X-4. [pmid: 16618297].
1640 Moggia AV, Harris GS, Dunson TR, et al. A comparative study of a progestin-only oral contraceptive versus non-hormonal methods in lactating women in Buenos Aires, Argentina. Contraception. Jul. 1991;44(1):31-43. X-2, X-4. [pmid: 1893700].
1641 Moghetti P, Castello R, Negri C, et al. Metformin effects on clinical features, endocrine and metabolic profiles, and insulin sensitivity in polycystic ovary syndrome: a randomized, double-blind, placebo-controlled 6-month trial, followed by open, long-term clinical evaluation. J Clin Endocrinol Metab. Jan. 2000;85(1):139-46. X-2, X-3, X-4. [pmid: 10634377].
1642 Moghissi KS. Add-back therapy in the treatment of endometriosis: the North American experience. Br J Obstet Gynaecol. Oct. Suppl 14. 1996;103:14. X-2. [pmid: 8916981].
1643 Mogul HR, Peterson SJ, Weinstein BI, et al. Metformin and carbohydrate-modified diet: a novel obesity treatment protocol: preliminary findings from a case series of nondiabetic women with midlife weight gain and hyperinsulinemia. Heart Dis. Sep-Oct. 2001;3(5):285-92. X-2, X-3, X-4. [pmid: 11975807].
1644 Moise KJ Jr. Effect of advancing gestational age on the frequency of fetal ductal constriction in association with maternal indomethacin use. Am J Obstet Gynecol. May. 1993;168(5):1350-3. X-2, X-4. [pmid: 8498410].
1645 Mok CC, Lau CS, Wong RW. Clinical characteristics, treatment, and outcome of adult onset Still's disease in southern Chinese. J Rheumatol. Dec. 1998;25(12):2345-51. X-2, X-3, X-4. [pmid: 9858428].
1646 Molina RC, Sandoval JZ, Montero AV, et al. Comparative performance of a combined injectable contraceptive (50 mg norethisterone enanthate plus 5mg estradiol valerate) and a combined oral contraceptive (0.15 mg levonorgestrel plus 0.03 mg ethinyl estradiol) in adolescents. J Pediatr Adolesc Gynecol. Feb. 2009;22(1):25-31. X-2. [pmid: 19232299].
1647 Momoeda M, Harada T, Terakawa N, et al. Long-term use of dienogest for the treatment of endometriosis. J Obstet Gynaecol Res. Dec. 2009;35(6):1069-76. X-2. [pmid: 20025633].
1648 Mona Eng P, Seeger JD, Loughlin J, et al. Serum potassium monitoring for users of ethinyl estradiol/drospirenone taking medications predisposing to hyperkalemia: physician compliance and survey of knowledge and attitudes. Contraception. Feb. 2007;75(2):101-7. X-2, X-3, X-4. [pmid: 17241838].
1649 Monagle J, Molnar A, Shearer W. Oral medication for post-Caesarean analgesia. Aust N Z J Obstet Gynaecol. May. 1998;38(2):169-71. X-2, X-4. [pmid: 9653853].
1650 Montalto M, Curigliano V, Santoro L, et al. Prophylactic aspirin therapy does not increase faecal calprotectin concentrations. Eur J Gastroenterol Hepatol. Sep. 2006;18(9):965-7. X-2, X-3, X-4. [pmid: 16894309].
1651 Monteiro I, Bahamondes L, Diaz J, et al. Therapeutic use of levonorgestrel-releasing intrauterine system in women with menorrhagia: a pilot study(1). Contraception. May. 2002;65(5):325-8. X-2, X-3. [pmid: 12057782].
1652 Montes FR, Pardo DF, Carreno M, et al. Risk factors associated with postoperative seizures in patients undergoing cardiac surgery who received tranexamic acid: a case-control study. Ann Card Anaesth. Jan-Mar. 2012;15(1):6-12. X-2. [pmid: 22234015].
1653 Montes R, Nantes O, Alonso A, et al. The influence of polymorphisms of VKORC1 and CYP2C9 on major gastrointestinal bleeding risk in anticoagulated patients. Br J Haematol. Dec. 2008;143(5):727-33. X-2, X-3, X-4. [pmid: 18950464].
1654 Moodley M, Sewart S, Herrington CS, et al. The interaction between steroid hormones, human papillomavirus type 16, E6 oncogene expression, and cervical cancer. Int J Gynecol Cancer. Nov-Dec. 2003;13(6):834-42. X-2, X-3, X-4. [pmid: 14675321].
1655 Moon KW, Kim J, Kim JH, et al. Risk factors for acute kidney injury by non-steroidal anti-inflammatory drugs in patients with hyperuricaemia. Rheumatology (Oxford). Dec. 2011;50(12):2278-82. X-2. [pmid: 22019809].
1656 Moore N, Diris H, Martin K, et al. NSAID use profiles derived from reimbursement data in France. Therapie. Sep-Oct. 2004;59(5):541-6. X-2, X-3, X-4. [pmid: 15648307].
1657 Moore RA, Derry S, McQuay HJ. Cyclo-oxygenase-2 selective inhibitors and nonsteroidal anti-inflammatory drugs: balancing gastrointestinal and cardiovascular risk. BMC Musculoskelet Disord. 2007;8:73. X-4. [pmid: 17683540].
1658 Morabia A, Szklo M, Stewart W, et al. Consistent lack of association between breast cancer and oral contraceptives using either hospital or neighborhood controls. Prev Med. Mar. 1993;22(2):178-86. X-2, X-4. [pmid: 8483857].
1659 Morales WJ, Madhav H. Efficacy and safety of indomethacin compared with magnesium sulfate in the management of preterm labor: a randomized study. Am J Obstet Gynecol. Jul. 1993;169(1):97-102. X-2, X-4. [pmid: 8333483].
1660 Morant SV, Pettitt D, MacDonald TM, et al. Application of a propensity score to adjust for channelling bias with NSAIDs. Pharmacoepidemiol Drug Saf. Jun. 2004;13(6):345-53. X-4. [pmid: 15170763].
1661 Moreau C, Trussell J, Gilbert F, et al. Oral contraceptive tolerance: does the type of pill matter?. Obstet Gynecol. Jun. 2007;109(6):1277-85. X-4. [pmid: 17540798].
1662 Morgando A, Giordanino C, Baronio M, et al. Role of Helicobacter pylori infection in peptic ulcer haemorrhage. Minerva Med. Feb. 2006;97(1):47-50. X-2. [pmid: 16565698].
1663 Moride Y, Abenhaim L. Evidence of the depletion of susceptibles effect in non-experimental pharmacoepidemiologic research. J Clin Epidemiol. Jul. 1994;47(7):731-7. X-2, X-3, X-4. [pmid: 7722586].
1664 Moride Y, Ducruet T, Boivin JF, et al. Utilization of non-steroidal anti-inflammatory drugs in Quebec: adherence to the Canadian consensus on prescription guidelines. Can J Clin Pharmacol. Summer. 2005;12(2):e201-11. X-3, X-4. [pmid: 15998959].
1665 Moride Y, Ducruet T, Boivin JF, et al. Prescription channeling of COX-2 inhibitors and traditional nonselective nonsteroidal anti-inflammatory drugs: a population-based case-control study. Arthritis Res Ther. 2005;7(2):R333-42. X-4. [pmid: 15743481].
1666 Morimoto LM, Newcomb PA, Ulrich CM, et al. Risk factors for hyperplastic and adenomatous polyps: evidence for malignant potential?. Cancer Epidemiol Biomarkers Prev. Oct. 2002;11(10 Pt 1):1012-8. X-2, X-3, X-4. [pmid: 12376501].
1667 Morley-Forster P, Newton PT, Cook MJ. Ketorolac and indomethacin are equally efficacious for the relief of minor postoperative pain. Can J Anaesth. Dec. 1993;40(12):1126-30. X-2, X-3, X-4. [pmid: 8281587].
1668 Morris AJ, Murray L, Sturrock RD, et al. Short report: the effect of misoprostol on the anaemia of NSAID enteropathy. Aliment Pharmacol Ther. Jun. 1994;8(3):343-6. X-2, X-3, X-4. [pmid: 7918931].
1669 Morris CR, Harvey IM, Stebbings WS, et al. Anti-inflammatory drugs, analgesics and the risk of perforated colonic diverticular disease. Br J Surg. Oct. 2003;90(10):1267-72. X-4. [pmid: 14515298].
1670 Morrison C, Waszak C, Katz K, et al. Clinical outcomes of two early postpartum IUD insertion programs in Africa. Contraception. Jan. 1996;53(1):17-21. X-2, X-3, X-4. [pmid: 8631184].
1671 Morrison CS, Richardson BA, Celentano DD, et al. Prospective clinical trials designed to assess the use of hormonal contraceptives and risk of HIV acquisition. J Acquir Immune Defic Syndr. Mar. Suppl 1. 2005;38:S17-8. X-8. [pmid: 15867602].
1672 Mosis G, Dieleman JP, Stricker B, et al. A randomized database study in general practice yielded quality data but patient recruitment in routine consultation was not practical. J Clin Epidemiol. May. 2006;59(5):497-502. X-2, X-3, X-4. [pmid: 16632138].
1673 Motola D, Vargiu A, Leone R, et al. Hepatic adverse drug reactions: a case/non-case study in Italy. Eur J Clin Pharmacol. Jan. 2007;63(1):73-9. X-4. [pmid: 17119945].
1674 Motsko SP, Rascati KL, Busti AJ, et al. Temporal relationship between use of NSAIDs, including selective COX-2 inhibitors, and cardiovascular risk. Drug Saf. 2006;29(7):621-32. X-6, X-7. [pmid: 16808554].
1675 Moyes VJ, Metcalfe KA, Drake WM. Clinical use of cabergoline as primary and adjunctive treatment for acromegaly. Eur J Endocrinol. Nov. 2008;159(5):541-5. X-2, X-3, X-4. [pmid: 18708434].
1676 Mudd PA, Katial RK, Alam R, et al. Variations in expression of matrix metalloproteinase-9 and tissue inhibitor of metalloproteinase-1 in nasal mucosa of aspirin-sensitive versus aspirin-tolerant patients with nasal polyposis. Ann Allergy Asthma Immunol. Oct. 2011;107(4):353-9. X-2, X-3, X-4. [pmid: 21962096].
1677 Mudge DW, Tan KS, Miles R, et al. Intravenous versus oral iron supplementation for correction of post-transplant anaemia in renal transplant patients. BMC Nephrol. 2009;10:14. X-1, X-2, X-3, X-4. [pmid: 19500381].
1678 Mulberg AE, Linz C, Bern E, et al. Identification of nonsteroidal antiinflammatory drug-induced gastroduodenal injury in children with juvenile rheumatoid arthritis. J Pediatr. Apr. 1993;122(4):647-9. X-2. [pmid: 8463919].
1679 Muneyyirci-Delale O, Karacan M. Effect of norethindrone acetate in the treatment of symptomatic endometriosis. Int J Fertil Womens Med. Jan-Feb. 1998;43(1):24-7. X-2, X-3. [pmid: 9532466].
1680 Munger MA, Gardner SF, Ateshkadi A, et al. Misoprostol effects on diclofenac-induced cardiorenal changes in salt-sensitive patients with hypertension: the MEDIC Study. Pharmacotherapy. Jul. 2008;28(7):834-42. X-2, X-3, X-4. [pmid: 18576898].
1681 Munoz-Fernandez S, Hidalgo V, Fernandez-Melon J, et al. Sulfasalazine reduces the number of flares of acute anterior uveitis over a one-year period. J Rheumatol. Jun. 2003;30(6):1277-9. X-2, X-3, X-4. [pmid: 12784403].
1682 Munro FJ, Young SJ, Broome IJ, et al. Intravenous tenoxicam for analgesia following laparoscopic cholecystectomy. Anaesth Intensive Care. Feb. 1998;26(1):56-60. X-3, X-4. [pmid: 9513669].
1683 Murata Y, Itakura A, Matsuzawa K, et al. Possible antenatal and perinatal related factors in development of cystic periventricular leukomalacia. Brain Dev. Jan. 2005;27(1):17-21. X-2, X-3, X-4. [pmid: 15626536].
1684 Murkes D, Conner P, Leifland K, et al. Effects of percutaneous estradiol-oral progesterone versus oral conjugated equine estrogens-medroxyprogesterone acetate on breast cell proliferation and bcl-2 protein in healthy women. Fertil Steril. Mar. 1. 2011;95(3):1188-91. X-2. [pmid: 21067727].
1685 Muss HB, Case LD, Atkins JN, et al. Tamoxifen versus high-dose oral medroxyprogesterone acetate as initial endocrine therapy for patients with metastatic breast cancer: a Piedmont Oncology Association study. J Clin Oncol. Aug. 1994;12(8):1630-8. X-2, X-3, X-4. [pmid: 8040675].
1686 Muzii L, Marana R, Caruana P, et al. Postoperative administration of monophasic combined oral contraceptives after laparoscopic treatment of ovarian endometriomas: a prospective, randomized trial. Am J Obstet Gynecol. Sep. 2000;183(3):588-92. X-2, X-4. [pmid: 10992178].
1687 Myer L, Denny L, Wright TC, et al. Prospective study of hormonal contraception and women's risk of HIV infection in South Africa. Int J Epidemiol. Feb. 2007;36(1):166-74. X-8. [pmid: 17175547].
1688 Mylotte MJ, Loudon N. Interim insertion of Multiload Cu 250 IUCD. Br J Obstet Gynaecol. Sep. 1982;89(Suppl 4):41-2. X-2, X-4. [pmid: 6758838].
1689 Nachtigall LB, Valassi E, Lo J, et al. Gender effects on cardiac valvular function in hyperprolactinaemic patients receiving cabergoline: a retrospective study. Clin Endocrinol (Oxf). Jan. 2010;72(1):53-8. X-2. [pmid: 19508591].
1690 Nachtigall MJ, Smilen SW, Nachtigall RD, et al. Incidence of breast cancer in a 22-year study of women receiving estrogen-progestin replacement therapy. Obstet Gynecol. Nov. 1992;80(5):827-30. X-2, X-4. [pmid: 1328978].
1691 Nagata C, Matsushita Y, Inaba S, et al. Unapproved use of high-dose combined pills in Japan: a community study on prevalence and health characteristics of the users. Prev Med. Jul-Aug. 1997;26(4):565-9. X-4. [pmid: 9245680].
1692 Nahidi F, Jalalinia S. Comparing the complications of 2 copper intrauterine devices: T380A and Cu-Safe 300. East Mediterr Health J. Jan-Feb. 2008;14(1):95-102. X-2, X-4. [pmid: 18557456].
1693 Najam R, Agarwal D, Tyagi R, et al. Comparison of traneximic acid with a combination of traneximic acid and mefenamic acid in reducing menstrual blood loss in ovulatory dysfunctional uterine bleeding (DUB). Journal of Clinical and Diagnostic Research. 2010;4(5):3020-5. X-2, X-3, X-4.
1694 Nakaoka S, Ishizaki T, Urushihara H, et al. Echocardiography for the detection of valvulopathy associated with the use of ergot-derived dopamine agonists in patients with Parkinson's disease. Intern Med. 2011;50(7):687-94. X-2, X-7. [pmid: 21467699].
1695 Nakashima S, Arai S, Mizuno Y, et al. A clinical study of Japanese patients with ulcer induced by low-dose aspirin and other non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. Jun. Suppl 2. 2005;21:60-6. X-2. [pmid: 15943849].
1696 Nakayama M, Iwakiri R, Hara M, et al. Low-dose aspirin is a prominent cause of bleeding ulcers in patients who underwent emergency endoscopy. J Gastroenterol. 2009;44(9):912-8. X-2, X-4. [pmid: 19436943].
1697 Nakhai-Pour HR, Broy P, Sheehy O, et al. Use of nonaspirin nonsteroidal anti-inflammatory drugs during pregnancy and the risk of spontaneous abortion. CMAJ. Oct. 18. 2011;183(15):1713-20. X-4. [pmid: 21896698].
1698 Nanda K, Morrison CS, Kwok C, et al. Discontinuation of oral contraceptives and depot medroxyprogesterone acetate among women with and without HIV in Uganda, Zimbabwe and Thailand. Contraception. Jun. 2011;83(6):542-8. X-4. [pmid: 21570552].
1699 Nankhonya JM, Datta-Chaudhuri ML, Bhan GL. Acute upper gastrointestinal hemorrhage in older people: a prospective study in two neighboring districts. J Am Geriatr Soc. Jun. 1997;45(6):752-4. X-2, X-3, X-4. [pmid: 9180673].
1700 Nappi C, Tommaselli GA, Morra I, et al. Efficacy and tolerability of oral bovine lactoferrin compared to ferrous sulfate in pregnant women with iron deficiency anemia: a prospective controlled randomized study. Acta Obstet Gynecol Scand. 2009;88(9):1031-5. X-2, X-3, X-4. [pmid: 19639462].
1701 Narendranathan M, Chitra P, Kurien M, et al. Ketotifen in prevention of indomethacin-induced gastropathy. Indian J Gastroenterol. Apr-Jun. 1999;18(2):76-7. X-2, X-3, X-4. [pmid: 10319538].
1702 Neafsey PJ. Double trouble: acetaminophen increases the risk of upper GI complications for people taking NSAIDs. Home Healthc Nurse. Sep. 2004;22(9):641-2. X-1. [pmid: 15359177].
1703 Nelson C, Rigel D, Smith S, et al. Phase IV open-label assessment of the treatment of actinic keratosis with 3.0% diclofenac sodium topical gel (Solaraze). J Drugs Dermatol. Jul-Aug. 2004;3(4):401-7. X-2, X-3, X-4. [pmid: 15303784].
1704 Nesher G, Sonnenblick M, Dwolatzky T. Protective effect of misoprostol on indomethacin induced renal dysfunction in elderly patients. J Rheumatol. Apr. 1995;22(4):713-6. X-2, X-3, X-4. [pmid: 7791169].
1705 Nesher G, Zimran A, Hershko C. Reduced incidence of hyperkalemia and azotemia in patients receiving sulindac compared with indomethacin. Nephron. 1988;48(4):291-5. X-2, X-4. [pmid: 3362274].
1706 Ness RB, Dodge RC, Edwards RP, et al. Contraception methods, beyond oral contraceptives and tubal ligation, and risk of ovarian cancer. Ann Epidemiol. Mar. 2011;21(3):188-96. X-4. [pmid: 21109450].
1707 Nessa A, Latif SA, Uddin MM, et al. Serum HDL-cholesterol in women using low dose oral contraceptives. Mymensingh Med J. Jul. 2007;16(2 Suppl):S3-6. X-2, X-4. [pmid: 17917628].
1708 Nestrud RM, Hill DE, Arrington RW, et al. Indomethacin treatment in patent ductus arteriosus. A double-blind study utilizing indomethacin plasma levels. Dev Pharmacol Ther. 1980;1(2-3):125-36. X-2, X-3, X-4. [pmid: 6765467].
1709 Nettis E, Colanardi MC, Ferrannini A, et al. Immune tolerance to drugs. (II).: Long-term tolerability of nimesulide in patients with NSAID hypersensitivity. Immunopharmacol Immunotoxicol. Aug. 2004;26(3):469-80. X-2, X-4. [pmid: 15518179].
1710 Nettis E, Colanardi MC, Ferrannini A, et al. Short-term and long-term tolerability of rofecoxib in patients with prior reactions to nonsteroidal anti-inflammatory drugs. Ann Allergy Asthma Immunol. Jan. 2005;94(1):29-33. X-2, X-3, X-4. [pmid: 15702812].
1711 Nettis E, Colanardi MC, Paola RD, et al. Tolerance test in patients with multiple drug allergy syndrome. Immunopharmacol Immunotoxicol. Nov. 2001;23(4):617-26. X-2, X-3, X-4. [pmid: 11792020].
1712 Nettis E, Marcandrea M, Maggio GD, et al. Retrospective analysis of drug-induced urticaria and angioedema: a survey of 2287 patients. Immunopharmacol Immunotoxicol. Nov. 2001;23(4):585-95. X-4. [pmid: 11792017].
1713 Neumann K. NIMRA-survey: NSAIDs impact on mortality. Results of an Austrian Survey in 2006. Wien Med Wochenschr. 2008;158(3-4):119-26. X-4. [pmid: 18330529].
1714 Neutel CI, Appel WC. The effect of alcohol abuse on the risk of NSAID-related gastrointestinal events. Ann Epidemiol. May. 2000;10(4):246-50. X-4. [pmid: 10854958].
1715 Neven P, Lunde T, Benedetti-Panici P, et al. A multicentre randomised trial to compare uterine safety of raloxifene with a continuous combined hormone replacement therapy containing oestradiol and norethisterone acetate. BJOG. Feb. 2003;110(2):157-67. X-2, X-3, X-4. [pmid: 12618160].
1716 Ng A, Temple A, Smith G, et al. Early analgesic effects of parecoxib versus ketorolac following laparoscopic sterilization: a randomized controlled trial. Br J Anaesth. Jun. 2004;92(6):846-9. X-2, X-3, X-4. [pmid: 15121727].
1717 Ng FH, Wong SY, Lam KF, et al. Famotidine is inferior to pantoprazole in preventing recurrence of aspirin-related peptic ulcers or erosions. Gastroenterology. Jan. 2010;138(1):82-8. X-2, X-3, X-4. [pmid: 19837071].
1718 Ng JL, Morgan DJ, Loh NK, et al. Life-threatening hypokalaemia associated with ibuprofen-induced renal tubular acidosis. Med J Aust. Mar. 21. 2011;194(6):313-6. X-2, X-4. [pmid: 21426288].
1719 Ng JM, Mellor DD, Masson EA, et al. Sulphonyurea as a cause of severe hypoglycaemia in the community. Prim Care Diabetes. Apr. 2010;4(1):61-3. X-2, X-4. [pmid: 20064751].
1720 Ng PC, So KW, Fok TF, et al. Comparing sulindac with indomethacin for closure of ductus arteriosus in preterm infants. J Paediatr Child Health. Aug. 1997;33(4):324-8. X-2, X-4. [pmid: 9323621].
1721 Ng YW, Liang S, Singh K. Effects of Mirena (levonorgestrel-releasing intrauterine system) and Ortho Gynae T380 intrauterine copper device on lipid metabolism--a randomized comparative study. Contraception. Jan. 2009;79(1):24-8. X-2, X-3. [pmid: 19041437].
1722 Nguyen M, Dougados M, Berdah L, et al. Diacerhein in the treatment of osteoarthritis of the hip. Arthritis Rheum. Apr. 1994;37(4):529-36. X-2, X-4. [pmid: 8147930].
1723 Nguyen P, Nava-Ocampo A, Levy A, et al. Effect of iron content on the tolerability of prenatal multivitamins in pregnancy. BMC Pregnancy Childbirth. 2008;8:17. X-2, X-4. [pmid: 18482454].
1724 Nichols GA, Conner C, Brown JB. Initial nonadherence, primary failure and therapeutic success of metformin monotherapy in clinical practice. Curr Med Res Opin. Sep. 2010;26(9):2127-35. X-3, X-4. [pmid: 20658898].
1725 Nickel JC, Forrest JB, Tomera K, et al. Pentosan polysulfate sodium therapy for men with chronic pelvic pain syndrome: a multicenter, randomized, placebo controlled study. J Urol. Apr. 2005;173(4):1252-5. X-2, X-3, X-4. [pmid: 15758763].
1726 Nicolau-Raducu R, Subramaniam K, Marquez J, et al. Safety and efficacy of tranexamic acid compared with aprotinin in thoracic aortic surgery with deep hypothermic circulatory arrest. J Cardiothorac Vasc Anesth. Feb. 2010;24(1):73-9. X-2. [pmid: 19717314].
1727 Niebyl JR, Blake DA, White RD, et al. The inhibition of premature labor with indomethacin. Am J Obstet Gynecol. Apr. 15. 1980;136(8):1014-9. X-2, X-3, X-4. [pmid: 7369252].
1728 Nielsen GL, Sorensen HT, Larsen H, et al. Risk of adverse birth outcome and miscarriage in pregnant users of non-steroidal anti-inflammatory drugs: population based observational study and case-control study. BMJ. Feb. 3. 2001;322(7281):266-70. X-4. [pmid: 11157526].
1729 Nielsen GL, Sorensen HT, Mellemkjoer L, et al. Risk of hospitalization resulting from upper gastrointestinal bleeding among patients taking corticosteroids: a register-based cohort study. Am J Med. Nov. 2001;111(7):541-5. X-4. [pmid: 11705430].
1730 Nielsen NC, Nygren KG, Allonen H. Three years of experience after post-abortal insertion of Nova-T and Copper-T-200. Acta Obstet Gynecol Scand. 1984;63(3):261-4. X-2, X-3, X-4. [pmid: 6730944].
1731 Niemi T, Tanskanen P, Taxell C, et al. Effects of nonsteroidal anti-inflammatory drugs on hemostasis in patients with aneurysmal subarachnoid hemorrhage. J Neurosurg Anesthesiol. Jul. 1999;11(3):188-94. X-2, X-4. [pmid: 10414674].
1732 Nishiike S, Kato T, Nagai M, et al. Preoperative flurbiprofen for pain prevention after tonsillectomy in adults. J Clin Anesth. Dec. 2007;19(8):596-600. X-2, X-3, X-4. [pmid: 18083473].
1733 Niv Y, Battler A, Abuksis G, et al. Endoscopy in asymptomatic minidose aspirin consumers. Dig Dis Sci. Jan. 2005;50(1):78-80. X-2, X-4. [pmid: 15712641].
1734 Niwa K, Onogi K, Wu Y, et al. Clinical implication of medroxyprogesterone acetate against advanced ovarian carcinoma: a pilot study. Eur J Gynaecol Oncol. 2008;29(3):252-5. X-2, X-3, X-4. [pmid: 18592789].
1735 Niwa Y, Nakamura M, Miyahara R, et al. Geranylgeranylacetone protects against diclofenac-induced gastric and small intestinal mucosal injuries in healthy subjects: a prospective randomized placebo-controlled double-blind cross-over study. Digestion. 2009;80(4):260-6. X-2, X-3, X-4. [pmid: 19844108].
1736 Niwa Y, Nakamura M, Ohmiya N, et al. Efficacy of rebamipide for diclofenac-induced small-intestinal mucosal injuries in healthy subjects: a prospective, randomized, double-blinded, placebo-controlled, cross-over study. J Gastroenterol. 2008;43(4):270-6. X-2, X-3, X-4. [pmid: 18458842].
1737 Noble PW, Albera C, Bradford WZ, et al. Pirfenidone in patients with idiopathic pulmonary fibrosis (CAPACITY): two randomised trials. Lancet. May. 21. 2011;377(9779):1760-9. X-2, X-3, X-4. [pmid: 21571362].
1738 Noerpramana NP. A cohort study of Norplant implant: side-effects and acceptance. Adv Contracept. Jun. 1995;11(2):97-114. X-2, X-4. [pmid: 7491860].
1739 Noerpramana NP. Blood-lipid fractions: the side-effects and continuation of Norplant use. Adv Contracept. Mar. 1997;13(1):13-37. X-2, X-4. [pmid: 9181182].
1740 Noize P, Benard-Laribiere A, Aulois-Griot M, et al. Cutaneous adverse effects of ketoprofen for topical use: clinical patterns and costs. Am J Clin Dermatol. 2010;11(2):131-6. X-2, X-4. [pmid: 20141234].
1741 Noren GN, Sundberg R, Bate A, et al. A statistical methodology for drug-drug interaction surveillance. Stat Med. Jul. 20. 2008;27(16):3057-70. X-1, X-4. [pmid: 18344185].
1742 Norgard B, Fonager K, Pedersen L, et al. Birth outcome in women exposed to 5-aminosalicylic acid during pregnancy: a Danish cohort study. Gut. Feb. 2003;52(2):243-7. X-2, X-4. [pmid: 12524407].
1743 Norgard B, Pedersen L, Johnsen SP, et al. COX-2-selective inhibitors and the risk of upper gastrointestinal bleeding in high-risk patients with previous gastrointestinal diseases: a population-based case-control study. Aliment Pharmacol Ther. Apr. 1. 2004;19(7):817-25. X-4. [pmid: 15043523].
1744 Norton ME, Merrill J, Cooper BA, et al. Neonatal complications after the administration of indomethacin for preterm labor. N Engl J Med. Nov. 25. 1993;329(22):1602-7. X-2, X-3, X-4. [pmid: 8232428].
1745 Ntaios G, Chatzinikolaou A, Kaiafa G, et al. Evaluation of use of proton pump inhibitors in Greece. Eur J Intern Med. Mar. 2009;20(2):171-3. X-3, X-4. [pmid: 19327607].
1746 Nunes AP, Lapane KL, Weinstock MA. Association between non-steroidal anti-inflammatory drugs and keratinocyte carcinomas of the skin among participants in the Veterans Affairs Topical Tretinoin Chemoprevention Trial. Pharmacoepidemiol Drug Saf. Sep. 2011;20(9):922-9. X-2. [pmid: 21688346].
1747 Nygren KG, Nielsen NC, Pyorala T, et al. Intrauterine contraception with Nova-T and copper-T-200 during three years. Contraception. Nov. 1981;24(5):529-42. X-2, X-4. [pmid: 7032839].
1748 O'Brien FB, Stewart WC, Sturtevant FM. Incidence of pelvic inflammatory disease in clinical trials with Cu-7 (intrauterine copper contraceptive): a statistical analysis. Contraception. Feb. 1983;27(2):111-22. X-4. [pmid: 6851553].
1749 O'Connor R, O'Leary M, Ballot J, et al. A phase I clinical and pharmacokinetic study of the multi-drug resistance protein-1 (MRP-1) inhibitor sulindac, in combination with epirubicin in patients with advanced cancer. Cancer Chemother Pharmacol. Jan. 2007;59(1):79-87. X-2, X-3, X-4. [pmid: 16642371].
1750 Odin P, Oehlwein C, Storch A, et al. Efficacy and safety of high-dose cabergoline in Parkinson's disease. Acta Neurol Scand. Jan. 2006;113(1):18-24. X-2. [pmid: 16367894].
1751 Odmark IS, Jonsson B, Backstrom T. Bleeding patterns in postmenopausal women using continuous combination hormone replacement therapy with conjugated estrogen and medroxyprogesterone acetate or with 17beta-estradiol and norethindrone acetate. Am J Obstet Gynecol. May. 2001;184(6):1131-8. X-2, X-3, X-4. [pmid: 11349178].
1752 O'Donovan DJ, Baetiong A, Adams K, et al. Necrotizing enterocolitis and gastrointestinal complications after indomethacin therapy and surgical ligation in premature infants with patent ductus arteriosus. J Perinatol. Jun. 2003;23(4):286-90. X-2, X-4. [pmid: 12774134].
1753 Oeda T, Masaki M, Yamamoto K, et al. High risk factors for valvular heart disease from dopamine agonists in patients with Parkinson's disease. J Neural Transm. Feb. 2009;116(2):171-8. X-2. [pmid: 19082526].
1754 Ofori B, Oraichi D, Blais L, et al. Risk of congenital anomalies in pregnant users of non-steroidal anti-inflammatory drugs: A nested case-control study. Birth Defects Res B Dev Reprod Toxicol. Aug. 2006;77(4):268-79. X-4. [pmid: 16929547].
1755 Oh JM, Kim SH, Suh CH, et al. Lack of association of glutathione S-transferase P1 Ile105Val polymorphism with aspirin-intolerant asthma. Korean J Intern Med. Sep. 2005;20(3):232-6. X-2, X-3, X-4. [pmid: 16295782].
1756 Ojala R, Ikonen S, Tammela O. Perinatal indomethacin treatment and neonatal complications in preterm infants. Eur J Pediatr. Mar. 2000;159(3):153-5. X-2, X-4. [pmid: 10664225].
1757 Ojala R, Ruuska T, Karikoski R, et al. Gastroesophageal endoscopic findings and gastrointestinal symptoms in preterm neonates with and without perinatal indomethacin exposure. J Pediatr Gastroenterol Nutr. Feb. 2001;32(2):182-8. X-2, X-4. [pmid: 11321390].
1758 Ojule JD, Oriji VK, Okongwu C. A five year review of the complications of progestogen only injectable contraceptive at the University of Port-Harcourt Teaching Hospital. Niger J Med. Jan-Mar. 2010;19(1):87-95. X-2. [pmid: 20232762].
1759 Okie S. Raising the safety bar--the FDA's coxib meeting. N Engl J Med. Mar. 31. 2005;352(13):1283-5. X-1. [pmid: 15800221].
1760 Okunlola MA, Owonikoko KM, Roberts OA, et al. Discontinuation pattern among IUCD users at the family planning clinic, University College Hospital, Ibadan. J Obstet Gynaecol. Feb. 2006;26(2):152-6. X-2, X-4. [pmid: 16483976].
1761 Oldfield K, Milne R, Vessey M. The effects on mortality of the use of combined oral contraceptives. Br J Fam Plann. Apr. 1998;24(1):2-6. X-4. [pmid: 9719700].
1762 Olokoba AB, Olokoba LB, Jimoh AA. Upper gastrointestinal tract bleeding in Ilorin, Nigeria--a report of 30 cases. Niger J Clin Pract. Sep. 2009;12(3):240-4. X-2, X-4. [pmid: 19803017].
1763 Olsen JC, McGrath NA, Schwarz DG, et al. A double-blind randomized clinical trial evaluating the analgesic efficacy of ketorolac versus butorphanol for patients with suspected biliary colic in the emergency department. Acad Emerg Med. Aug. 2008;15(8):718-22. X-2, X-3, X-4. [pmid: 18637080].
1764 Olsen NJ, Branch VK, Jonnala G, et al. Phase 1, placebo-controlled, dose escalation trial of chicory root extract in patients with osteoarthritis of the hip or knee. BMC Musculoskelet Disord. 2010;11:156. X-2, X-3, X-4. [pmid: 20618964].
1765 Omar HA, Zakharia RM, Kanungo S, et al. Incidence of galactorrhea in young women using Depot-Medroxyprogesterone Acetate. ScientificWorldJournal. 2006;6:538-41. X-2. [pmid: 16680366].
1766 Onder G, Penninx BW, Landi F, et al. Depression and adverse drug reactions among hospitalized older adults. Arch Intern Med. Feb. 10. 2003;163(3):301-5. X-7. [pmid: 12578510].
1767 Ong TZ, Hawkey CJ, Ho KY. Nonsteroidal anti-inflammatory drug use is a significant cause of peptic ulcer disease in a tertiary hospital in Singapore: a prospective study. J Clin Gastroenterol. Oct. 2006;40(9):795-800. X-2, X-3. [pmid: 17016134].
1768 Ono M, Miki N, Amano K, et al. Individualized high-dose cabergoline therapy for hyperprolactinemic infertility in women with micro- and macroprolactinomas. J Clin Endocrinol Metab. Jun. 2010;95(6):2672-9. X-2, X-3. [pmid: 20357175].
1769 Ono M, Miki N, Kawamata T, et al. Prospective study of high-dose cabergoline treatment of prolactinomas in 150 patients. J Clin Endocrinol Metab. Dec. 2008;93(12):4721-7. X-2, X-3. [pmid: 18812485].
1770 Onodera T, Majima T, Sawaguchi N, et al. Risk of deep venous thrombosis in drain clamping with tranexamic acid and carbazochrome sodium sulfonate hydrate in total knee arthroplasty. J Arthroplasty. Jan. 2012;27(1):105-8. X-2. [pmid: 21435821].
1771 Ooba N, Yamaguchi T, Kubota K. The impact in Japan of regulatory action on prescribing of dopamine receptor agonists: analysis of a claims database between 2005 and 2008. Drug Saf. Apr. 1. 2011;34(4):329-38. X-3, X-4, X-8. [pmid: 21417505].
1772 Ootani H, Iwakiri R, Shimoda R, et al. Role of Helicobacter pylori infection and nonsteroidal anti-inflammatory drug use in bleeding peptic ulcers in Japan. J Gastroenterol. Jan. 2006;41(1):41-6. X-2, X-3, X-4. [pmid: 16501856].
1773 Opatrny L, Dell'Aniello S, Assouline S, et al. Hormone replacement therapy use and variations in the risk of breast cancer. BJOG. Jan. 2008;115(2):169-75. discussion 75. X-7. [pmid: 18081598].
1774 Orlowski JP. Whatever happened to Reye's syndrome? Did it ever really exist?. Crit Care Med. Aug. 1999;27(8):1582-7. X-2, X-3, X-4. [pmid: 10470768].
1775 Ornbjerg LM, Andersen HB, Kryger P, et al. What do patients in rheumatologic care know about the risks of NSAIDs?. J Clin Rheumatol. Apr. 2008;14(2):69-73. X-2, X-3, X-4. [pmid: 18391673].
1776 Orr-Walker BJ, Evans MC, Ames RW, et al. The effect of past use of the injectable contraceptive depot medroxyprogesterone acetate on bone mineral density in normal post-menopausal women. Clin Endocrinol (Oxf). Nov. 1998;49(5):615-8. X-2, X-4. [pmid: 10197077].
1777 Ortayli N, Bulut A, Sahin T, et al. Immediate postabortal contraception with the levonorgestrel intrauterine device, Norplant, and traditional methods. Contraception. Jun. 2001;63(6):309-14. X-2, X-4. [pmid: 11672552].
1778 Ortonne JP, Queille-Roussel C, Duteil L. 3% diclofenac in 2.5% hyaluronic acid (Solaraze) does not induce photosensitivity or phototoxicity alone or in combination with sunscreens. Eur J Dermatol. Jul-Aug. 2006;16(4):385-90. X-2, X-4. [pmid: 16935795].
1779 Ostensen M, Ostensen H. Safety of nonsteroidal antiinflammatory drugs in pregnant patients with rheumatic disease. J Rheumatol. Jun. 1996;23(6):1045-9. X-2, X-4. [pmid: 8782138].
1780 Otley CC, Fewkes JL, Frank W, et al. Complications of cutaneous surgery in patients who are taking warfarin, aspirin, or nonsteroidal anti-inflammatory drugs. Arch Dermatol. Feb. 1996;132(2):161-6. X-2, X-4. [pmid: 8629823].
1781 Owens JM, Shroyer KR, Kingdom TT. Expression of cyclooxygenase and lipoxygenase enzymes in nasal polyps of aspirin-sensitive and aspirin-tolerant patients. Arch Otolaryngol Head Neck Surg. Jun. 2006;132(6):579-87. X-2, X-3, X-4. [pmid: 16785401].
1782 Owen-Smith V, Hannaford PC, Warskyj M, et al. Effects of changes in smoking status on risk estimates for myocardial infarction among women recruited for the Royal College of General Practitioners' Oral Contraception Study in the UK. J Epidemiol Community Health. Jul. 1998;52(7):420-4. X-4. [pmid: 9799875].
1783 Ozcagli E, Sardas S, Biri A. Assessment of DNA damage in postmenopausal women under hormone replacement therapy. Maturitas. Jul. 16. 2005;51(3):280-5. X-2, X-4. [pmid: 15978971].
1784 Ozdil B, Cosar A, Akkiz H, et al. Atherosclerosis and acetylsalicylic acid are independent risk factors for hemorrhage in patients with gastric or duodenal ulcer. Anadolu Kardiyol Derg. Feb. 2011;11(1):53-6. X-2, X-3, X-4. [pmid: 21220246].
1785 Ozkaya-Bayazit E, Bayazit H, Ozarmagan G. Drug related clinical pattern in fixed drug eruption. Eur J Dermatol. Jun. 2000;10(4):288-91. X-2. [pmid: 10846256].
1786 P S, P M, Pr S. Systemic adverse drug reactions: a preliminary report from the regional pharmacovigilance center, western Nepal. Pak J Pharm Sci. Oct. 2008;21(4):465-7. X-2, X-4. [pmid: 18930872].
1787 Pacor ML, Di Lorenzo G, Mansueto P, et al. Relationship between human leucocyte antigen class I and class II and chronic idiopathic urticaria associated with aspirin and/or NSAIDs hypersensitivity. Mediators Inflamm. 2006;2006(5):62489. X-2, X-3, X-4. [pmid: 17392574].
1788 Paganini-Hill A, Clark LJ, Henderson VW, et al. Clock drawing: analysis in a retirement community. J Am Geriatr Soc. Jul. 2001;49(7):941-7. X-3, X-4. [pmid: 11527486].
1789 Page AJ, Reid SA, Speedy DB, et al. Exercise-associated hyponatremia, renal function, and nonsteroidal antiinflammatory drug use in an ultraendurance mountain run. Clin J Sport Med. Jan. 2007;17(1):43-8. X-2, X-4. [pmid: 17304005].
1790 Page J, Henry D. Consumption of NSAIDs and the development of congestive heart failure in elderly patients: an underrecognized public health problem. Arch Intern Med. Mar. 27. 2000;160(6):777-84. X-2. [pmid: 10737277].
1791 Pakalnis A, Butz C, Splaingard D, et al. Emotional problems and prevalence of medication overuse in pediatric chronic daily headache. J Child Neurol. Dec. 2007;22(12):1356-9. X-2, X-3, X-4. [pmid: 18174551].
1792 Pakarinen P, Luukkainen T. Five years' experience with a small intracervical/intrauterine levonorgestrel-releasing device. Contraception. Nov. 2005;72(5):342-5. X-2, X-4. [pmid: 16246659].
1793 Pakarinen P, Luukkainen T, Elomaa K, et al. A 12-month comparative clinical investigation of a levonorgestrel-releasing intracervical device situated in the uterine cavity or cervical canal. Contraception. Sep. 1996;54(3):187-92. X-2. [pmid: 8899261].
1794 Pakarinen PI, Suvisaari J, Luukkainen T, et al. Intracervical and fundal administration of levonorgestrel for contraception: endometrial thickness, patterns of bleeding, and persisting ovarian follicles. Fertil Steril. Jul. 1997;68(1):59-64. X-2, X-3, X-4. [pmid: 9207585].
1795 Pal S, Bhattacharya KF, Agapito C, et al. A study of excessive daytime sleepiness and its clinical significance in three groups of Parkinson's disease patients taking pramipexole, cabergoline and levodopa mono and combination therapy. J Neural Transm. 2001;108(1):71-7. X-2. [pmid: 11261748].
1796 Pala L, Monami M, Lamanna C, et al. Failure to metformin and insulin secretagogue monotherapy: an observational cohort study. Acta Diabetol. Dec. 2010;47(Suppl 1):7-11. X-2, X-3, X-4. [pmid: 19290462].
1797 Palayekar V, Joshi JV, Hazari KT, et al. Chlamydia trachomatis detected in cervical smears from Copper-T users by DFA test. Adv Contracept. Jun. 1996;12(2):145-52. X-2, X-4. [pmid: 8863910].
1798 Palikhe NS, Kim SH, Cho BY, et al. Association of three sets of high-affinity IgE receptor (FcepsilonR1) polymorphisms with aspirin-intolerant asthma. Respir Med. Aug. 2008;102(8):1132-9. X-2, X-3, X-4. [pmid: 18595682].
1799 Palma-Carlos AG, Medina M, Palma-Carlos ML. Prevalence of drug allergy in an out-patient population. Eur Ann Allergy Clin Immunol. May. 2006;38(5):142-5. X-2. [pmid: 17058844].
1800 Palmer K. The Vioxx fallout. Minn Med. Mar. 2005;88(3):26-30. X-1. [pmid: 15852592].
1801 Palomba S, Falbo A, Di Cello A, et al. Does metformin affect the ovarian response to gonadotropins for in vitro fertilization treatment in patients with polycystic ovary syndrome and reduced ovarian reserve? A randomized controlled trial. Fertil Steril. Nov. 2011;96(5):1128-33. X-2, X-3. [pmid: 21917254].
1802 Palomba S, Falbo A, Russo T, et al. Insulin sensitivity after metformin suspension in normal-weight women with polycystic ovary syndrome. J Clin Endocrinol Metab. Aug. 2007;92(8):3128-35. X-2, X-3, X-4. [pmid: 17519312].
1803 Palomba S, Orio F Jr., Nardo LG, et al. Metformin administration versus laparoscopic ovarian diathermy in clomiphene citrate-resistant women with polycystic ovary syndrome: a prospective parallel randomized double-blind placebo-controlled trial. J Clin Endocrinol Metab. Oct. 2004;89(10):4801-9. X-2, X-3, X-4. [pmid: 15472166].
1804 Palomba S, Orio F Jr., Russo T, et al. BsmI vitamin D receptor genotypes influence the efficacy of antiresorptive treatments in postmenopausal osteoporotic women. A 1-year multicenter, randomized and controlled trial. Osteoporos Int. Aug. 2005;16(8):943-52. X-2, X-3, X-4. [pmid: 15739035].
1805 Pan YS, Chen LT, Tseng CA, et al. Clinical and endoscopic features of non-steroidal anti-inflammatory drug-induced colorectal ulcerations. J Formos Med Assoc. Nov. 2005;104(11):804-10. X-4. [pmid: 16496059].
1806 Pandi SP, Hadjar LN, Prihyugiharto T. Introductory trial of the once-a-month injectable contraceptive, Cyclofem, in Indonesia. Adv Contracept. Mar. 1993;9(1):33-40. X-3, X-4. [pmid: 8342452].
1807 Pandya BJ, Bron M, McCall T, et al. Achieving glycemic goal with initial versus sequential combination therapy using metformin and pioglitazone in type 2 diabetes mellitus. Curr Med Res Opin. Jan. 2011;27(1):189-95. X-2, X-3. [pmid: 21142610].
1808 Pang W, Mok MS, Ku MC, et al. Patient-controlled analgesia with morphine plus lysine acetyl salicylate. Anesth Analg. Oct. 1999;89(4):995-8. X-2, X-4. [pmid: 10512278].
1809 Panidis D, Georgopoulos NA, Piouka A, et al. The impact of oral contraceptives and metformin on anti-Mullerian hormone serum levels in women with polycystic ovary syndrome and biochemical hyperandrogenemia. Gynecol Endocrinol. Aug. 2011;27(8):587-92. X-2, X-3. [pmid: 20836726].
1810 Pantalone KM, Kattan MW, Yu C, et al. The risk of developing coronary artery disease or congestive heart failure, and overall mortality, in type 2 diabetic patients receiving rosiglitazone, pioglitazone, metformin, or sulfonylureas: a retrospective analysis. Acta Diabetol. Jun. 2009;46(2):145-54. X-3. [pmid: 19194648].
1811 Pantoja M, Medeiros T, Baccarin MC, et al. Variations in body mass index of users of depot-medroxyprogesterone acetate as a contraceptive. Contraception. Feb. 2010;81(2):107-11. X-2. [pmid: 20103446].
1812 Papadima A, Lagoudianakis EE, Antonakis PT, et al. Parecoxib vs. lornoxicam in the treatment of postoperative pain after laparoscopic cholecystectomy: a prospective randomized placebo-controlled trial. Eur J Anaesthesiol. Feb. 2007;24(2):154-8. X-2, X-3, X-4. [pmid: 16938157].
1813 Papatheodoridis GV, Papadelli D, Cholongitas E, et al. Effect of helicobacter pylori infection on the risk of upper gastrointestinal bleeding in users of nonsteroidal anti-inflammatory drugs. Am J Med. May. 1. 2004;116(9):601-5. X-2, X-3, X-4. [pmid: 15093756].
1814 Paquette L, Friedlich P, Ramanathan R, et al. Concurrent use of indomethacin and dexamethasone increases the risk of spontaneous intestinal perforation in very low birth weight neonates. J Perinatol. Aug. 2006;26(8):486-92. X-2, X-4. [pmid: 16791261].
1815 Pardo Cabello AJ, Gonzalez Contreras LG, Manzano Gamero MV, et al. Prevalence of fatal adverse drug reactions in hospitalized patients. Int J Clin Pharmacol Ther. Oct. 2009;47(10):596-602. X-2. [pmid: 19825322].
1816 Pareja JA, Caminero AB, Franco E, et al. Dose, efficacy and tolerability of long-term indomethacin treatment of chronic paroxysmal hemicrania and hemicrania continua. Cephalalgia. Nov. 2001;21(9):906-10. X-2, X-4. [pmid: 11903285].
1817 Parikh A, Scadding GK, Gray P, et al. High levels of nitric oxide synthase activity are associated with nasal polyp tissue from aspirin-sensitive asthmatics. Acta Otolaryngol. Apr. 2002;122(3):302-5. X-2, X-3, X-4. [pmid: 12030579].
1818 Parikh V, Gandhi AS. Safety of copper T as contraceptive after caesarean section. J Indian Med Assoc. May. 1989;87(5):113-5. X-2, X-3, X-4. [pmid: 2600433].
1819 Parilla BV, Grobman WA, Holtzman RB, et al. Indomethacin tocolysis and risk of necrotizing enterocolitis. Obstet Gynecol. Jul. 2000;96(1):120-3. X-2, X-4. [pmid: 10862854].
1820 Park HK, Lee SH, Chu K, et al. Effects of celecoxib on volumes of hematoma and edema in patients with primary intracerebral hemorrhage. J Neurol Sci. Apr. 15. 2009;279(1-2):43-6. X-2, X-4. [pmid: 19168192].
1821 Park JJ, Kim JW, Kim HJ, et al. The prevalence of and risk factors for Barrett's esophagus in a Korean population: A nationwide multicenter prospective study. J Clin Gastroenterol. Nov-Dec. 2009;43(10):907-14. X-4. [pmid: 19417682].
1822 Park JS, Chang HS, Park CS, et al. Association analysis of cysteinyl-leukotriene receptor 2 (CYSLTR2) polymorphisms with aspirin intolerance in asthmatics. Pharmacogenet Genomics. Jul. 2005;15(7):483-92. X-2, X-3, X-4. [pmid: 15970796].
1823 Park SY, Moon SH, Park MS, et al. The effects of ketorolac injected via patient controlled analgesia postoperatively on spinal fusion. Yonsei Med J. Apr. 30. 2005;46(2):245-51. X-2, X-4. [pmid: 15861498].
1824 Parkin L, Sharples K, Hernandez RK, et al. Risk of venous thromboembolism in users of oral contraceptives containing drospirenone or levonorgestrel: nested case-control study based on UK General Practice Research Database. BMJ. 2011;342:d2139. X-2, X-4. [pmid: 21511804].
1825 Parthasarathi G, Ramesh M, Nyfort-Hansen K, et al. Clinical pharmacy in a South Indian teaching hospital. Ann Pharmacother. May. 2002;36(5):927-32. X-2, X-3, X-4. [pmid: 11978174].
1826 Partridge CG, Campbell JH, Alvarado F. The effect of platelet-altering medications on bleeding from minor oral surgery procedures. J Oral Maxillofac Surg. Jan. 2008;66(1):93-7. X-2. [pmid: 18083421].
1827 Pashankar DS, Bishop WP, Mitros FA. Chemical gastropathy: a distinct histopathologic entity in children. J Pediatr Gastroenterol Nutr. Nov. 2002;35(5):653-7. X-2. [pmid: 12454581].
1828 Pasina L, Nobili A, Tettamanti M, et al. Co-prescription of gastroprotective agents in patients taking non-selective NSAIDs or COX-2 selective inhibitors: analysis of prescriptions. Int J Clin Pharmacol Ther. Nov. 2010;48(11):735-43. X-4. [pmid: 20979932].
1829 Paspatis GA, Matrella E, Kapsoritakis A, et al. An epidemiological study of acute upper gastrointestinal bleeding in Crete, Greece. Eur J Gastroenterol Hepatol. Nov. 2000;12(11):1215-20. X-2. [pmid: 11111778].
1830 Pasquale SA, Knuppel RA, Owens AG, et al. Irregular bleeding, body mass index and coital frequency in Norplant contraceptive users. Contraception. Aug. 1994;50(2):109-16. X-2, X-4. [pmid: 7956210].
1831 Passalacqua G, Milanese M, Mincarini M, et al. Single-dose oral tolerance test with alternative compounds for the management of adverse reactions to drugs. Int Arch Allergy Immunol. Nov. 2002;129(3):242-7. X-2. [pmid: 12444322].
1832 Passarelli MC, Jacob-Filho W, Figueras A. Adverse drug reactions in an elderly hospitalised population: inappropriate prescription is a leading cause. Drugs Aging. 2005;22(9):767-77. X-2, X-4. [pmid: 16156680].
1833 Pastuszak A, Pinelli M, Koren G. Pregnancy outcome following fetal exposure to tiaprofenic acid in the first trimester. Am J Perinatol. Sep. 1993;10(5):354-7. X-2, X-3, X-4. [pmid: 8240592].
1834 Patel BR. A comparative study of subsyde-CR versus meloxicam in rheumatic disorders. J Indian Med Assoc. May. 2000;98(5):250-2. X-4. [pmid: 11002624].
1835 Patel H, Barr A, Jeejeebhoy KN. Renal effects of long-term treatment with 5-aminosalicylic acid. Can J Gastroenterol. Mar. 2009;23(3):170-6. X-2, X-4. [pmid: 19319380].
1836 Patel P, Khulusi S, Mendall MA, et al. Prospective screening of dyspeptic patients by Helicobacter pylori serology. Lancet. Nov. 18. 1995;346(8986):1315-8. X-2, X-3, X-4. [pmid: 7475768].
1837 Patel RM, Marfatia YS. Clinical study of cutaneous drug eruptions in 200 patients. Indian J Dermatol Venereol Leprol. Jul-Aug. 2008;74(4):430. X-2, X-4. [pmid: 18810845].
1838 Pathan E, Gaitonde S, Rajadhyaksha S, et al. A longitudinal study of serum creatinine levels in patients of rheumatoid arthritis on long term NSAID therapy. J Assoc Physicians India. Nov. 2003;51:1045-9. X-2. [pmid: 15260386].
1839 Patino FG, Olivieri J, Allison JJ, et al. Nonsteroidal antiinflammatory drug toxicity monitoring and safety practices. J Rheumatol. Dec. 2003;30(12):2680-8. X-2, X-3, X-4. [pmid: 14719213].
1840 Patterson MK, Castellsague J, Walker AM. Hospitalization for peptic ulcer and bleeding in users of selective COX-2 inhibitors and nonselective NSAIDs with special reference to celecoxib. Pharmacoepidemiol Drug Saf. Oct. 2008;17(10):982-8. X-4. [pmid: 18711705].
1841 Pavlicevic I, Kuzmanic M, Rumboldt M, et al. Interaction between antihypertensives and NSAIDs in primary care: a controlled trial. Can J Clin Pharmacol. Fall. 2008;15(3):e372-82. X-2, X-3. [pmid: 18953082].
1842 Pawaskar MD, Blickensderfer AL, Hoogwerf BJ, et al. Hypoglycemia in patients with type 2 diabetes using concomitant exenatide BID and long-acting insulin therapy. J Med Econ. 2011;14(6):705-8. X-3, X-8. [pmid: 21892855].
1843 Pearce HM, Layton D, Wilton LV, et al. Deep vein thrombosis and pulmonary embolism reported in the Prescription Event Monitoring Study of Yasmin. Br J Clin Pharmacol. Jul. 2005;60(1):98-102. X-4. [pmid: 15963100].
1844 Peck JD, Hulka BS, Poole C, et al. Steroid hormone levels during pregnancy and incidence of maternal breast cancer. Cancer Epidemiol Biomarkers Prev. Apr. 2002;11(4):361-8. X-2, X-3, X-4. [pmid: 11927496].
1845 Peckham GJ, Miettinen OS, Ellison RC, et al. Clinical course to 1 year of age in premature infants with patent ductus arteriosus: results of a multicenter randomized trial of indomethacin. J Pediatr. Aug. 1984;105(2):285-91. X-2, X-4. [pmid: 6379136].
1846 Pecora PG, Kaplan B. Corticosteroids and ulcers: is there an association?. Ann Pharmacother. Jul-Aug. 1996;30(7-8):870-2. X-1, X-2. [pmid: 8826575].
1847 Pedersen OD, Jensen HK. Long-term treatment with transcutaneous estradiol and oral medroxyprogesterone acetate. Acta Obstet Gynecol Scand. Dec. 1992;71(8):593-8. X-2, X-4. [pmid: 1336917].
1848 Pedersen-Bjergaard U, Andersen M, Hansen PB. Thrombocytopenia induced by noncytotoxic drugs in Denmark 1968-91. J Intern Med. Jun. 1996;239(6):509-15. X-2. [pmid: 8656144].
1849 Peers T, Stevens JE, Graham J, et al. Norplant implants in the UK: first year continuation and removals. Contraception. Jun. 1996;53(6):345-51. X-3, X-4. [pmid: 8773421].
1850 Peltier AP. Practical management of NSAID gastropathy in rheumatic patients. Scand J Rheumatol Suppl. 1989;78:12-7. discussion 30-2. X-1, X-3, X-4. [pmid: 2786645].
1851 Penning-van Beest F, Erkens J, Petersen KU, et al. Main comedications associated with major bleeding during anticoagulant therapy with coumarins. Eur J Clin Pharmacol. Jul. 2005;61(5-6):439-44. X-4, X-8. [pmid: 15947920].
1852 Penning-van Beest FJ, Koerselman J, Herings RM. Quantity and quality of potential drug interactions with coumarin anticoagulants in the Netherlands. Pharm World Sci. Dec. 2007;29(6):671-5. X-4. [pmid: 17453356].
1853 Penston JG, Wormsley KG. Nine years of maintenance treatment with ranitidine for patients with duodenal ulcer disease. Aliment Pharmacol Ther. Oct. 1992;6(5):629-45. X-2, X-4. [pmid: 1420753].
1854 Penta de Peppo A, Pierri MD, Scafuri A, et al. Intraoperative antifibrinolysis and blood-saving techniques in cardiac surgery. Prospective trial of 3 antifibrinolytic drugs. Tex Heart Inst J. 1995;22(3):231-6. X-2, X-3, X-4. [pmid: 7580360].
1855 Pentti K, Honkanen R, Tuppurainen MT, et al. Hormone replacement therapy and mortality in 52- to 70-year-old women: the Kuopio Osteoporosis Risk Factor and Prevention Study. Eur J Endocrinol. Jan. 2006;154(1):101-7. X-4, X-7. [pmid: 16381998].
1856 Perdriger A, Mariette X, Kuntz JL, et al. Safety of infliximab used in combination with leflunomide or azathioprine in daily clinical practice. J Rheumatol. May. 2006;33(5):865-9. X-2, X-4. [pmid: 16652418].
1857 Perez Gutthann S, Garcia Rodriguez LA. The increased risk of hospitalizations for acute liver injury in a population with exposure to multiple drugs. Epidemiology. Nov. 1993;4(6):496-501. X-4. [pmid: 8268277].
1858 Perez Gutthann S, Garcia Rodriguez LA, Raiford DS, et al. Nonsteroidal anti-inflammatory drugs and the risk of hospitalization for acute renal failure. Arch Intern Med. Nov. 25. 1996;156(21):2433-9. X-4. [pmid: 8944736].
1859 Perez-Gutthann S, Garcia-Rodriguez LA, Duque-Oliart A, et al. Low-dose diclofenac, naproxen, and ibuprofen cohort study. Pharmacotherapy. Jul. 1999;19(7):854-9. X-4. [pmid: 10417034].
1860 Perez-Ruiz F, Calabozo M, Herrero-Beites AM, et al. Improvement of renal function in patients with chronic gout after proper control of hyperuricemia and gouty bouts. Nephron. Nov. 2000;86(3):287-91. X-2. [pmid: 11096285].
1861 Perneger TV, Whelton PK, Klag MJ. Risk of kidney failure associated with the use of acetaminophen, aspirin, and nonsteroidal antiinflammatory drugs. N Engl J Med. Dec. 22. 1994;331(25):1675-9. X-2. [pmid: 7969358].
1862 Perrone J, Phillips C, Gaieski D. Occult metformin toxicity in three patients with profound lactic acidosis. J Emerg Med. Mar. 2011;40(3):271-5. X-2. [pmid: 18571361].
1863 Persson I, Adami HO, Norell SE, et al. Evaluation of a prescription based record-linkage model for epidemiological studies of long-term adverse effects of drugs--with special regard to combined oral contraceptives. Eur J Clin Pharmacol. 1991;40(5):489-93. X-1, X-4. [pmid: 1884723].
1864 Persson I, Thurfjell E, Bergstrom R, et al. Hormone replacement therapy and the risk of breast cancer. Nested case-control study in a cohort of Swedish women attending mammography screening. Int J Cancer. Sep. 4. 1997;72(5):758-61. X-4, X-7. [pmid: 9311590].
1865 Persson PE, Nilsson OS, Berggren AM. Do non-steroidal anti-inflammatory drugs cause endoprosthetic loosening? A 10-year follow-up of a randomized trial on ibuprofen for prevention of heterotopic ossification after hip arthroplasty. Acta Orthop. Dec. 2005;76(6):735-40. X-2, X-4. [pmid: 16470423].
1866 Peters N, Jay N, Barraud D, et al. Metformin-associated lactic acidosis in an intensive care unit. Crit Care. 2008;12(6):R149. X-8. [pmid: 19036140].
1867 Petersen KR, Brooks L, Jacobsen N, et al. Clinical performance of intrauterine devices in nulligravidae: is the length of the endometrial cavity of significance?. Acta Eur Fertil. Jul-Aug. 1991;22(4):225-8. X-2, X-3, X-4. [pmid: 1844327].
1868 Petersen KR, Christiansen E, Madsbad S, et al. Metabolic and fibrinolytic response to changed insulin sensitivity in users of oral contraceptives. Contraception. Dec. 1999;60(6):337-44. X-2, X-4. [pmid: 10715368].
1869 Petersen KR, Skouby SO, Sidelmann J, et al. Assessment of endothelial function during oral contraception in women with insulin-dependent diabetes mellitus. Metabolism. Nov. 1994;43(11):1379-83. X-2, X-3. [pmid: 7968593].
1870 Petric M, Tasic L, Sukljevic S. Nonsteroidal anti-inflammatory drug usage and gastrointestinal outcomes in the Republic of Serbia. J Pain Palliat Care Pharmacother. 2009;23(1):40-7. X-4. [pmid: 19296354].
1871 Petty GW, Brown RD Jr., Whisnant JP, et al. Frequency of major complications of aspirin, warfarin, and intravenous heparin for secondary stroke prevention. A population-based study. Ann Intern Med. Jan. 5. 1999;130(1):14-22. X-2, X-4. [pmid: 9890845].
1872 Pham T, Le Henanff A, Ravaud P, et al. Evaluation of the symptomatic and structural efficacy of a new hyaluronic acid compound, NRD101, in comparison with diacerein and placebo in a 1 year randomised controlled study in symptomatic knee osteoarthritis. Ann Rheum Dis. Dec. 2004;63(12):1611-7. X-2, X-3, X-4. [pmid: 15331394].
1873 Phemister DA, Laurent S, Harrison FN Jr. Use of Norplant contraceptive implants in the immediate postpartum period: safety and tolerance. Am J Obstet Gynecol. Jan. 1995;172(1 Pt 1):175-9. X-2, X-4. [pmid: 7847530].
1874 Phupong V, Sophonsritsuk A, Taneepanichskul S. The effect of tranexamic acid for treatment of irregular uterine bleeding secondary to Norplant use. Contraception. Mar. 2006;73(3):253-6. X-2, X-3, X-4. [pmid: 16472565].
1875 Pierce SJ, Gazvani MR, Farquharson RG. Long-term use of gonadotropin-releasing hormone analogs and hormone replacement therapy in the management of endometriosis: a randomized trial with a 6-year follow-up. Fertil Steril. Nov. 2000;74(5):964-8. X-2, X-4. [pmid: 11056241].
1876 Pietrzak B, Kaminski P, Wielgos M, et al. Combined oral contraception in women after renal transplantation. Neuro Endocrinol Lett. Oct. 2006;27(5):679-82. X-2, X-4. [pmid: 17159814].
1877 Piette F, Teillet L, Naudin R, et al. Efficacy of misoprostol in the prophylaxis of gastroduodenal lesions induced by short-term nonsteroidal antiinflammatory drug therapy in elderly patients. A multicenter double-blind, placebo-controlled trial. Rev Rhum Engl Ed. Apr. 1997;64(4):259-66. X-2, X-3, X-4. [pmid: 9178399].
1878 Pikkarainen E, Lehtonen-Veromaa M, Mottonen T, et al. Estrogen-progestin contraceptive use during adolescence prevents bone mass acquisition: a 4-year follow-up study. Contraception. Sep. 2008;78(3):226-31. X-2. [pmid: 18692613].
1879 Pillai L, Burnett BP, Levy RM. GOAL: multicenter, open-label, post-marketing study of flavocoxid, a novel dual pathway inhibitor anti-inflammatory agent of botanical origin. Curr Med Res Opin. May. 2010;26(5):1055-63. X-2, X-4. [pmid: 20225990].
1880 Piller R, Chang-Claude J, Linseisen J. Plasma enterolactone and genistein and the risk of premenopausal breast cancer. Eur J Cancer Prev. Jun. 2006;15(3):225-32. X-2, X-3, X-4. [pmid: 16679865].
1881 Pilotto A, Franceschi M, Leandro G, et al. Proton-pump inhibitors reduce the risk of uncomplicated peptic ulcer in elderly either acute or chronic users of aspirin/non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. Nov. 15. 2004;20(10):1091-7. X-7. [pmid: 15569111].
1882 Pilotto A, Franceschi M, Longoa MG, et al. Helicobacter pylori infection and the prevention of peptic ulcer with proton pump inhibitors in elderly subjects taking low-dose aspirin. Dig Liver Dis. Oct. 2004;36(10):666-70. X-2, X-3, X-4. [pmid: 15506665].
1883 Pilotto A, Leandro G, Di Mario F, et al. Role of Helicobacter pylori infection on upper gastrointestinal bleeding in the elderly: a case-control study. Dig Dis Sci. Mar. 1997;42(3):586-91. X-2. [pmid: 9073143].
1884 Pilotto A, Seripa D, Franceschi M, et al. Genetic susceptibility to nonsteroidal anti-inflammatory drug-related gastroduodenal bleeding: role of cytochrome P450 2C9 polymorphisms. Gastroenterology. Aug. 2007;133(2):465-71. X-2, X-3, X-4. [pmid: 17681167].
1885 Pinheiro SP, Tworoger SS, Cramer DW, et al. Use of nonsteroidal antiinflammatory agents and incidence of ovarian cancer in 2 large prospective cohorts. Am J Epidemiol. Jun. 1. 2009;169(11):1378-87. X-4. [pmid: 19342401].
1886 Pini LA, Sternieri E. Active reporting scheme: an example to evaluate specific adverse drug reactions. Acta Physiol Hung. 1990;75(Suppl):237-8. X-4. [pmid: 2371875].
1887 Pink D, Lindner T, Mrozek A, et al. Harm or benefit of hormonal treatment in metastatic low-grade endometrial stromal sarcoma: single center experience with 10 cases and review of the literature. Gynecol Oncol. Jun. 2006;101(3):464-9. X-2, X-4. [pmid: 16368128].
1888 Piper JM, Ray WA, Daugherty JR, et al. Corticosteroid use and peptic ulcer disease: role of nonsteroidal anti-inflammatory drugs. Ann Intern Med. May. 1. 1991;114(9):735-40. X-4, X-7. [pmid: 2012355].
1889 Piya-Anant M, Koetsawang S, Patrasupapong N, et al. Effectiveness of Cyclofem in the treatment of depot medroxyprogesterone acetate induced amenorrhea. Contraception. Jan. 1998;57(1):23-8. X-2, X-3, X-4. [pmid: 9554247].
1890 Plaza V, Serrano J, Picado C, et al. Frequency and clinical characteristics of rapid-onset fatal and near-fatal asthma. Eur Respir J. May. 2002;19(5):846-52. X-2, X-3, X-4. [pmid: 12030723].
1891 Plu-Bureau G, Le MG, Thalabard JC, et al. Percutaneous progesterone use and risk of breast cancer: results from a French cohort study of premenopausal women with benign breast disease. Cancer Detect Prev. 1999;23(4):290-6. X-2, X-4. [pmid: 10403900].
1892 Pochobradsky MG, Mele G, Beretta A, et al. Post-marketing survey of nimesulide in the short-term treatment of osteoarthritis. Drugs Exp Clin Res. 1991;17(3):197-204. X-4. [pmid: 1914847].
1893 Pohjolainen T, Jekunen A, Autio L, et al. Treatment of acute low back pain with the COX-2-selective anti-inflammatory drug nimesulide: results of a randomized, double-blind comparative trial versus ibuprofen. Spine (Phila Pa 1976). Jun. 15. 2000;25(12):1579-85. X-3, X-4, X-5. [pmid: 10851109].
1894 Polaneczky M, Guarnaccia M, Alon J, et al. Early experience with the contraceptive use of depot medroxyprogesterone acetate in an inner-city clinic population. Fam Plann Perspect. Jul-Aug. 1996;28(4):174-8. X-2. [pmid: 8853283].
1895 Polati E, Finco G, Gottin L, et al. Prospective randomized double-blind trial of neurolytic coeliac plexus block in patients with pancreatic cancer. Br J Surg. Feb. 1998;85(2):199-201. X-2, X-3, X-4. [pmid: 9501815].
1896 Polimeni G, Salvo F, Cutroneo P, et al. Adverse reactions induced by NSAIDs and antibacterials: analysis of spontaneous reports from the Sicilian regional database. Drug Saf. 2006;29(5):449-59. X-2. [pmid: 16689558].
1897 Pongsatha S, Muttarak M, Chaovisitseree S, et al. Mammographic changes related to different types of hormonal therapies. J Med Assoc Thai. Feb. 2006;89(2):123-9. X-2. [pmid: 16578996].
1898 Pongwecharak J, Tengmeesri N, Malanusorn N, et al. Prescribing metformin in type 2 diabetes with a contraindication: prevalence and outcome. Pharm World Sci. Aug. 2009;31(4):481-6. X-3. [pmid: 19462255].
1899 Pookarnjanamorakot C, Laohacharoensombat W, Jaovisidha S. The clinical efficacy of piroxicam fast-dissolving dosage form for postoperative pain control after simple lumbar spine surgery: a double-blinded randomized study. Spine (Phila Pa 1976). Mar. 1. 2002;27(5):447-51. X-2, X-3, X-4. [pmid: 11880827].
1900 Pope J, Jerome D, Fenlon D, et al. Frequency of adverse drug reactions in patients with systemic lupus erythematosus. J Rheumatol. Mar. 2003;30(3):480-4. X-2, X-4. [pmid: 12610805].
1901 Post MS, Rosing J, Van Der Mooren MJ, et al. Increased resistance to activated protein C after short-term oral hormone replacement therapy in healthy post-menopausal women. Br J Haematol. Dec. 2002;119(4):1017-23. X-2, X-3, X-4. [pmid: 12472583].
1902 Potter LS, Dalberth BT, Canamar R, et al. Depot medroxyprogesterone acetate pioneers. A retrospective study at a North Carolina Health Department. Contraception. Nov. 1997;56(5):305-12. X-2. [pmid: 9437559].
1903 Pradhan BB, Tatsumi RL, Gallina J, et al. Ketorolac and spinal fusion: does the perioperative use of ketorolac really inhibit spinal fusion?. Spine (Phila Pa 1976). Sep. 1. 2008;33(19):2079-82. X-2, X-3, X-4. [pmid: 18698276].
1904 Prakash J, Niwas SS, Parekh A, et al. Multiple myeloma--presenting as acute kidney injury. J Assoc Physicians India. Jan. 2009;57:23-6. X-2, X-3, X-4. [pmid: 19753754].
1905 Prata N, Gessessew A, Cartwright A, et al. Provision of injectable contraceptives in Ethiopia through community-based reproductive health agents. Bull World Health Organ. Aug. 1. 2011;89(8):556-64. X-2, X-4. [pmid: 21836754].
1906 Pratt N, Roughead EE, Ryan P, et al. Differential impact of NSAIDs on rate of adverse events that require hospitalization in high-risk and general veteran populations: a retrospective cohort study. Drugs Aging. Jan. 1. 2010;27(1):63-71. X-4. [pmid: 20030433].
1907 Prentice RL, Chlebowski RT, Stefanick ML, et al. Estrogen plus progestin therapy and breast cancer in recently postmenopausal women. Am J Epidemiol. May. 15. 2008;167(10):1207-16. X-4, X-7. [pmid: 18372396].
1908 Prentice RL, Manson JE, Langer RD, et al. Benefits and risks of postmenopausal hormone therapy when it is initiated soon after menopause. Am J Epidemiol. Jul. 1. 2009;170(1):12-23. X-4, X-7. [pmid: 19468079].
1909 Preshaw PM, Knutsen MA, Mariotti A. Experimental gingivitis in women using oral contraceptives. J Dent Res. Nov. 2001;80(11):2011-5. X-2, X-4. [pmid: 11759012].
1910 Preston JT, Cameron IT, Adams EJ, et al. Comparative study of tranexamic acid and norethisterone in the treatment of ovulatory menorrhagia. Br J Obstet Gynaecol. May. 1995;102(5):401-6. X-2, X-4. [pmid: 7612535].
1911 Price-Forbes AN, Callaghan R, Allen ME, et al. A regional audit of the use of COX-2 selective non-steroidal anti-inflammatory drugs (NSAIDs) in rheumatology clinics in the West Midlands, in relation to NICE guidelines. Rheumatology (Oxford). Jul. 2005;44(7):921-4. X-4. [pmid: 15827035].
1912 Protti A, Russo R, Tagliabue P, et al. Oxygen consumption is depressed in patients with lactic acidosis due to biguanide intoxication. Crit Care. 2010;14(1):R22. X-2, X-3, X-4. [pmid: 20170489].
1913 Proudman SM, Keen HI, Stamp LK, et al. Response-driven combination therapy with conventional disease-modifying antirheumatic drugs can achieve high response rates in early rheumatoid arthritis with minimal glucocorticoid and nonsteroidal anti-inflammatory drug use. Semin Arthritis Rheum. Oct. 2007;37(2):99-111. X-2, X-4. [pmid: 17391739].
1914 Psaty BM, Weiss NS. NSAID trials and the choice of comparators--questions of public health importance. N Engl J Med. Jan. 25. 2007;356(4):328-30. X-1. [pmid: 17251528].
1915 Publig W, Wustinger C, Zandl C. Non-steroidal anti-inflammatory drugs (NSAID) cause gastrointestinal ulcers mainly in Helicobacter pylori carriers. Wien Klin Wochenschr. 1994;106(9):276-9. X-2. [pmid: 8023522].
1916 Pullar T, Murphy B, Taggart A, et al. Patterns of out-patients non-steroidal anti-inflammatory drug prescribing in two teaching hospital rheumatology units--implications for post-marketing surveillance. J Clin Pharm Ther. Aug. 1990;15(4):267-72. X-2, X-3, X-4. [pmid: 2229206].
1917 Puri AS, Monga R, Garg S, et al. Diaphragm disease of duodenum following long-term NSAIDs use: endoscopic management. Indian J Gastroenterol. Sep-Oct. 2004;23(5):189-90. X-2, X-3, X-4. [pmid: 15599008].
1918 Qin LH, Goldberg JM, Hao G. A 4-year follow-up study of women with Norplant-2 contraceptive implants. Contraception. Nov. 2001;64(5):301-3. X-2, X-4. [pmid: 11777490].
1919 Quaratino D, Romano A, Papa G, et al. Long-term tolerability of nimesulide and acetaminophen in nonsteroidal antiinflammatory drug-intolerant patients. Ann Allergy Asthma Immunol. Jul. 1997;79(1):47-50. X-2, X-3, X-4. [pmid: 9236499].
1920 Quehenberger P, Loner U, Kapiotis S, et al. Increased levels of activated factor VII and decreased plasma protein S activity and circulating thrombomodulin during use of oral contraceptives. Thromb Haemost. Nov. 1996;76(5):729-34. X-4, X-5. [pmid: 8950781].
1921 Quigley CA, Crowe BJ, Anglin DG, et al. Growth hormone and low dose estrogen in Turner syndrome: results of a United States multi-center trial to near-final height. J Clin Endocrinol Metab. May. 2002;87(5):2033-41. X-2, X-3, X-4. [pmid: 11994337].
1922 Quijada-Carrera J, Valenzuela-Castano A, Povedano-Gomez J, et al. Comparison of tenoxicam and bromazepan in the treatment of fibromyalgia: a randomized, double-blind, placebo-controlled trial. Pain. May-Jun. 1996;65(2-3):221-5. X-2, X-3, X-4. [pmid: 8826510].
1923 Quinones Estevez MD. Are selective COX-2 inhibitors a safe option in patients with intolerance to nonsteroidal antiinflammatory drugs?. J Investig Allergol Clin Immunol. 2009;19(4):328-30. X-2. [pmid: 19639736].
1924 Quiralte J, Blanco C, Castillo R, et al. Anaphylactoid reactions due to nonsteroidal antiinflammatory drugs: clinical and cross-reactivity studies. Ann Allergy Asthma Immunol. Mar. 1997;78(3):293-6. X-2, X-4. [pmid: 9087155].
1925 Quiralte J, Delgado J, Saenz de San Pedro B, et al. Safety of the new selective cyclooxygenase type 2 inhibitors rofecoxib and celecoxib in patients with anaphylactoid reactions to nonsteroidal anti-inflammatory drugs. Ann Allergy Asthma Immunol. Oct. 2004;93(4):360-4. X-2, X-4. [pmid: 15521372].
1926 Quiralte J, Saenz de San Pedro B, Florido JJ. Safety of selective cyclooxygenase-2 inhibitor rofecoxib in patients with NSAID-induced cutaneous reactions. Ann Allergy Asthma Immunol. Jul. 2002;89(1):63-6. X-2, X-4. [pmid: 12141722].
1927 Rabe T, Mueck AO, Deuringer FU, et al. Spacing-out of progestin--efficacy, tolerability and compliance of two regimens for hormonal replacement in the late postmenopause. Gynecol Endocrinol. Dec. 1997;11(6):383-92. X-2, X-4. [pmid: 9476087].
1928 Rabeneck L, Wristers K, Goldstein JL, et al. Reliability, validity, and responsiveness of severity of dyspepsia assessment (SODA) in a randomized clinical trial of a COX-2-specific inhibitor and traditional NSAID therapy. Am J Gastroenterol. Jan. 2002;97(1):32-9. X-4. [pmid: 11808967].
1929 Radat F, Sakh D, Lutz G, et al. Psychiatric comorbidity is related to headache induced by chronic substance use in migraineurs. Headache. Jul-Aug. 1999;39(7):477-80. X-2, X-3, X-4. [pmid: 11279930].
1930 Rager KM, Fowler A, Omar HA. Successful treatment of depot medroxyprogesterone acetate-related vaginal bleeding improves continuation rates in adolescents. ScientificWorldJournal. 2006;6:353-5. X-2, X-3, X-4. [pmid: 16547584].
1931 Raghu G, Brown KK, Costabel U, et al. Treatment of idiopathic pulmonary fibrosis with etanercept: an exploratory, placebo-controlled trial. Am J Respir Crit Care Med. Nov. 1. 2008;178(9):948-55. X-2, X-3, X-4. [pmid: 18669816].
1932 Ragni N, Boccardo E, Viglino S, et al. Oral contraception and breast pathology. Acta Eur Fertil. Jun. 1981;12(2):141-63. X-1, X-2, X-3, X-4. [pmid: 6794288].
1933 Rahman A, Segasothy M, Samad SA, et al. Analgesic use and chronic renal disease in patients with headache. Headache. Sep. 1993;33(8):442-5. X-2. [pmid: 8262786].
1934 Rahme E, Bardou M, Dasgupta K, et al. Hospitalization for gastrointestinal bleeding associated with non-steroidal anti-inflammatory drugs among elderly patients using low-dose aspirin: a retrospective cohort study. Rheumatology (Oxford). Feb. 2007;46(2):265-72. X-4, X-7. [pmid: 16844699].
1935 Rahme E, Barkun A, Nedjar H, et al. Hospitalizations for upper and lower GI events associated with traditional NSAIDs and acetaminophen among the elderly in Quebec, Canada. Am J Gastroenterol. Apr. 2008;103(4):872-82. X-4, X-7. [pmid: 18371130].
1936 Rahme E, Barkun AN, Toubouti Y, et al. Do proton-pump inhibitors confer additional gastrointestinal protection in patients given celecoxib?. Arthritis Rheum. Jun. 15. 2007;57(5):748-55. X-3, X-4. [pmid: 17530673].
1937 Rahme E, Choquette D, Beaulieu M, et al. Impact of a general practitioner educational intervention on osteoarthritis treatment in an elderly population. Am J Med. Nov. 2005;118(11):1262-70. X-2, X-3, X-4. [pmid: 16271911].
1938 Rahme E, Joseph L, Kong SX, et al. Gastrointestinal health care resource use and costs associated with nonsteroidal antiinflammatory drugs versus acetaminophen: retrospective cohort study of an elderly population. Arthritis Rheum. Apr. 2000;43(4):917-24. X-4, X-7. [pmid: 10765939].
1939 Rahme E, Joseph L, Kong SX, et al. Cost of prescribed NSAID-related gastrointestinal adverse events in elderly patients. Br J Clin Pharmacol. Aug. 2001;52(2):185-92. X-4, X-7. [pmid: 11488776].
1940 Rahme E, Nedjar H. Risks and benefits of COX-2 inhibitors vs non-selective NSAIDs: does their cardiovascular risk exceed their gastrointestinal benefit? A retrospective cohort study. Rheumatology (Oxford). Mar. 2007;46(3):435-8. X-7. [pmid: 17255138].
1941 Rahme E, Nedjar H, Bizzi A, et al. Hospitalization for gastrointestinal adverse events attributable to the use of low-dose aspirin among patients 50 years or older also using non-steroidal anti-inflammatory drugs: a retrospective cohort study. Aliment Pharmacol Ther. Nov. 15. 2007;26(10):1387-98. X-4, X-7. [pmid: 17892525].
1942 Rahme E, Pettitt D, LeLorier J. Determinants and sequelae associated with utilization of acetaminophen versus traditional nonsteroidal antiinflammatory drugs in an elderly population. Arthritis Rheum. Nov. 2002;46(11):3046-54. X-7. [pmid: 12428249].
1943 Rahme E, Watson DJ, Kong SX, et al. Association between nonnaproxen NSAIDs, COX-2 inhibitors and hospitalization for acute myocardial infarction among the elderly: a retrospective cohort study. Pharmacoepidemiol Drug Saf. May. 2007;16(5):493-503. X-4, X-7. [pmid: 17086567].
1944 Rajagopalan R, Iyer S, Perez A. Comparison of pioglitazone with other antidiabetic drugs for associated incidence of liver failure: no evidence of increased risk of liver failure with pioglitazone. Diabetes Obes Metab. Mar. 2005;7(2):161-9. X-4. [pmid: 15715889].
1945 Rakhshani F, Mohammadi M. Contraception continuation rates and reasons for discontinuation in Zahedan, Islamic Republic of Iran. East Mediterr Health J. May. 2004;10(3):260-7. X-8. [pmid: 16212200].
1946 Ramadan FH, Masoodi N, El-Solh AA. Clinical factors associated with hyperkalemia in patients with congestive heart failure. J Clin Pharm Ther. Jun. 2005;30(3):233-9. X-2, X-3, X-4. [pmid: 15896240].
1947 Ramakrishnan K, Johnson AD. Gastroduodenal ulcer perforation. Br J Clin Pract. Sep. 1986;40(9):371-2. X-2, X-4. [pmid: 3801262].
1948 Ramam M, Bhat R, Jindal S, et al. Patient-reported multiple drug reactions: clinical profile and results of challenge testing. Indian J Dermatol Venereol Leprol. Jul-Aug. 2010;76(4):382-6. X-2. [pmid: 20657119].
1949 Ramirez Hidalgo A, Pujol Ribera E. Use of the intrauterine device: efficacy and safety. Eur J Contracept Reprod Health Care. Sep. 2000;5(3):198-207. X-2. [pmid: 11131785].
1950 Ramsoekh D, van Leerdam ME, Rauws EA, et al. Outcome of peptic ulcer bleeding, nonsteroidal anti-inflammatory drug use, and Helicobacter pylori infection. Clin Gastroenterol Hepatol. Sep. 2005;3(9):859-64. X-2. [pmid: 16234022].
1951 Rao G. Aspirin preparation and risk of GI bleeding. J Fam Pract. Mar. 1997;44(3):242-3. X-1, X-4. [pmid: 9071237].
1952 Rao GR, Ghosh S, Dhurat R, et al. Efficacy, safety, and tolerability of microsphere adapalene vs. conventional adapalene for acne vulgaris. Int J Dermatol. Dec. 2009;48(12):1360-5. X-2, X-4. [pmid: 20415678].
1953 Rashad S, Revell P, Hemingway A, et al. Effect of non-steroidal anti-inflammatory drugs on the course of osteoarthritis. Lancet. Sep. 2. 1989;2(8662):519-22. X-2, X-4. [pmid: 2570233].
1954 Rasheed SM, Abdelmonem AM. Complications among adolescents using copper intrauterine contraceptive devices. Int J Gynaecol Obstet. Dec. 2011;115(3):269-72. X-2, X-4. [pmid: 21872240].
1955 Rask O, Nilsson KO, Berntorp E. Oestrogen treatment of constitutional tall stature in girls: is there a risk of thrombosis or bleeding?. Acta Paediatr. Mar. 2008;97(3):342-7. X-2, X-4. [pmid: 18298783].
1956 Raskin JB, White RH, Jaszewski R, et al. Misoprostol and ranitidine in the prevention of NSAID-induced ulcers: a prospective, double-blind, multicenter study. Am J Gastroenterol. Feb. 1996;91(2):223-7. X-2, X-3, X-4. [pmid: 8607484].
1957 Rasmussen VG, Poulsen SH, Dupont E, et al. Heart valve disease associated with treatment with ergot-derived dopamine agonists: a clinical and echocardiographic study of patients with Parkinson's disease. J Intern Med. Jan. 2008;263(1):90-8. X-2. [pmid: 18036161].
1958 Ratner RE, Maggs D, Nielsen LL, et al. Long-term effects of exenatide therapy over 82 weeks on glycaemic control and weight in over-weight metformin-treated patients with type 2 diabetes mellitus. Diabetes Obes Metab. Jul. 2006;8(4):419-28. X-2, X-3, X-4. [pmid: 16776749].
1959 Rattray B, Nugent DJ, Young G. Celecoxib in the treatment of haemophilic synovitis, target joints, and pain in adults and children with haemophilia. Haemophilia. Sep. 2006;12(5):514-7. X-2, X-4. [pmid: 16919082].
1960 Raudaskoski TH, Tomas EI, Paakkari IA, et al. Serum lipids and lipoproteins in postmenopausal women receiving transdermal oestrogen in combination with a levonorgestrel-releasing intrauterine device. Maturitas. Jun. 1995;22(1):47-53. X-2, X-4. [pmid: 7666816].
1961 Raverot G, Jacob M, Jouanneau E, et al. Secondary deterioration of visual field during cabergoline treatment for macroprolactinoma. Clin Endocrinol (Oxf). Apr. 2009;70(4):588-92. X-2. [pmid: 18673461].
1962 Rawal N, Kroner K, Simin-Geertsen M, et al. Safety of lornoxicam in the treatment of postoperative pain: a post-marketing study of analgesic regimens containing lornoxicam compared with standard analgesic treatment in 3752 day-case surgery patients. Clin Drug Investig. 2010;30(10):687-97. X-4. [pmid: 20701400].
1963 Rawson NS. Impact of preexisting health conditions on the outcome of an adverse drug reaction alerting program: gastrointestinal disorders before piroxicam and sulindac therapy. Ann Pharmacother. Jul-Aug. 1995;29(7-8):676-80. X-3, X-4. [pmid: 8520079].
1964 Rawson NS, Inman WH. Prescription-Event Monitoring. Recent experience with 5 NSAIDs. Med Toxicol. Suppl 1. 1986;1:79-82. X-4. [pmid: 3821431].
1965 Rawson NS, Nourjah P, Grosser SC, et al. Factors associated with celecoxib and rofecoxib utilization. Ann Pharmacother. Apr. 2005;39(4):597-602. X-4. [pmid: 15755796].
1966 Ray WA, Chung CP, Stein CM, et al. Risk of peptic ulcer hospitalizations in users of NSAIDs with gastroprotective cotherapy versus coxibs. Gastroenterology. Sep. 2007;133(3):790-8. X-4. [pmid: 17854591].
1967 Ray WA, Stein CM, Byrd V, et al. Educational program for physicians to reduce use of non-steroidal anti-inflammatory drugs among community-dwelling elderly persons: a randomized controlled trial. Med Care. May. 2001;39(5):425-35. X-2, X-3, X-4. [pmid: 11317091].
1968 Ray WA, Stein CM, Daugherty JR, et al. COX-2 selective non-steroidal anti-inflammatory drugs and risk of serious coronary heart disease. Lancet. Oct. 5. 2002;360(9339):1071-3. X-2, X-4. [pmid: 12383990].
1969 Ray WA, Varas-Lorenzo C, Chung CP, et al. Cardiovascular risks of nonsteroidal antiinflammatory drugs in patients after hospitalization for serious coronary heart disease. Circ Cardiovasc Qual Outcomes. May. 2009;2(3):155-63. X-4. [pmid: 20031832].
1970 Raynauld JP, Martel-Pelletier J, Bias P, et al. Protective effects of licofelone, a 5-lipoxygenase and cyclo-oxygenase inhibitor, versus naproxen on cartilage loss in knee osteoarthritis: a first multicentre clinical trial using quantitative MRI. Ann Rheum Dis. Jun. 2009;68(6):938-47. X-2, X-3, X-4. [pmid: 18653484].
1971 Reasbeck PG, Rice ML, Reasbeck JC. Double-blind controlled trial of indomethacin as an adjunct to narcotic analgesia after major abdominal surgery. Lancet. Jul. 17. 1982;2(8290):115-8. X-2, X-3, X-4. [pmid: 6123836].
1972 Rebbeck TR, Troxel AB, Norman S, et al. Pharmacogenetic modulation of combined hormone replacement therapy by progesterone-metabolism genotypes in postmenopausal breast cancer risk. Am J Epidemiol. Dec. 15. 2007;166(12):1392-9. X-2, X-3, X-4. [pmid: 17827444].
1973 Rehan N, Inayatullah A, Chaudhary I. Norplant: reasons for discontinuation and side-effects. Eur J Contracept Reprod Health Care. Jun. 2000;5(2):113-8. X-2, X-4. [pmid: 10943573].
1974 Reid PC, Virtanen-Kari S. Randomised comparative trial of the levonorgestrel intrauterine system and mefenamic acid for the treatment of idiopathic menorrhagia: a multiple analysis using total menstrual fluid loss, menstrual blood loss and pictorial blood loss assessment charts. BJOG. Aug. 2005;112(8):1121-5. X-2, X-3. [pmid: 16045528].
1975 Reid RW, Zimmerman AA, Laussen PC, et al. The efficacy of tranexamic acid versus placebo in decreasing blood loss in pediatric patients undergoing repeat cardiac surgery. Anesth Analg. May. 1997;84(5):990-6. X-2, X-3, X-4. [pmid: 9141920].
1976 Reiff A, Lovell DJ, Adelsberg JV, et al. Evaluation of the comparative efficacy and tolerability of rofecoxib and naproxen in children and adolescents with juvenile rheumatoid arthritis: a 12-week randomized controlled clinical trial with a 52-week open-label extension. J Rheumatol. May. 2006;33(5):985-95. X-2, X-4. [pmid: 16583464].
1977 Reijman M, Bierma-Zeinstra SM, Pols HA, et al. Is there an association between the use of different types of nonsteroidal antiinflammatory drugs and radiologic progression of osteoarthritis? The Rotterdam Study. Arthritis Rheum. Oct. 2005;52(10):3137-42. X-4, X-7. [pmid: 16200593].
1978 Reinhart DJ, Goldberg ME, Roth JV, et al. Transdermal fentanyl system plus im ketorolac for the treatment of postoperative pain. Can J Anaesth. Apr. 1997;44(4):377-84. X-2, X-4. [pmid: 9104519].
1979 Reinprayoon D, Taneepanichskul S, Bunyavejchevin S, et al. Effects of the etonogestrel-releasing contraceptive implant (Implanon on parameters of breastfeeding compared to those of an intrauterine device. Contraception. Nov. 2000;62(5):239-46. X-2, X-4. [pmid: 11172794].
1980 Reiter SL, Baer LJ. Initial selection of oral contraceptives. J Reprod Med. May. 1990;35(5):547-8. X-2. [pmid: 2352250].
1981 Renier M, Buytaert P. Open prospective multicenter trial with a new monophasic contraceptive combination containing gestodene. Contraception. May. 1991;43(5):413-21. X-4. [pmid: 1914456].
1982 Resseguie LJ, Hick JF, Bruen JA, et al. Congenital malformations among offspring exposed in utero to progestins, Olmsted County, Minnesota, 1936-1974. Fertil Steril. Apr. 1985;43(4):514-9. X-2, X-4. [pmid: 3987922].
1983 Reuben SS, Ablett D, Kaye R. High dose nonsteroidal anti-inflammatory drugs compromise spinal fusion. Can J Anaesth. May. 2005;52(5):506-12. X-2, X-4. [pmid: 15872130].
1984 Rexrode KM, Buring JE, Glynn RJ, et al. Analgesic use and renal function in men. JAMA. Jul. 18. 2001;286(3):315-21. X-6. [pmid: 11466097].
1985 Reyes-Morales H, Mino-Leon D, Doubova SV, et al. Postmarketing pharmacovigilance of adverse drug reactions: the case of rosiglitazone in Mexico. Int J Clin Pharmacol Ther. Jan. 2012;50(1):1-9. X-2, X-4. [pmid: 22192639].
1986 Rheinlaender C, Helfenstein D, Walch E, et al. Total serum bilirubin levels during cyclooxygenase inhibitor treatment for patent ductus arteriosus in preterm infants. Acta Paediatr. Jan. 2009;98(1):36-42. X-2, X-4. [pmid: 18764861].
1987 Rhemrev PE, van Os WA, Edelman DA, et al. Medical removals of the Multiload IUD. Adv Contracept. Jun. 1988;4(2):125-30. X-3, X-4. [pmid: 3213669].
1988 Rice MM, Graves AB, McCurry SM, et al. Postmenopausal estrogen and estrogen-progestin use and 2-year rate of cognitive change in a cohort of older Japanese American women: The Kame Project. Arch Intern Med. Jun. 12. 2000;160(11):1641-9. X-2. [pmid: 10847257].
1989 Richards J, Johnson A, Fox G, et al. A second course of ibuprofen is effective in the closure of a clinically significant PDA in ELBW infants. Pediatrics. Aug. 2009;124(2):e287-93. X-2, X-3, X-4. [pmid: 19651568].
1990 Richardson BA, Otieno PA, Mbori-Ngacha D, et al. Hormonal contraception and HIV-1 disease progression among postpartum Kenyan women. AIDS. Mar. 30. 2007;21(6):749-53. X-2. [pmid: 17413696].
1991 Riddell RH, Tanaka M, Mazzoleni G. Non-steroidal anti-inflammatory drugs as a possible cause of collagenous colitis: a case-control study. Gut. May. 1992;33(5):683-6. X-2. [pmid: 1612488].
1992 Riddle R, Ryser CN, Morton AA, et al. The impact on health-related quality of life from non-steroidal anti-inflammatory drugs, methotrexate, or steroids in treatment for juvenile idiopathic arthritis. J Pediatr Psychol. Apr. 2006;31(3):262-71. X-2, X-4. [pmid: 15872147].
1993 Riley AP, Stewart MK, Chakraborty J. Program- and method-related determinants of first DMPA use duration in rural Bangladesh. Stud Fam Plann. Sep-Oct. 1994;25(5):255-67. X-2, X-4. [pmid: 7871551].
1994 Rimbas M, Marinescu M, Voiosu MR, et al. NSAID-induced deleterious effects on the proximal and mid small bowel in seronegative spondyloarthropathy patients. World J Gastroenterol. Feb. 28. 2011;17(8):1030-5. X-2, X-3, X-4. [pmid: 21448355].
1995 Risques RA, Vaughan TL, Li X, et al. Leukocyte telomere length predicts cancer risk in Barrett's esophagus. Cancer Epidemiol Biomarkers Prev. Dec. 2007;16(12):2649-55. X-2, X-3, X-4. [pmid: 18086770].
1996 Ritchie LD. A clinical evaluation of flurbiprofen LAT and piroxicam gel: a multicentre study in general practice. Clin Rheumatol. May. 1996;15(3):243-7. X-2, X-3, X-4. [pmid: 8793254].
1997 Rivera R, Gousse A. Does postmenopausal hormone therapy cause urinary incontinence?. Nat Clin Pract Urol. Jun. 2006;3(6):304-5. X-1, X-2, X-4, X-7. [pmid: 16763639].
1998 Rivers JK, McLean DI. An open study to assess the efficacy and safety of topical 3% diclofenac in a 2.5% hyaluronic acid gel for the treatment of actinic keratoses. Arch Dermatol. Oct. 1997;133(10):1239-42. X-2, X-3, X-4. [pmid: 9382562].
1999 Rizk DE. Subdermal levonorgestrel implants. Three years' experience in Cairo, Egypt. J Reprod Med. Sep. 1995;40(9):638-44. X-2, X-4. [pmid: 8576880].
2000 Robe PA, Martin D, Albert A, et al. A phase 1-2, prospective, double blind, randomized study of the safety and efficacy of Sulfasalazine for the treatment of progressing malignant gliomas: study protocol of [ISRCTN45828668]. BMC Cancer. 2006;6:29. X-2, X-3, X-4. [pmid: 16448552].
2001 Robert E, Musatti L, Piscitelli G, et al. Pregnancy outcome after treatment with the ergot derivative, cabergoline. Reprod Toxicol. Jul-Aug. 1996;10(4):333-7. X-2, X-8. [pmid: 8829257].
2002 Robertson DJ, Larsson H, Friis S, et al. Proton pump inhibitor use and risk of colorectal cancer: a population-based, case-control study. Gastroenterology. Sep. 2007;133(3):755-60. X-4. [pmid: 17678921].
2003 Robinson JL, Griest S, James KE, et al. Impact of aspirin intolerance on outcomes of sinus surgery. Laryngoscope. May. 2007;117(5):825-30. X-2, X-3, X-4. [pmid: 17473677].
2004 Robinson R, China S, Bunkheila A, et al. Mirena intrauterine system in the treatment of menstrual disorders: a survey of UK patients' experience, acceptability and satisfaction. J Obstet Gynaecol. Oct. 2008;28(7):728-31. X-2. [pmid: 19065370].
2005 Rodriguez A, Reviriego J, Karamanos V, et al. Management of cardiovascular risk factors with pioglitazone combination therapies in type 2 diabetes: an observational cohort study. Cardiovasc Diabetol. 2011;10:18. X-3, X-4. [pmid: 21314919].
2006 Roll A, Wuthrich B, Schmid-Grendelmeier P, et al. Tolerance to celecoxib in patients with a history of adverse reactions to nonsteroidal anti-inflammatory drugs. Swiss Med Wkly. Oct. 28. 2006;136(43-44):684-90. X-2, X-3, X-4. [pmid: 17183430].
2007 Romer T. Prospective comparison study of levonorgestrel IUD versus Roller-Ball endometrial ablation in the management of refractory recurrent hypermenorrhea. Eur J Obstet Gynecol Reprod Biol. May. 2000;90(1):27-9. X-2, X-3. [pmid: 10767506].
2008 Romieu I, Fabre A, Fournier A, et al. Postmenopausal hormone therapy and asthma onset in the E3N cohort. Thorax. Apr. 2010;65(4):292-7. X-4, X-7. [pmid: 20142267].
2009 Romsing J, Ostergaard D, Walther-Larsen S, et al. Analgesic efficacy and safety of preoperative versus postoperative ketorolac in paediatric tonsillectomy. Acta Anaesthesiol Scand. Aug. 1998;42(7):770-5. X-2, X-3, X-4. [pmid: 9698951].
2010 Ronnerdag M, Odlind V. Late bleeding problems with the levonorgestrel-releasing intrauterine system: evaluation of the endometrial cavity. Contraception. Apr. 2007;75(4):268-70. X-2. [pmid: 17362704].
2011 Ronquist G, Rodriguez LA, Ruigomez A, et al. Association between captopril, other antihypertensive drugs and risk of prostate cancer. Prostate. Jan. 1. 2004;58(1):50-6. X-3, X-4. [pmid: 14673952].
2012 Rooney TW, Furst DE, Koehnke R, et al. Aspirin is not associated with more toxicity than other nonsteroidal antiinflammatory drugs in patients with rheumatoid arthritis treated with methotrexate. J Rheumatol. Aug. 1993;20(8):1297-302. X-2, X-4. [pmid: 8230008].
2013 Roos Y. Antifibrinolytic treatment in subarachnoid hemorrhage: a randomized placebo-controlled trial. STAR Study Group. Neurology. Jan. 11. 2000;54(1):77-82. X-2, X-3, X-4. [pmid: 10636129].
2014 Rosenberg JA, Goldstein JL. Safety and efficacy of lumiracoxib compared with NSAIDs. Nat Clin Pract Gastroenterol Hepatol. Jan. 2005;2(1):14-5. X-1, X-2, X-4. [pmid: 16265092].
2015 Rosenberg L, Palmer JR, Rao RS, et al. Low-dose oral contraceptive use and the risk of myocardial infarction. Arch Intern Med. Apr. 23. 2001;161(8):1065-70. X-4. [pmid: 11322840].
2016 Ross AH, Boyd ME, Colgan TJ, et al. Comparison of transdermal and oral sequential gestagen in combination with transdermal estradiol: effects on bleeding patterns and endometrial histology. Obstet Gynecol. Nov. 1993;82(5):773-9. X-2, X-4. [pmid: 8414325].
2017 Rossing MA, Daling JR, Weiss NS, et al. Past use of an intrauterine device and risk of tubal pregnancy. Epidemiology. May. 1993;4(3):245-51. X-2, X-4. [pmid: 8512988].
2018 Roth S, Bennett R, Caldron P, et al. Reduced risk of NSAID gastropathy (GI mucosal toxicity) with nonacetylated salicylate (salsalate): an endoscopic study. Semin Arthritis Rheum. Feb. 1990;19(4 Suppl 2):11-9. X-2. [pmid: 2181673].
2019 Roth SH, Bennett R, Caldron P, et al. A longterm endoscopic evaluation of patients with arthritis treated with nabumetone vs naproxen. J Rheumatol. Jun. 1994;21(6):1118-23. X-2. [pmid: 7932425].
2020 Roth SH, Tindall EA, Jain AK, et al. A controlled study comparing the effects of nabumetone, ibuprofen, and ibuprofen plus misoprostol on the upper gastrointestinal tract mucosa. Arch Intern Med. Nov. 22. 1993;153(22):2565-71. X-2. [pmid: 8239849].
2021 Roth-Cline MD. Clinical trials in the wake of Vioxx: requiring statistically extreme evidence of benefit to ensure the safety of new drugs. Circulation. May. 9. 2006;113(18):2253-9. X-1, X-2, X-3, X-4. [pmid: 16684875].
2022 Roto P, Sainio H, Reunala T, et al. Addition of ferrous sulfate to cement and risk of chromium dermatitis among construction workers. Contact Dermatitis. Jan. 1996;34(1):43-50. X-2, X-4. [pmid: 8789225].
2023 Roughead EE, Ramsay E, Pratt N, et al. NSAID use in individuals at risk of renal adverse events: an observational study to investigate trends in Australian veterans. Drug Saf. 2008;31(11):997-1003. X-3, X-4. [pmid: 18840019].
2024 Roujeau JC, Kelly JP, Naldi L, et al. Medication use and the risk of Stevens-Johnson syndrome or toxic epidermal necrolysis. N Engl J Med. Dec. 14. 1995;333(24):1600-7. X-2. [pmid: 7477195].
2025 Roumie CL, Arbogast PG, Mitchel EF Jr., et al. Prescriptions for chronic high-dose cyclooxygenase-2 inhibitors are often inappropriate and potentially dangerous. J Gen Intern Med. Oct. 2005;20(10):879-83. X-3, X-4. [pmid: 16191131].
2026 Roumie CL, Choma NN, Kaltenbach L, et al. Non-aspirin NSAIDs, cyclooxygenase-2 inhibitors and risk for cardiovascular events-stroke, acute myocardial infarction, and death from coronary heart disease. Pharmacoepidemiol Drug Saf. Nov. 2009;18(11):1053-63. X-4. [pmid: 19637402].
2027 Rovensky J, Micekova D. Six-month prospective study to monitor the treatment of rheumatic diseases with sustained-release flurbiprofen. Drugs Exp Clin Res. 2000;26(1):19-24. X-2, X-3, X-4. [pmid: 10761533].
2028 Rovensky J, Micekova D, Gubzova Z, et al. Treatment of knee osteoarthritis with a topical non-steroidal antiinflammatory drug. Results of a randomized, double-blind, placebo-controlled study on the efficacy and safety of a 5% ibuprofen cream. Drugs Exp Clin Res. 2001;27(5-6):209-21. X-2, X-4. [pmid: 11951579].
2029 Rowan JA. A trial in progress gestational diabetes. Treatment with metformin compared with insulin (the Metformin in Gestational Diabetes [MiG] trial). Diabetes Care. Jul. Suppl 2. 2007;30:S214-9. X-2. [pmid: 17596475].
2030 Rowlands S, Guillebaud J, Bounds W, et al. Side effects of danazol compared with an ethinyloestradiol/norgestrel combination when used for postcoital contraception. Contraception. Jan. 1983;27(1):39-49. X-2, X-3, X-4. [pmid: 6839757].
2031 Rozenberg S, Ylikorkala O, Arrenbrecht S. Comparison of continuous and sequential transdermal progestogen with sequential oral progestogen in postmenopausal women using continuous transdermal estrogen: vasomotor symptoms, bleeding patterns, and serum lipids. Int J Fertil Womens Med. Suppl 2. 1997;42:376-87. X-2. [pmid: 9397385].
2032 Rozendaal L, le Cessie S, Wit JM, et al. Growth-reductive therapy in children with marfan syndrome. J Pediatr. Nov. 2005;147(5):674-9. X-2, X-4. [pmid: 16291362].
2033 Rubinstein ML, Halpern-Felsher BL, Irwin CE Jr. An evaluation of the use of the transdermal contraceptive patch in adolescents. J Adolesc Health. May. 2004;34(5):395-401. X-2, X-3, X-4. [pmid: 15093794].
2034 Ruel MA, Wang F, Bourke ME, et al. Is tranexamic acid safe in patients undergoing coronary endarterectomy?. Ann Thorac Surg. May. 2001;71(5):1508-11. X-2, X-4. [pmid: 11383791].
2035 Rugstad HE, Hundal O, Holme I, et al. Piroxicam and naproxen plasma concentrations in patients with osteoarthritis: relation to age, sex, efficacy and adverse events. Clin Rheumatol. Sep. 1986;5(3):389-98. X-4. [pmid: 3536263].
2036 Ruigomez A, Garcia Rodriguez LA, Wallander MA, et al. Natural history of gastro-oesophageal reflux disease diagnosed in general practice. Aliment Pharmacol Ther. Oct. 1. 2004;20(7):751-60. X-3, X-4. [pmid: 15379835].
2037 Ruminjo JK, Achwal I, Ruminjo IN. Acceptability of Norplant contraceptive subdermal implants in Kenya. East Afr Med J. Sep. 1994;71(9):558-61. X-3, X-4. [pmid: 7875087].
2038 Russo P, Papa V, Russo S, et al. Topical nonsteroidal anti-inflammatory drugs in uncomplicated cataract surgery: effect of sodium naproxen. Eur J Ophthalmol. Sep-Oct. 2005;15(5):598-606. X-2, X-3, X-4. [pmid: 16167290].
2039 Ryan P, Hetzel DJ, Shearman DJ, et al. Risk factors for ulcerative reflux oesophagitis: a case-control study. J Gastroenterol Hepatol. May-Jun. 1995;10(3):306-12. X-2, X-4. [pmid: 7548808].
2040 Ryan PJ, Singh SP, Guillebaud J. Depot medroxyprogesterone and bone mineral density. J Fam Plann Reprod Health Care. Jan. 2002;28(1):12-5. X-2. [pmid: 16259808].
2041 Rybo G, Andersson K, Odlind V. Hormonal intrauterine devices. Ann Med. Apr. 1993;25(2):143-7. X-8. [pmid: 8489751].
2042 Saag KG, Rubenstein LM, Chrischilles EA, et al. Nonsteroidal antiinflammatory drugs and cognitive decline in the elderly. J Rheumatol. Nov. 1995;22(11):2142-7. X-7. [pmid: 8596158].
2043 Sabatini R, Cagiano R. Comparison profiles of cycle control, side effects and sexual satisfaction of three hormonal contraceptives. Contraception. Sep. 2006;74(3):220-3. X-2. [pmid: 16904415].
2044 Sachar D. Exposure to mesalamine during pregnancy increased preterm deliveries (but not birth defects) and decreased birth weight. Gut. Sep. 1998;43(3):316. X-2, X-4. [pmid: 9863473].
2045 Sadikot SM, Mogensen CE. Risk of coronary artery disease associated with initial sulphonylurea treatment of patients with type 2 diabetes: a matched case-control study. Diabetes Res Clin Pract. Dec. 2008;82(3):391-5. X-2, X-3, X-4. [pmid: 18945509].
2046 Sagay AS, Okeahialam BN, Imade GE. Electrocardiographic changes among Nigerian Norplant users. West Afr J Med. Apr-Jun. 2002;21(2):146-8. X-2, X-4. [pmid: 12403039].
2047 Sagay AS, Okeahialam BN, Imade GE, et al. Evaluation of cardiovascular morbidity in Nigerian women after 3 years of Norplant contraception. Afr J Reprod Health. Apr. 2008;12(1):47-53. X-2, X-4. [pmid: 20695154].
2048 Sahi SP, Basu SK, Bansal SK. Non-steroidal anti-inflammatory drugs and gastrointestinal bleeding in the elderly. Br J Clin Pract. Jan. 1990;44(1):22-3. 7. X-2. [pmid: 2317434].
2049 Sahin Y, Unluhizarci K, Yilmazsoy A, et al. The effects of metformin on metabolic and cardiovascular risk factors in nonobese women with polycystic ovary syndrome. Clin Endocrinol (Oxf). Dec. 2007;67(6):904-8. X-2. [pmid: 17666089].
2050 Sairanen J, Tammela TL, Leppilahti M, et al. Cyclosporine A and pentosan polysulfate sodium for the treatment of interstitial cystitis: a randomized comparative study. J Urol. Dec. 2005;174(6):2235-8. X-2, X-3, X-4. [pmid: 16280777].
2051 Saito Y, Morimoto T, Ogawa H, et al. Low-dose aspirin therapy in patients with type 2 diabetes and reduced glomerular filtration rate: subanalysis from the JPAD trial. Diabetes Care. Feb. 2011;34(2):280-5. X-3, X-4. [pmid: 21270185].
2052 Sakai H, Minami Y, Kanetake H, et al. Chemo-endocrine therapy for prostate cancer with bone metastasis. Nagasaki Prostate Cancer Research Group. Cancer Chemother Pharmacol. 1994;35(Suppl):S23-6. X-2, X-3, X-4. [pmid: 7994782].
2053 Sakamoto C, Sugano K, Ota S, et al. Case-control study on the association of upper gastrointestinal bleeding and nonsteroidal anti-inflammatory drugs in Japan. Eur J Clin Pharmacol. Sep. 2006;62(9):765-72. X-2. [pmid: 16821007].
2054 Salih BA, Abasiyanik MF, Bayyurt N, et al. H pylori infection and other risk factors associated with peptic ulcers in Turkish patients: a retrospective study. World J Gastroenterol. Jun. 21. 2007;13(23):3245-8. X-4. [pmid: 17589905].
2055 Salim AS. A new approach to the treatment of nonsteroidal anti-inflammatory drugs induced gastric bleeding by free radical scavengers. Surg Gynecol Obstet. May. 1993;176(5):484-90. X-2, X-3, X-4. [pmid: 8480273].
2056 Saloheimo P, Ahonen M, Juvela S, et al. Regular aspirin-use preceding the onset of primary intracerebral hemorrhage is an independent predictor for death. Stroke. Jan. 2006;37(1):129-33. X-2, X-4. [pmid: 16322483].
2057 Salokorpi T, Eronen M, von Wendt L. Growth and development until 18 months of children exposed to tocolytics indomethacin or nylidrin. Neuropediatrics. Aug. 1996;27(4):174-7. X-2, X-4. [pmid: 8892364].
2058 Salonen A, Silvola J, Kokki H. Does 1 or 2 g paracetamol added to ketoprofen enhance analgesia in adult tonsillectomy patients?. Acta Anaesthesiol Scand. Oct. 2009;53(9):1200-6. X-2, X-3, X-4. [pmid: 19572937].
2059 Salvo F, Polimeni G, Cutroneo PM, et al. Allergic reactions to oral drugs: A case/non-case study from an Italian spontaneous reporting database (GIF). Pharmacol Res. Sep-Oct. 2008;58(3-4):202-7. X-4. [pmid: 18692136].
2060 Sammartino A, Di Carlo C, Mandato VD, et al. Effects of genistein on the endometrium: ultrasonographic evaluation. Gynecol Endocrinol. Feb. 2003;17(1):45-9. X-2, X-3, X-4. [pmid: 12724018].
2061 Sammour RN, Ohel G, Cohen M, et al. Oral naproxen versus oral tramadol for analgesia after cesarean delivery. Int J Gynaecol Obstet. May. 2011;113(2):144-7. X-2, X-3. [pmid: 21435642].
2062 Samonis G, Margioris AN, Bafaloukos D, et al. Prospective randomized study of aminoglutethimide (AG) versus medroxyprogesterone acetate (MPA) versus AG+MPA in generalized breast cancer. Oncology. Sep-Oct. 1994;51(5):411-5. X-2, X-3, X-4. [pmid: 8052481].
2063 Samsioe G, Boschitsch E, Concin H, et al. Endometrial safety, overall safety and tolerability of transdermal continuous combined hormone replacement therapy over 96 weeks: a randomized open-label study. Climacteric. Oct. 2006;9(5):368-79. X-2, X-3, X-4. [pmid: 17080587].
2064 Samuelsson E, Hagg S. Incidence of venous thromboembolism in young Swedish women and possibly preventable cases among combined oral contraceptive users. Acta Obstet Gynecol Scand. Jul. 2004;83(7):674-81. X-4. [pmid: 15225194].
2065 Sanak M, Kielbasa B, Bochenek G, et al. Exhaled eicosanoids following oral aspirin challenge in asthmatic patients. Clin Exp Allergy. Dec. 2004;34(12):1899-904. X-2, X-3, X-4. [pmid: 15663565].
2066 Sanchez Andrada S, Rodriguez Valverde V. A double-blind randomised controlled trial of droxicam versus indomethacin in rheumatoid arthritis. Eur J Rheumatol Inflamm. 1991;11(4):15-20. X-2, X-3, X-4. [pmid: 1365485].
2067 Sanchez Palacios A, Schamann F, Garcia JA, et al. Sensitization to neumoallergens influence in mothers of asthmatic children. Allergol Immunopathol (Madr). Jan-Feb. 1996;24(1):7-12. X-2, X-3, X-4. [pmid: 8882754].
2068 Sander M, Spies CD, Martiny V, et al. Mortality associated with administration of high-dose tranexamic acid and aprotinin in primary open-heart procedures: a retrospective analysis. Crit Care. 2010;14(4):R148. X-2. [pmid: 20682059].
2069 Sanders SA, Graham CA, Bass JL, et al. A prospective study of the effects of oral contraceptives on sexuality and well-being and their relationship to discontinuation. Contraception. Jul. 2001;64(1):51-8. X-2. [pmid: 11535214].
2070 Sandler DP, Burr FR, Weinberg CR. Nonsteroidal anti-inflammatory drugs and the risk for chronic renal disease. Ann Intern Med. Aug. 1. 1991;115(3):165-72. X-2. [pmid: 2058870].
2071 Sandoval HP, De Castro LE, Vroman DT, et al. Evaluation of 0.4% ketorolac tromethamine ophthalmic solution versus 0.5% ketorolac tromethamine ophthalmic solution after phacoemulsification and intraocular lens implantation. J Ocul Pharmacol Ther. Aug. 2006;22(4):251-7. X-2, X-3, X-4. [pmid: 16910866].
2072 Sang GW, Shao QX, Ge RS, et al. A multicentred phase III comparative clinical trial of Mesigyna, Cyclofem and Injectable No. 1 given monthly by intramuscular injection to Chinese women. I. Contraceptive efficacy and sid effects. Contraception. Mar. 1995;51(3):167-83. X-4. [pmid: 7621685].
2073 Sangem M, Asthana S, Amin S. Multiple courses of indomethacin and neonatal outcomes in premature infants. Pediatr Cardiol. Sep. 2008;29(5):878-84. X-2, X-3, X-4. [pmid: 18094917].
2074 Sangi-Haghpeykar H, Poindexter AN 3rd, Bateman L, et al. Experiences of injectable contraceptive users in an urban setting. Obstet Gynecol. Aug. 1996;88(2):227-33. X-2. [pmid: 8692507].
2075 Sapoznikov B, Vilkin A, Hershkovici M, et al. Minidose aspirin and gastrointestinal bleeding--a retrospective, case-control study in hospitalized patients. Dig Dis Sci. Sep. 2005;50(9):1621-4. X-2, X-4. [pmid: 16133960].
2076 Sapp AV, Lindbloom EJ. Do third-generation oral contraceptives (OCs) increase the risk of venous thrombosis?. J Fam Pract. Oct. 2001;50(10):893. X-1, X-2, X-4. [pmid: 11674894].
2077 Saran R, Dykstra DM, Wolfe RA, et al. Association between vascular access failure and the use of specific drugs: the Dialysis Outcomes and Practice Patterns Study (DOPPS). Am J Kidney Dis. Dec. 2002;40(6):1255-63. X-3, X-4. [pmid: 12460045].
2078 Sardella A, Uglietti D, Demarosi F, et al. Benzydamine hydrochloride oral rinses in management of burning mouth syndrome. A clinical trial. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Dec. 1999;88(6):683-6. X-2, X-3, X-4. [pmid: 10625850].
2079 Sasahara K, Uchida Y, Matsuda K, et al. Role of energy metabolism in drug-induced acute gastric mucosal injuries in humans. J Gastroenterol Hepatol. Feb. 2000;15(2):127-32. X-2, X-3, X-4. [pmid: 10735535].
2080 Saubermann LJ, Wolf JL. Mesalamine: safe at first look. Inflamm Bowel Dis. May. 1999;5(2):148-9. X-4. [pmid: 10338388].
2081 Savabi-Esfahany M, Fadaei S, Yousefy A. Use of combined oral contraceptives: retrospective study in Isfahan, Islamic Republic of Iran. East Mediterr Health J. May-Jul. 2006;12(3-4):417-22. X-2. [pmid: 17037711].
2082 Savage AH, Anderson BL, Simhan HN. The safety of prolonged indomethacin therapy. Am J Perinatol. Apr. 2007;24(4):207-13. X-2, X-4. [pmid: 17447185].
2083 Savage KJ, Clarkson PM. Oral contraceptive use and exercise-induced muscle damage and recovery. Contraception. Jul. 2002;66(1):67-71. X-2, X-4. [pmid: 12169383].
2084 Savage RL, Moller PW, Ballantyne CL, et al. Variation in the risk of peptic ulcer complications with nonsteroidal antiinflammatory drug therapy. Arthritis Rheum. Jan. 1993;36(1):84-90. X-2. [pmid: 8424842].
2085 Sawaya GF, Grady D, Kerlikowske K, et al. The positive predictive value of cervical smears in previously screened postmenopausal women: the Heart and Estrogen/progestin Replacement Study (HERS). Ann Intern Med. Dec. 19. 2000;133(12):942-50. X-7. [pmid: 11119395].
2086 Sawhney MS, McDougall H, Nelson DB, et al. Fecal occult blood test in patients on low-dose aspirin, warfarin, clopidogrel, or non-steroidal anti-inflammatory drugs. Dig Dis Sci. Jun. 2010;55(6):1637-42. X-2, X-3, X-4. [pmid: 20195757].
2087 Saxena T, Maheshwari S, Goyal RK. Serum insulin assay: an important therapeutic tool in management of freshly diagnosed type 2 diabetes mellitus. J Assoc Physicians India. Aug. 2000;48(8):815-7. X-2, X-3, X-4. [pmid: 11273476].
2088 Scapa E, Horowitz M, Waron M, et al. Duodenal ulcer in the elderly. J Clin Gastroenterol. Oct. 1989;11(5):502-6. X-2, X-3. [pmid: 2794428].
2089 Scarabin PY, Plu-Bureau G, Zitoun D, et al. Changes in haemostatic variables induced by oral contraceptives containing 50 micrograms or 30 micrograms oestrogen: absence of dose-dependent effect on PAI-1 activity. Thromb Haemost. Sep. 1995;74(3):928-32. X-2. [pmid: 8571323].
2090 Scaricabarozzi I, Chinea B, Scotti A. Imidazole salicylate in the treatment of osteoarthrosis and musculoskeletal trauma: a postmarketing survey. Clin Ther. 1988;10(2):229-36. X-2, X-4. [pmid: 3273866].
2091 Schachter AD, Arbus GS, Alexander RJ, et al. Non-steroidal anti-inflammatory drug-associated nephrotoxicity in Bartter syndrome. Pediatr Nephrol. Nov. 1998;12(9):775-7. X-2, X-4. [pmid: 9874326].
2092 Schad SG, Kraus A, Haubitz I, et al. Early onset pauciarticular arthritis is the major risk factor for naproxen-induced pseudoporphyria in juvenile idiopathic arthritis. Arthritis Res Ther. 2007;9(1):R10. X-2. [pmid: 17266758].
2093 Schaefer MG, Plowman BK, Morreale AP, et al. Interaction of rofecoxib and celecoxib with warfarin. Am J Health Syst Pharm. Jul. 1. 2003;60(13):1319-23. X-2, X-4. [pmid: 12901032].
2094 Schaeverbeke T, Broutet N, Zerbib F, et al. Should we eradicate Helicobacter pylori before prescribing an NSAID? Result of a placebo-controlled study. Am J Gastroenterol. Dec. 2005;100(12):2637-43. X-2, X-4. [pmid: 16393213].
2095 Schalekamp T, Klungel OH, Souverein PC, et al. Increased bleeding risk with concurrent use of selective serotonin reuptake inhibitors and coumarins. Arch Intern Med. Jan. 28. 2008;168(2):180-5. X-4. [pmid: 18227365].
2096 Schatz H, Schoppel K, Lehwalder D, et al. Efficacy, tolerability and safety of nateglinide in combination with metformin. Results from a study under general practice conditions. Exp Clin Endocrinol Diabetes. Aug. 2003;111(5):262-6. X-4. [pmid: 12951631].
2097 Schechter BA, Trattler W. Efficacy and safety of bromfenac for the treatment of corneal ulcer pain. Adv Ther. Oct. 2010;27(10):756-61. X-2, X-4. [pmid: 20845001].
2098 Scheiman JM. What are the effects of cyclooxygenase-2-specific inhibitors on the small bowel?. Nat Clin Pract Gastroenterol Hepatol. May. 2005;2(5):212-3. X-2. [pmid: 16265202].
2099 Schernhammer ES, Kang JH, Chan AT, et al. A prospective study of aspirin use and the risk of pancreatic cancer in women. J Natl Cancer Inst. Jan. 7. 2004;96(1):22-8. X-4. [pmid: 14709735].
2100 Schiappacasse V, Diaz S, Zepeda A, et al. Health and growth of infants breastfed by Norplant contraceptive implants users: a six-year follow-up study. Contraception. Jul. 2002;66(1):57-65. X-2, X-4. [pmid: 12169382].
2101 Schjerning Olsen AM, Fosbol EL, Lindhardsen J, et al. Duration of treatment with nonsteroidal anti-inflammatory drugs and impact on risk of death and recurrent myocardial infarction in patients with prior myocardial infarction: a nationwide cohort study. Circulation. May. 24. 2011;123(20):2226-35. X-4. [pmid: 21555710].
2102 Schmid M, Gode U, Schafer D, et al. Arachidonic acid metabolism in nasal tissue and peripheral blood cells in aspirin intolerant asthmatics. Acta Otolaryngol. Mar. 1999;119(2):277-80. X-2, X-3, X-4. [pmid: 10320091].
2103 Schmidt M, Christiansen CF, Horvath-Puho E, et al. Non-steroidal anti-inflammatory drug use and risk of venous thromboembolism. J Thromb Haemost. Jul. 2011;9(7):1326-33. X-4. [pmid: 21592304].
2104 Schmidt M, Pedersen L, Maeng M, et al. Nonsteroidal antiinflammatory drug use and cardiovascular risks after coronary stent implantation. Pharmacotherapy. May. 2011;31(5):458-68. X-4. [pmid: 21923427].
2105 Schneeweiss S, Glynn RJ, Avorn J, et al. NSAID switching and short-term gastrointestinal outcome rates after the withdrawal of rofecoxib. Pharmacoepidemiol Drug Saf. Dec. 2009;18(12):1134-42. X-4. [pmid: 19844943].
2106 Schneeweiss S, Glynn RJ, Avorn J, et al. A Medicare database review found that physician preferences increasingly outweighed patient characteristics as determinants of first-time prescriptions for COX-2 inhibitors. J Clin Epidemiol. Jan. 2005;58(1):98-102. X-3, X-4. [pmid: 15649677].
2107 Schneider C, Jick SS, Meier CR. Risk of cardiovascular outcomes in users of estradiol/dydrogesterone or other HRT preparations. Climacteric. Oct. 2009;12(5):445-53. X-4. [pmid: 19565370].
2108 Schneider V, Levesque LE, Zhang B, et al. Association of selective and conventional nonsteroidal antiinflammatory drugs with acute renal failure: A population-based, nested case-control analysis. Am J Epidemiol. Nov. 1. 2006;164(9):881-9. X-7. [pmid: 17005625].
2109 Schnitzer TJ, Kivitz A, Frayssinet H, et al. Efficacy and safety of naproxcinod in the treatment of patients with osteoarthritis of the knee: a 13-week prospective, randomized, multicenter study. Osteoarthritis Cartilage. May. 2010;18(5):629-39. X-2, X-4. [pmid: 20202489].
2110 Scholes D, LaCroix AZ, Ichikawa LE, et al. Injectable hormone contraception and bone density: results from a prospective study. Epidemiology. Sep. 2002;13(5):581-7. X-2. [pmid: 12192229].
2111 Scholes D, LaCroix AZ, Ichikawa LE, et al. The association between depot medroxyprogesterone acetate contraception and bone mineral density in adolescent women. Contraception. Feb. 2004;69(2):99-104. X-2, X-4. [pmid: 14759613].
2112 Schramm G, Heckes B. Switching hormonal contraceptives to a chlormadinone acetate-containing oral contraceptive. The Contraceptive Switch Study. Contraception. Aug. 2007;76(2):84-90. X-4. [pmid: 17656175].
2113 Schuetz E, Sanchez J, Garcia-Barbal J, et al. Therapeutic activity, clinical and gastric tolerance of 20mg daily dose of droxicam in comparison with piroxicam in patients with degenerative joint disease. Eur J Rheumatol Inflamm. 1991;11(4):21-8. X-2, X-4. [pmid: 1365486].
2114 Schultz ST, Klonoff-Cohen HS, Wingard DL, et al. Acetaminophen (paracetamol) use, measles-mumps-rubella vaccination, and autistic disorder: the results of a parent survey. Autism. May. 2008;12(3):293-307. X-2, X-4. [pmid: 18445737].
2115 Schwarz BE, Pierce C, Walden CE, et al. Reference period analysis of vaginal bleeding with triphasic oral contraceptive agents containing norethindrone or levonorgestrel: a comparison study. Int J Fertil. May-Jun. 1992;37(3):176-82. X-2, X-3, X-4. [pmid: 1355765].
2116 Schwingl PJ, Shelton J. Modeled estimates of myocardial infarction and venous thromboembolic disease in users of second and third generation oral contraceptives. Contraception. Mar. 1997;55(3):125-9. X-2, X-4. [pmid: 9114999].
2117 Scott DL, Berry H, Capell H, et al. The long-term effects of non-steroidal anti-inflammatory drugs in osteoarthritis of the knee: a randomized placebo-controlled trial. Rheumatology (Oxford). Oct. 2000;39(10):1095-101. X-2, X-3, X-4. [pmid: 11035129].
2118 Scott KA, Martin JH, Inder WJ. Acidosis in the hospital setting: is metformin a common precipitant?. Intern Med J. May. 2010;40(5):342-6. X-2. [pmid: 19323699].
2119 Scuderi B, Driussi GB, Chizzolini M, et al. Effectiveness and tolerance of piroxicam 0.5% and diclofenac sodium 0.1% in controlling inflammation after cataract surgery. Eur J Ophthalmol. Jul. 2003;13(6):536-40. X-2, X-3, X-4. [pmid: 12948311].
2120 Seaman HE, de Vries CS, Farmer RD. The risk of liver disorders in women prescribed cyproterone acetate in combination with ethinyloestradiol (Dianette): a nested case-control study using the GPRD. Pharmacoepidemiol Drug Saf. Oct-Nov. 2003;12(7):541-50. X-4. [pmid: 14558177].
2121 Seaman HE, de Vries CS, Farmer RD. Venous thromboembolism associated with cyproterone acetate in combination with ethinyloestradiol (Dianette): observational studies using the UK General Practice Research Database. Pharmacoepidemiol Drug Saf. Jul. 2004;13(7):427-36. X-4. [pmid: 15269926].
2122 Sebaldt RJ, Petrie A, Goldsmith CH, et al. Appropriateness of NSAID and Coxib prescribing for patients with osteoarthritis by primary care physicians in Ontario: results from the CANOAR study. Am J Manag Care. Nov. 2004;10(11 Pt 1):742-50. X-2, X-3, X-4. [pmid: 15623264].
2123 See Y, Ng SC, Tho KS, et al. Are antacids necessary as routine prescriptives with non-steroidal anti-inflammatory drugs?. Ann Acad Med Singapore. Mar. 1998;27(2):219-22. X-2, X-4. [pmid: 9663314].
2124 Seeger JD, Loughlin J, Eng PM, et al. Risk of thromboembolism in women taking ethinylestradiol/drospirenone and other oral contraceptives. Obstet Gynecol. Sep. 2007;110(3):587-93. X-4. [pmid: 17766604].
2125 Segal R, Lubart E, Leibovitz A, et al. Early and late effects of low-dose aspirin on renal function in elderly patients. Am J Med. Oct. 15. 2003;115(6):462-6. X-2, X-4. [pmid: 14563503].
2126 Segal R, Lubart E, Leibovitz A, et al. Renal effects of low dose aspirin in elderly patients. Isr Med Assoc J. Oct. 2006;8(10):679-82. X-2, X-3, X-4. [pmid: 17125112].
2127 Segall-Gutierrez P, Xiang AH, Watanabe RM, et al. Deterioration in cardiometabolic risk markers in obese women during depot medroxyprogesterone acetate use. Contraception. Jan. 2012;85(1):36-41. X-2. [pmid: 22067800].
2128 Segasothy M, Cheong I, Kong BC, et al. Further evidence of analgesic nephropathy in Malaysia. Med J Malaysia. Dec. 1986;41(4):377-9. X-2. [pmid: 3670164].
2129 Segasothy M, Chin GL, Sia KK, et al. Chronic nephrotoxicity of anti-inflammatory drugs used in the treatment of arthritis. Br J Rheumatol. Feb. 1995;34(2):162-5. X-2. [pmid: 7704463].
2130 Segasothy M, Samad SA, Zulfigar A, et al. Chronic renal disease and papillary necrosis associated with the long-term use of nonsteroidal anti-inflammatory drugs as the sole or predominant analgesic. Am J Kidney Dis. Jul. 1994;24(1):17-24. X-2. [pmid: 8023820].
2131 Segstro R, Morley-Forster PK, Lu G. Indomethacin as a postoperative analgesic for total hip arthroplasty. Can J Anaesth. Jul. 1991;38(5):578-81. X-2, X-4. [pmid: 1934204].
2132 Seidowsky A, Nseir S, Houdret N, et al. Metformin-associated lactic acidosis: a prognostic and therapeutic study. Crit Care Med. Jul. 2009;37(7):2191-6. X-2, X-3, X-4. [pmid: 19487945].
2133 Sell S, Phillips O, Handel M. No difference between two doses of diclofenac in prophylaxis of heterotopic ossifications after total hip arthroplasty. Acta Orthop Scand. Feb. 2004;75(1):45-9. X-2, X-4. [pmid: 15022805].
2134 Sen M, Ozol D, Bozer M. Influence of preemptive analgesia on pulmonary function and complications for laparoscopic cholecystectomy. Dig Dis Sci. Dec. 2009;54(12):2742-7. X-2, X-3, X-4. [pmid: 19117121].
2135 Sener M, Yilmazer C, Yilmaz I, et al. Patient-controlled analgesia with lornoxicam vs. dipyrone for acute postoperative pain relief after septorhinoplasty: a prospective, randomized, double-blind, placebo-controlled study. Eur J Anaesthesiol. Mar. 2008;25(3):177-82. X-2, X-3, X-4. [pmid: 17953792].
2136 Senna GE, Passalacqua G, Dama A, et al. Nimesulide and meloxicam are a safe alternative drugs for patients intolerant to nonsteroidal anti-inflammatory drugs. Eur Ann Allergy Clin Immunol. Dec. 2003;35(10):393-6. X-2, X-3, X-4. [pmid: 14768525].
2137 Sereepapong W, Chotnopparatpattara P, Taneepanichskul S, et al. Endometrial progesterone and estrogen receptors and bleeding disturbances in depot medroxyprogesterone acetate users. Hum Reprod. Mar. 2004;19(3):547-52. X-2, X-3, X-4. [pmid: 14998949].
2138 Serni U. Global safety of etodolac: reports from worldwide postmarketing surveillance studies. Rheumatol Int. 1990;10(Suppl):23-7. X-1, X-4. [pmid: 2150568].
2139 Serrano P, Lanas A, Arroyo MT, et al. Risk of upper gastrointestinal bleeding in patients taking low-dose aspirin for the prevention of cardiovascular diseases. Aliment Pharmacol Ther. Nov. 2002;16(11):1945-53. X-2, X-4. [pmid: 12390104].
2140 Shaaban MM, Salah M. A two-year experience with Norplant implants in Assiut, Egypt. Contraception. Apr. 1984;29(4):335-43. X-2, X-3, X-4. [pmid: 6430639].
2141 Shaaban MM, Salah M, Zarzour A, et al. A prospective study of NORPLANT implants and the TCu 380AgIUD in Assiut, Egypt. Stud Fam Plann. Jun-Jul. 1983;14(6-7):163-9. X-2, X-4. [pmid: 6414117].
2142 Shaaban MM, Zakherah MS, El-Nashar SA, et al. Levonorgestrel-releasing intrauterine system compared to low dose combined oral contraceptive pills for idiopathic menorrhagia: a randomized clinical trial. Contraception. Jan. 2011;83(1):48-54. X-2, X-3, X-4. [pmid: 21134503].
2143 Shaamash AH, Sayed GH, Hussien MM, et al. A comparative study of the levonorgestrel-releasing intrauterine system Mirena versus the Copper T380A intrauterine device during lactation: breast-feeding performance, infant growth and infant development. Contraception. Nov. 2005;72(5):346-51. X-2, X-4. [pmid: 16246660].
2144 Shaamash AH, Zakhari MM. Increased serum levels of nitric oxide metabolites among users of levonorgestrel-releasing implants [corrected] a possible role in progestin-induced bleeding. Hum Reprod. Jan. 2005;20(1):302-6. X-2, X-4. [pmid: 15471931].
2145 Shaarawy M, El-Mallah SY, Seoudi S, et al. Effects of the long-term use of depot medroxyprogesterone acetate as hormonal contraceptive on bone mineral density and biochemical markers of bone remodeling. Contraception. Oct. 2006;74(4):297-302. X-2. [pmid: 16982229].
2146 Shaffer CL, Gal P, Ransom JL, et al. Effect of age and birth weight on indomethacin pharmacodynamics in neonates treated for patent ductus arteriosus. Crit Care Med. Feb. 2002;30(2):343-8. X-2, X-4. [pmid: 11889306].
2147 Shah DD, Fonarow GC, Horwich TB. Metformin therapy and outcomes in patients with advanced systolic heart failure and diabetes. J Card Fail. Mar. 2010;16(3):200-6. X-2, X-4. [pmid: 20206893].
2148 Shah JA, Edwards CM, Probert CS. Should azathioprine and 5-aminosalicylates be coprescribed in inflammatory bowel disease?: an audit of adverse events and outcome. Eur J Gastroenterol Hepatol. Mar. 2008;20(3):169-73. X-2, X-4. [pmid: 18301295].
2149 Shah SK, Arthur A, Yang YC, et al. A retrospective study to investigate racial and ethnic variations in the treatment of psoriasis with etanercept. J Drugs Dermatol. Aug. 2011;10(8):866-72. X-2, X-3, X-4. [pmid: 21818507].
2150 Shaheen SO, Newson RB, Henderson AJ, et al. Prenatal paracetamol exposure and risk of asthma and elevated immunoglobulin E in childhood. Clin Exp Allergy. Jan. 2005;35(1):18-25. X-4. [pmid: 15649261].
2151 Shainhouse JZ, Grierson LM, Naseer Z. A long-term, open-label study to confirm the safety of topical diclofenac solution containing dimethyl sulfoxide in the treatment of the osteoarthritic knee. Am J Ther. Nov-Dec. 2010;17(6):566-76. X-2, X-4. [pmid: 20216203].
2152 Shamim N, Rehan N, Inayatullah A. Use of Norplant in Pakistan: two years experience. J Pak Med Assoc. Jan. 1994;44(1):3-7. X-2, X-3, X-4. [pmid: 8158837].
2153 Shankel SW, Johnson DC, Clark PS, et al. Acute renal failure and glomerulopathy caused by nonsteroidal anti-inflammatory drugs. Arch Intern Med. May. 1992;152(5):986-90. X-2. [pmid: 1580726].
2154 Shapiro S, Rosenberg L, Hoffman M, et al. Risk of breast cancer in relation to the use of injectable progestogen contraceptives and combined estrogen/progestogen contraceptives. Am J Epidemiol. Feb. 15. 2000;151(4):396-403. X-4. [pmid: 10695598].
2155 Shargil AA. Hormone replacement therapy in perimenopausal women with a triphasic contraceptive compound: a three-year prospective study. Int J Fertil. 8. 1985;30(1):15-28. X-2, X-3, X-4. [pmid: 2862116].
2156 Sharma A, Gupta R, Ram J, et al. Topical ketorolac 0.5% solution for the treatment of vernal keratoconjunctivitis. Indian J Ophthalmol. Sep. 1997;45(3):177-80. X-2, X-3, X-4. [pmid: 9475021].
2157 Sharma S. Upper gastrointestinal bleeding after hip and knee arthroplasty. Orthopedics. Mar. 2006;29(3):255-7. X-2. [pmid: 16539204].
2158 Sharma S, Chang DW, Koutz C, et al. Incidence of hematoma associated with ketorolac after TRAM flap breast reconstruction. Plast Reconstr Surg. Feb. 2001;107(2):352-5. X-2, X-4. [pmid: 11214049].
2159 Sharma ST, Wickham EP 3rd, Nestler JE. Changes in glucose tolerance with metformin treatment in polycystic ovary syndrome: a retrospective analysis. Endocr Pract. Jul-Aug. 2007;13(4):373-9. X-2, X-3, X-4. [pmid: 17669713].
2160 Sharma VK, Sethuraman G, Kumar B. Cutaneous adverse drug reactions: clinical pattern and causative agents--a 6 year series from Chandigarh, India. J Postgrad Med. Apr-Jun. 2001;47(2):95-9. X-2. [pmid: 11832597].
2161 Sharma VK, Sethuraman G, Minz A. Stevens Johnson syndrome, toxic epidermal necrolysis and SJS-TEN overlap: a retrospective study of causative drugs and clinical outcome. Indian J Dermatol Venereol Leprol. May-Jun. 2008;74(3):238-40. X-2. [pmid: 18583791].
2162 Shaw RW, Symonds IM, Tamizian O, et al. Randomised comparative trial of thermal balloon ablation and levonorgestrel intrauterine system in patients with idiopathic menorrhagia. Aust N Z J Obstet Gynaecol. Aug. 2007;47(4):335-40. X-2, X-3. [pmid: 17627692].
2163 Shawki O, Peters A, Abraham-Hebert S. Hysteroscopic endometrial destruction, optimum method for preoperative endometrial preparation: a prospective, randomized, multicenter evaluation. JSLS. Jan-Mar. 2002;6(1):23-7. X-2, X-4. [pmid: 12002292].
2164 Shaya FT, Blume SW, Blanchette CM, et al. Selective cyclooxygenase-2 inhibition and cardiovascular effects: an observational study of a Medicaid population. Arch Intern Med. Jan. 24. 2005;165(2):181-6. X-4. [pmid: 15668364].
2165 Sheffield CA, Kane MP, Busch RS, et al. Safety and efficacy of exenatide in combination with insulin in patients with type 2 diabetes mellitus. Endocr Pract. Apr. 2008;14(3):285-92. X-2, X-3, X-4. [pmid: 18463034].
2166 Shegem NS, Alsheek Nasir AM, Batieha AM, et al. Effects of short term metformin administration on androgens in diabetic men. Saudi Med J. Jan. 2004;25(1):75-8. X-2, X-3, X-4. [pmid: 14758385].
2167 Shen B, Fazio VW, Remzi FH, et al. Effect of withdrawal of nonsteroidal anti-inflammatory drug use on ileal pouch disorders. Dig Dis Sci. Dec. 2007;52(12):3321-8. X-2, X-3, X-4. [pmid: 17410449].
2168 Sheng J, Zhang WY, Zhang JP, et al. The LNG-IUS study on adenomyosis: a 3-year follow-up study on the efficacy and side effects of the use of levonorgestrel intrauterine system for the treatment of dysmenorrhea associated with adenomyosis. Contraception. Mar. 2009;79(3):189-93. X-2. [pmid: 19185671].
2169 Shepherd WF, Fsadni MG, Raj PS. A clinical evaluation of diclofenac-gentamicin combination eye drops in the control of inflammation after cataract surgery. Diclofenac-Gentamicin versus Gentamicin Study Group. Ocul Immunol Inflamm. Mar. 1998;6(1):13-8. X-2, X-3, X-4. [pmid: 9798189].
2170 Sherman KJ, Daling JR, McKnight B, et al. Hormonal factors in vulvar cancer. A case-control study. J Reprod Med. Nov. 1994;39(11):857-61. X-2, X-4. [pmid: 7853273].
2171 Shi W, Wang YM, Li SL, et al. Adverse effect of drug-induced emotional problems on work and daily activities. A principal component as an independent predictor of ADRs in Shanghai patients with osteo-arthropathy taking nabumetone. Int J Clin Pharmacol Ther. Jun. 2004;42(6):321-7. X-2, X-3, X-4. [pmid: 15222724].
2172 Shi W, Wang YM, Li SL, et al. Risk factors of adverse drug reaction from non-steroidal anti-inflammatory drugs in Shanghai patients with arthropathy. Acta Pharmacol Sin. Mar. 2004;25(3):357-65. X-2. [pmid: 15000891].
2173 Shibuya T, Ohkusa T, Yokoyama T, et al. Colonic mucosal lesions associated with long-term or short-term administration of nonsteroidal anti-inflammatory drugs. Colorectal Dis. Nov. 2010;12(11):1113-21. X-2, X-4. [pmid: 19817771].
2174 Shiffman ML, Farrel MT, Yee YS. Risk of bleeding after endoscopic biopsy or polypectomy in patients taking aspirin or other NSAIDS. Gastrointest Endosc. Jul-Aug. 1994;40(4):458-62. X-2, X-4. [pmid: 7926536].
2175 Shimizu S, Nakamura S, Kishino M, et al. Role of antithrombotic therapy and nonsteroidal anti-inflammatory drug use in bleeding gastroduodenal ulcers. Intern Med. 2009;48(9):631-7. X-2. [pmid: 19420807].
2176 Shin D, Kim S, Kim CS, et al. Postoperative pain management using intravenous patient-controlled analgesia for pediatric patients. J Craniofac Surg. Mar. 2001;12(2):129-33. X-2, X-4. [pmid: 11314621].
2177 Shin YS, Lee YW, Choi YH, et al. Spontaneous reporting of adverse drug events by Korean regional pharmacovigilance centers. Pharmacoepidemiol Drug Saf. Oct. 2009;18(10):910-5. X-2, X-4. [pmid: 19621345].
2178 Shiraishi M, Kamo T, Hotta M, et al. Usefulness of switching to cabergoline from other dopamine agonists in patients with advanced Parkinson's disease. J Neural Transm. Jun. 2004;111(6):725-32. X-2. [pmid: 15168219].
2179 Shiuey Y, Ambati BK, Adamis AP. A randomized, double-masked trial of topical ketorolac versus artificial tears for treatment of viral conjunctivitis. Ophthalmology. Aug. 2000;107(8):1512-7. X-2, X-3, X-4. [pmid: 10919900].
2180 Shore-Lesserson L, Reich DL, Vela-Cantos F, et al. Tranexamic acid reduces transfusions and mediastinal drainage in repeat cardiac surgery. Anesth Analg. Jul. 1996;83(1):18-26. X-2, X-4. [pmid: 8659732].
2181 Shorr RI, Ray WA, Daugherty JR, et al. Concurrent use of nonsteroidal anti-inflammatory drugs and oral anticoagulants places elderly persons at high risk for hemorrhagic peptic ulcer disease. Arch Intern Med. Jul. 26. 1993;153(14):1665-70. X-4, X-7. [pmid: 8333804].
2182 Shorter NA, Liu JY, Mooney DP, et al. Indomethacin-associated bowel perforations: a study of possible risk factors. J Pediatr Surg. Mar. 1999;34(3):442-4. X-2, X-4. [pmid: 10211650].
2183 Shoupe D. Multicenter randomized comparative trial of two low-dose triphasic combined oral contraceptives containing desogestrel or norethindrone. Obstet Gynecol. May. 1994;83(5 Pt 1):679-85. X-2, X-4. [pmid: 8164925].
2184 Shoupe D, Mishell DR Jr., Bopp BL, et al. The significance of bleeding patterns in Norplant implant users. Obstet Gynecol. Feb. 1991;77(2):256-60. X-2, X-3, X-4. [pmid: 1899135].
2185 Shrivastava D, Rao TK, Sinert R, et al. The efficacy of erythropoietin in human immunodeficiency virus-infected end-stage renal disease patients treated by maintenance hemodialysis. Am J Kidney Dis. Jun. 1995;25(6):904-9. X-2, X-3, X-4. [pmid: 7771487].
2186 Shrivastava M, Uchit G, Chakravarti A, et al. Adverse drug reactions reported in Indira Gandhi Government Medical College and Hospital, Nagpur. J Assoc Physicians India. May. 2011;59:296-9. X-4. [pmid: 21751606].
2187 Shulman LP. The use of triphasic oral contraceptives in a continuous use regimen. Contraception. Aug. 2005;72(2):105-10. X-2, X-4. [pmid: 16022848].
2188 Sidney S, Petitti DB, Soff GA, et al. Venous thromboembolic disease in users of low-estrogen combined estrogen-progestin oral contraceptives. Contraception. Jul. 2004;70(1):3-10. X-2. [pmid: 15208046].
2189 Silberstein SD, Armellino JJ, Hoffman HD, et al. Treatment of menstruation-associated migraine with the nonprescription combination of acetaminophen, aspirin, and caffeine: results from three randomized, placebo-controlled studies. Clin Ther. Mar. 1999;21(3):475-91. X-2, X-3, X-4. [pmid: 10321417].
2190 Sillars B, Davis WA, Hirsch IB, et al. Sulphonylurea-metformin combination therapy, cardiovascular disease and all-cause mortality: the Fremantle Diabetes Study. Diabetes Obes Metab. Sep. 2010;12(9):757-65. X-2. [pmid: 20649627].
2191 Silverberg KM, Vaughn TC, Hansard LJ, et al. Vaginal (Crinone 8%) gel vs. intramuscular progesterone in oil for luteal phase support in in vitro fertilization: a large prospective trial. Fertil Steril. Feb. 2012;97(2):344-8. X-2, X-3, X-4. [pmid: 22188983].
2192 Silverman HS, Pfeifer MP. Relation between use of anti-inflammatory agents and left ventricular free wall rupture during acute myocardial infarction. Am J Cardiol. Feb. 1. 1987;59(4):363-4. X-2. [pmid: 3812291].
2193 Silverstein FE, Faich G, Goldstein JL, et al. Gastrointestinal toxicity with celecoxib vs nonsteroidal anti-inflammatory drugs for osteoarthritis and rheumatoid arthritis: the CLASS study: A randomized controlled trial. Celecoxib Long-term Arthritis Safety Study. JAMA. Sep. 13. 2000;284(10):1247-55. X-4. [pmid: 10979111].
2194 Simenon G, Van Gossum A, Adler M, et al. Macroscopic and microscopic gut lesions in seronegative spondyloarthropathies. J Rheumatol. Nov. 1990;17(11):1491-4. X-2, X-4. [pmid: 1980311].
2195 Simon CH, Dijkmans BA, Breedveld FC. Variations in the monitoring and management of the side effects of antirheumatic drugs by means of laboratory tests. Clin Exp Rheumatol. Nov-Dec. 1997;15(6):633-9. X-2, X-3, X-4. [pmid: 9444419].
2196 Simon JA, Lin F, Vittinghoff E, et al. The relation of postmenopausal hormone therapy to serum uric acid and the risk of coronary heart disease events: the Heart and Estrogen-Progestin Replacement Study (HERS). Ann Epidemiol. Feb. 2006;16(2):138-45. X-7. [pmid: 16039873].
2197 Simon LS, Weaver AL, Graham DY, et al. Anti-inflammatory and upper gastrointestinal effects of celecoxib in rheumatoid arthritis: a randomized controlled trial. JAMA. Nov. 24. 1999;282(20):1921-8. X-2. [pmid: 10580457].
2198 Simon LS, Zhao SZ, Arguelles LM, et al. Economic and gastrointestinal safety comparisons of etodolac, nabumetone, and oxaprozin from insurance claims data from patients with arthritis. Clin Ther. Nov-Dec. 1998;20(6):1218-35. discussion 192-3. X-4. [pmid: 9916614].
2199 Simunic V, Tomic V, Tomic J, et al. Comparative study of the efficacy and tolerability of two vaginal progesterone formulations, Crinone 8% gel and Utrogestan capsules, used for luteal support. Fertil Steril. Jan. 2007;87(1):83-7. X-2, X-3, X-4. [pmid: 17081536].
2200 Sinclair HK, Bond CM, Hannaford PC. Long term follow-up studies of users of nonprescription medicines purchased from community pharmacies: some methodological issues. Drug Saf. 2001;24(12):929-38. X-2, X-4. [pmid: 11735649].
2201 Singh G, Fries JF, Williams CA, et al. Toxicity profiles of disease modifying antirheumatic drugs in rheumatoid arthritis. J Rheumatol. Feb. 1991;18(2):188-94. X-4. [pmid: 1673721].
2202 Singh G, Ramey DR, Morfeld D, et al. Gastrointestinal tract complications of nonsteroidal anti- inflammatory drug treatment in rheumatoid arthritis. A prospective observational cohort study. Arch Intern Med. Jul. 22. 1996;156(14):1530-6. X-4. [pmid: 8687261].
2203 Singh K, Viegas OA, Fong YF, et al. Acceptability of Norplant implants for fertility regulation in Singapore. Contraception. Jan. 1992;45(1):39-47. X-2, X-4. [pmid: 1591920].
2204 Singh K, Viegas OA, Loke DF, et al. Evaluation of liver function and lipid metabolism following Norplant-2 rods removal. Adv Contracept. Sep. 1993;9(3):233-9. X-2, X-4. [pmid: 8237578].
2205 Singh K, Viegas OA, Ratnam SS. Norplant contraceptive subdermal implants: one year experience in Singapore. Contraception. May. 1988;37(5):457-69. X-2, X-4. [pmid: 3136971].
2206 Singh K, Viegas OA, Ratnam SS. A three-year evaluation of hemostatic function in Singaporean Norplant-2 rod acceptors. Adv Contracept. Jun. 1990;6(2):81-9. X-2. [pmid: 2119546].
2207 Singh R, al-Amari M. Clinical performance of intrauterine device TCu-380 A in Benghazi, Libyan Arab Jamahiriya. East Mediterr Health J. Sep-Nov. 2000;6(5-6):1073-82. X-2, X-4. [pmid: 12197330].
2208 Siskind V. Confidence intervals for the excess risk in case-control studies. Stat Med. Jul. 30. 1996;15(14):1535-44. X-1, X-2, X-8. [pmid: 8855479].
2209 Sivak-Sears NR, Schwartzbaum JA, Miike R, et al. Case-control study of use of nonsteroidal antiinflammatory drugs and glioblastoma multiforme. Am J Epidemiol. Jun. 15. 2004;159(12):1131-9. X-2, X-4. [pmid: 15191930].
2210 Sivin I, Diaz S, Pavez M, et al. Two-year comparative trial of the Gyne T* 380 Slimline and Gyne T* 380 intrauterine copper devices. Contraception. Nov. 1991;44(5):481-7. X-4. [pmid: 1797463].
2211 Sivin I, Mishell DR Jr., Darney P, et al. Levonorgestrel capsule implants in the United States: a 5-year study. Obstet Gynecol. Sep. 1998;92(3):337-44. X-2, X-4. [pmid: 9721766].
2212 Sivin I, Stern J. Health during prolonged use of levonorgestrel 20 micrograms/d and the copper TCu 380Ag intrauterine contraceptive devices: a multicenter study. International Committee for Contraception Research (ICCR). Fertil Steril. Jan. 1994;61(1):70-7. X-2. [pmid: 8293847].
2213 Sivin I, Stern J, Coutinho E, et al. Prolonged intrauterine contraception: a seven-year randomized study of the levonorgestrel 20 mcg/day (LNg 20) and the Copper T380 Ag IUDS. Contraception. Nov. 1991;44(5):473-80. X-2. [pmid: 1797462].
2214 Skander MP, Ryan FP. Non-steroidal anti-inflammatory drugs and pain free peptic ulceration in the elderly. BMJ. Oct. 1. 1988;297(6652):833-4. X-2, X-7. [pmid: 3140938].
2215 Skjeldestad F, Bratt H. Fertility after complicated and non-complicated use of IUDs. A controlled prospective study. Adv Contracept. Sep. 1988;4(3):179-84. X-2, X-3, X-4. [pmid: 3239478].
2216 Slattery ML, Curtin K, Ma K, et al. Diet activity, and lifestyle associations with p53 mutations in colon tumors. Cancer Epidemiol Biomarkers Prev. Jun. 2002;11(6):541-8. X-2, X-3, X-4. [pmid: 12050095].
2217 Slattery ML, Schaffer D, Edwards SL, et al. Are dietary factors involved in DNA methylation associated with colon cancer?. Nutr Cancer. 1997;28(1):52-62. X-4. [pmid: 9200151].
2218 Slatyer MA, Hensley MJ, Lopert R. A randomized controlled trial of piroxicam in the management of acute ankle sprain in Australian Regular Army recruits. The Kapooka Ankle Sprain Study. Am J Sports Med. Jul-Aug. 1997;25(4):544-53. X-2, X-3, X-4. [pmid: 9240990].
2219 Smalley W, Stein CM, Arbogast PG, et al. Underutilization of gastroprotective measures in patients receiving nonsteroidal antiinflammatory drugs. Arthritis Rheum. Aug. 2002;46(8):2195-200. X-3, X-4. [pmid: 12209525].
2220 Smalley WE, Ray WA, Daugherty JR, et al. Nonsteroidal anti-inflammatory drugs and the incidence of hospitalizations for peptic ulcer disease in elderly persons. Am J Epidemiol. Mar. 15. 1995;141(6):539-45. X-4, X-7. [pmid: 7900721].
2221 Smedley FH, Taube M, Leach R, et al. Non-steroidal anti-inflammatory drug ingestion: retrospective study of 272 bleeding or perforated peptic ulcers. Postgrad Med J. Dec. 1989;65(770):892-5. X-2. [pmid: 2616429].
2222 Smets HL, De Haes JF, De Swaef A, et al. Exposure of the elderly to potential nephrotoxic drug combinations in Belgium. Pharmacoepidemiol Drug Saf. Oct. 2008;17(10):1014-9. X-3, X-4. [pmid: 18763247].
2223 Smith I, Wilde A. Secondary tonsillectomy haemorrhage and non-steroidal anti-inflammatory drugs. J Laryngol Otol. Jan. 1999;113(1):28-30. X-2. [pmid: 10341915].
2224 Smith KJ, Skelton HG, Yeager J, et al. Pruritus in HIV-1 disease: therapy with drugs which may modulate the pattern of immune dysregulation. Dermatology. 1997;195(4):353-8. X-4. [pmid: 9529556].
2225 Smith MA, Hampton C, Rodier L, et al. Informatics. Detecting risks in elderly patients taking NSAIDs. Nurse Pract. Apr. 2011;36(4):51-3. X-1. [pmid: 21422979].
2226 Smith NL, Wiley JR, Legault C, et al. Effect of progestogen and progestogen type on hemostasis measures in postmenopausal women: the Postmenopausal Estrogen/Progestin Intervention (PEPI) Study. Menopause. Nov-Dec. 2008;15(6):1145-50. X-2, X-7. [pmid: 19186375].
2227 Smith TR, Sunshine A, Stark SR, et al. Sumatriptan and naproxen sodium for the acute treatment of migraine. Headache. Sep. 2005;45(8):983-91. X-2, X-3, X-4. [pmid: 16109111].
2228 Snaith A, Pugh L, Simpson CR, et al. The potential for interaction between warfarin and coprescribed medication: a retrospective study in primary care. Am J Cardiovasc Drugs. 2008;8(3):207-12. X-4. [pmid: 18533741].
2229 Snell ES. Regulatory decisions and the pharmaceutical industry. Med Toxicol. Suppl 1. 1986;1:130-6. X-1, X-2, X-3, X-4. [pmid: 3821429].
2230 Snowden R. General assessment of the Multiload Cu250 intrauterine device. UK network of IUCD research clinics. Br J Obstet Gynaecol. Sep. 1982;89(Suppl 4):58-65. X-2, X-3, X-4. [pmid: 7150529].
2231 Snyder BK, Clark RF. Effect of magnesium hydroxide administration on iron absorption after a supratherapeutic dose of ferrous sulfate in human volunteers: a randomized controlled trial. Ann Emerg Med. Apr. 1999;33(4):400-5. X-2, X-3, X-4. [pmid: 10092717].
2232 So LY, Fok TF, Sung RY, et al. Preterm infants with patent ductus arteriosus: treatment with an enteral preparation of indomethacin. Ann Trop Paediatr. 1992;12(4):403-8. X-2, X-3, X-4. [pmid: 1283670].
2233 Sobande AA, Al-Bar HM, Archibong EI, et al. Efficacy and acceptability of depo-medroxyprogesterone acetate injection. As a method of contraception in Saudi Arabia. Saudi Med J. Apr. 2000;21(4):348-51. X-2. [pmid: 11533816].
2234 Soderstrom RM. Will progesterone save the IUD?. J Reprod Med. May. 1983;28(5):305-8. X-2. [pmid: 6152982].
2235 Soeprono R. Extended use of the Multiload Cu-250. Adv Contracept. Jun. 1988;4(2):109-13. X-4. [pmid: 3213667].
2236 Soheilian M, Karimi S, Ramezani A, et al. Pilot study of intravitreal injection of diclofenac for treatment of macular edema of various etiologies. Retina. Mar. 2010;30(3):509-15. X-2, X-4. [pmid: 19952986].
2237 Sohn SH, Penzias AS, Emmi AM, et al. Administration of progesterone before oocyte retrieval negatively affects the implantation rate. Fertil Steril. Jan. 1999;71(1):11-4. X-2, X-3, X-4. [pmid: 9935109].
2238 Sokic-Milutinovic A, Krstic M, Rozer-Smolovic B, et al. Role of Helicobacter pylori infection in gastroduodenal damage in patients starting NSAID therapy: 4 Months follow-up study. Dig Dis Sci. Oct. 2010;55(10):2887-92. X-2. [pmid: 20094785].
2239 Solak O, Metin M, Esme H, et al. Effectiveness of gabapentin in the treatment of chronic post-thoracotomy pain. Eur J Cardiothorac Surg. Jul. 2007;32(1):9-12. X-2, X-4. [pmid: 17442584].
2240 Solomon DH, Avorn J, Sturmer T, et al. Cardiovascular outcomes in new users of coxibs and nonsteroidal antiinflammatory drugs: high-risk subgroups and time course of risk. Arthritis Rheum. May. 2006;54(5):1378-89. X-7. [pmid: 16645966].
2241 Solomon DH, Cadarette SM, Choudhry NK, et al. A cohort study of thiazolidinediones and fractures in older adults with diabetes. J Clin Endocrinol Metab. Aug. 2009;94(8):2792-8. X-7. [pmid: 19470635].
2242 Solomon DH, Glynn RJ, Bohn R, et al. The hidden cost of nonselective nonsteroidal antiinflammatory drugs in older patients. J Rheumatol. Apr. 2003;30(4):792-8. X-4, X-7. [pmid: 12672201].
2243 Solomon DH, Glynn RJ, Rothman KJ, et al. Subgroup analyses to determine cardiovascular risk associated with nonsteroidal antiinflammatory drugs and coxibs in specific patient groups. Arthritis Rheum. Aug. 15. 2008;59(8):1097-104. X-4. [pmid: 18668605].
2244 Solomon DH, Rassen JA, Glynn RJ, et al. The comparative safety of opioids for nonmalignant pain in older adults. Arch Intern Med. Dec. 13. 2010;170(22):1979-86. X-4. [pmid: 21149754].
2245 Solomon DH, Schneeweiss S, Glynn RJ, et al. Relationship between selective cyclooxygenase-2 inhibitors and acute myocardial infarction in older adults. Circulation. May. 4. 2004;109(17):2068-73. X-7. [pmid: 15096449].
2246 Solomon DH, Schneeweiss S, Glynn RJ, et al. Determinants of selective cyclooxygenase-2 inhibitor prescribing: are patient or physician characteristics more important?. Am J Med. Dec. 15. 2003;115(9):715-20. X-7. [pmid: 14693324].
2247 Solomon KD, Turkalj JW, Whiteside SB, et al. Topical 0.5% ketorolac vs 0.03% flurbiprofen for inhibition of miosis during cataract surgery. Arch Ophthalmol. Sep. 1997;115(9):1119-22. X-2, X-3, X-4. [pmid: 9298051].
2248 Somigliana E, Vercellini P, Vigano P, et al. Endometriosis and estroprogestins: the chicken or the egg causality dilemma. Fertil Steril. Jan. 2011;95(1):431-3. X-2. [pmid: 20883987].
2249 Sonmezer M, Atabekoglu C, Cengiz B, et al. Depot-medroxyprogesterone acetate in anticoagulated patients with previous hemorrhagic corpus luteum. Eur J Contracept Reprod Health Care. Mar. 2005;10(1):9-14. X-2. [pmid: 16036292].
2250 Sood A, Midha V, Sood N, et al. Azathioprine versus sulfasalazine in maintenance of remission in severe ulcerative colitis. Indian J Gastroenterol. May-Jun. 2003;22(3):79-81. X-2, X-4. [pmid: 12839376].
2251 Sood BG, Lulic-Botica M, Holzhausen KA, et al. The risk of necrotizing enterocolitis after indomethacin tocolysis. Pediatrics. Jul. 2011;128(1):e54-62. X-2, X-4. [pmid: 21690109].
2252 Sopena F, Lanas A, Sainz R. Esophageal motility and intraesophageal pH patterns in patients with esophagitis and chronic nonsteroidal anti-inflammatory drug use. J Clin Gastroenterol. Dec. 1998;27(4):316-20. X-2. [pmid: 9855260].
2253 Soraisham AS, Dalgleish S, Singhal N. Antenatal indomethacin tocolysis is associated with an increased need for surgical ligation of patent ductus arteriosus in preterm infants. J Obstet Gynaecol Can. May. 2010;32(5):435-42. X-2, X-4. [pmid: 20500951].
2254 Soraisham AS, Sauve R, Singhal N. Indomethacin tocolysis and neurodevelopmental outcome. Indian J Pediatr. Aug. 2011;78(8):946-52. X-2, X-4. [pmid: 21318396].
2255 Soranna L, Cucinelli F, Perri C, et al. Individual effect of E2 and dydrogesterone on insulin sensitivity in post-menopausal women. J Endocrinol Invest. Jun. 2002;25(6):547-50. X-2, X-4. [pmid: 12109627].
2256 Sorensen HT, Jacobsen J, Norgaard M, et al. Newer cyclo-oxygenase-2 selective inhibitors, other non-steroidal anti-inflammatory drugs and the risk of acute pancreatitis. Aliment Pharmacol Ther. Jul. 1. 2006;24(1):111-6. X-4. [pmid: 16803609].
2257 Sorensen HT, Mellemkjaer L, Blot WJ, et al. Risk of upper gastrointestinal bleeding associated with use of low-dose aspirin. Am J Gastroenterol. Sep. 2000;95(9):2218-24. X-2, X-4. [pmid: 11007221].
2258 Souter D, Harding J, McCowan L, et al. Antenatal indomethacin--adverse fetal effects confirmed. Aust N Z J Obstet Gynaecol. Feb. 1998;38(1):11-6. X-2, X-4. [pmid: 9521382].
2259 Souyri C, Olivier P, Grolleau S, et al. Severe necrotizing soft-tissue infections and nonsteroidal anti-inflammatory drugs. Clin Exp Dermatol. May. 2008;33(3):249-55. X-2. [pmid: 18261144].
2260 Souza AI, Batista Filho M, Bresani CC, et al. Adherence and side effects of three ferrous sulfate treatment regimens on anemic pregnant women in clinical trials. Cad Saude Publica. Jun. 2009;25(6):1225-33. X-2, X-4. [pmid: 19503953].
2261 Sowers JR, White WB, Pitt B, et al. The Effects of cyclooxygenase-2 inhibitors and nonsteroidal anti-inflammatory therapy on 24-hour blood pressure in patients with hypertension, osteoarthritis, and type 2 diabetes mellitus. Arch Intern Med. Jan. 24. 2005;165(2):161-8. X-2, X-4. [pmid: 15668361].
2262 Soylu A, Dolapcioglu C, Dolay K, et al. Endoscopic and histopathological evaluation of acute gastric injury in high-dose acetaminophen and nonsteroidal anti-inflammatory drug ingestion with suicidal intent. World J Gastroenterol. Nov. 21. 2008;14(43):6704-10. X-2. [pmid: 19034975].
2263 Soysal M, Soysal S, Ozer S. A randomized controlled trial of levonorgestrel releasing IUD and thermal balloon ablation in the treatment of menorrhagia. Zentralbl Gynakol. Apr. 2002;124(4):213-9. X-2. [pmid: 12080483].
2264 Soysal ME, Soysal S, Gurses E, et al. Laparoscopic presacral neurolysis for endometriosis-related pelvic pain. Hum Reprod. Mar. 2003;18(3):588-92. X-2, X-3, X-4. [pmid: 12615830].
2265 Speirs CJ, Dollery CT, Inman WH, et al. Postmarketing surveillance of enalapril II: Investigation of the potential role of enalapril in deaths with renal failure. BMJ. Oct. 1. 1988;297(6652):830-2. X-2, X-4. [pmid: 2846102].
2266 Spektor S, Agus S, Merkin V, et al. Low-dose aspirin prophylaxis and risk of intracranial hemorrhage in patients older than 60 years of age with mild or moderate head injury: a prospective study. J Neurosurg. Oct. 2003;99(4):661-5. X-2, X-4. [pmid: 14567600].
2267 Spellacy WN, Birk SA, Buggie J, et al. Prospective carbohydrate metabolism studies in women using a low-estrogen oral contraceptive for one year. J Reprod Med. Jun. 1981;26(6):295-8. X-2, X-3, X-4. [pmid: 7019435].
2268 Spellacy WN, Tsibris AM, Tsibris JC, et al. Carbohydrate metabolism studies after one year of using an oral contraceptive containing gestodene and ethinyl estradiol. Contraception. Feb. 1994;49(2):125-30. X-2, X-4. [pmid: 8143452].
2269 Spiller HA, Weber JA, Winter ML, et al. Multicenter case series of pediatric metformin ingestion. Ann Pharmacother. Dec. 2000;34(12):1385-8. X-2, X-4. [pmid: 11144693].
2270 Spitzer WO, Lewis MA, Heinemann LA, et al. Third generation oral contraceptives and risk of venous thromboembolic disorders: an international case-control study. Transnational Research Group on Oral Contraceptives and the Health of Young Women. BMJ. Jan. 13. 1996;312(7023):83-8. X-4. [pmid: 8555935].
2271 Sporrong T, Rybo G, Mattsson LA, et al. An objective and subjective assessment of uterine blood loss in postmenopausal women on hormone replacement therapy. Br J Obstet Gynaecol. May. 1992;99(5):399-401. X-2, X-3, X-4. [pmid: 1535788].
2272 Srinivasan S, Rao G. Does using nonsteroidal anti-inflammatory drugs (NSAIDs) during pregnancy increase the risk of adverse events?. J Fam Pract. May. 2001;50(5):467. X-1. [pmid: 11350713].
2273 Srinivasjois RM, Nathan EA, Doherty DA, et al. Renal impairment associated with indomethacin treatment for patent ductus arteriosus in extremely preterm neonates--is postnatal age at start of treatment important?. J Matern Fetal Neonatal Med. Dec. 2006;19(12):793-9. X-2, X-3, X-4. [pmid: 17190690].
2274 Srisupandit S. A three-year study of the copper-7 minigravigard intrauterine contraceptive device in nulliparous women. J Med Assoc Thai. Jun. 1988;71(6):294-7. X-4. [pmid: 3171448].
2275 St Germaine CG, Bogaty P, Boyer L, et al. Genetic polymorphisms and the cardiovascular risk of non-steroidal anti-inflammatory drugs. Am J Cardiol. Jun. 15. 2010;105(12):1740-5. X-2. [pmid: 20538124].
2276 St Sauver JL, Lieber MM, Slager SL, et al. Associations between variants in the cyclooxygenase 2 enzyme gene (PTGS2) and development of benign prostate enlargement. BJU Int. Nov. 2011;108(10):1610-5. X-2, X-3, X-4. [pmid: 21481131].
2277 Staab D, Kaufmann R, Brautigam M, et al. Treatment of infants with atopic eczema with pimecrolimus cream 1% improves parents' quality of life: a multicenter, randomized trial. Pediatr Allergy Immunol. Sep. 2005;16(6):527-33. X-2, X-3, X-4. [pmid: 16176401].
2278 Stack WA, Atherton JC, Hawkey GM, et al. Interactions between Helicobacter pylori and other risk factors for peptic ulcer bleeding. Aliment Pharmacol Ther. Mar. 2002;16(3):497-506. X-2, X-4. [pmid: 11876703].
2279 Stalman A, Tsai JA, Segerdahl M, et al. Ketorolac but not morphine exerts inflammatory and metabolic effects in synovial membrane after knee arthroscopy: a double-blind randomized prospective study using the microdialysis technique. Reg Anesth Pain Med. Nov-Dec. 2009;34(6):557-64. X-2, X-4. [pmid: 19916211].
2280 Stanback J, Qureshi ZP, Sekkade-Kigondu C. Advance provision of oral contraceptives to family planning clients in Kenya. East Afr Med J. May. 2002;79(5):257-8. X-2, X-3, X-4. [pmid: 12638810].
2281 Steen KS, Lems WF, Aertsen J, et al. Incidence of clinically manifest ulcers and their complications in patients with rheumatoid arthritis. Ann Rheum Dis. May. 2001;60(5):443-7. X-2, X-4. [pmid: 11302864].
2282 Steen KS, Nurmohamed MT, Visman I, et al. Decreasing incidence of symptomatic gastrointestinal ulcers and ulcer complications in patients with rheumatoid arthritis. Ann Rheum Dis. Feb. 2008;67(2):256-9. X-4. [pmid: 17604285].
2283 Stein CM, Griffin MR, Taylor JA, et al. Educational program for nursing home physicians and staff to reduce use of non-steroidal anti-inflammatory drugs among nursing home residents: a randomized controlled trial. Med Care. May. 2001;39(5):436-45. X-2, X-3, X-4. [pmid: 11317092].
2284 Stephanie R, Labied S, Blacher S, et al. Endometrial vessel maturation in women exposed to levonorgestrel-releasing intrauterine system for a short or prolonged period of time. Hum Reprod. Dec. 2007;22(12):3084-91. X-2. [pmid: 17921480].
2285 Stevens-Simon C, Kelly L, Wallis J. The timing of norplant insertion and postpartum depression in teenagers. J Adolesc Health. Jun. 2000;26(6):408-13. X-2, X-4. [pmid: 10822182].
2286 Stewart I, Thomas A. Mefenamic acid compared with diclofenac sodium in elderly patients with osteoarthritis. Br J Clin Pract. Aug. 1988;42(8):316-20. X-7. [pmid: 3061435].
2287 Stiasny-Kolster K, Benes H, Peglau I, et al. Effective cabergoline treatment in idiopathic restless legs syndrome. Neurology. Dec. 28. 2004;63(12):2272-9. X-2. [pmid: 15623686].
2288 Stika CS, Gross GA, Leguizamon G, et al. A prospective randomized safety trial of celecoxib for treatment of preterm labor. Am J Obstet Gynecol. Sep. 2002;187(3):653-60. X-2, X-4. [pmid: 12237643].
2289 Stolk P, Souverein PC, Leufkens HG, et al. The association between exposure to COX-2 inhibitors and schizophrenia deterioration. A nested case-control study. Pharmacopsychiatry. May. 2007;40(3):111-5. X-4. [pmid: 17541886].
2290 Stolte M, Karimi D, Vieth M, et al. Strictures, diaphragms, erosions or ulcerations of ischemic type in the colon should always prompt consideration of nonsteroidal anti-inflammatory drug-induced lesions. World J Gastroenterol. Oct. 7. 2005;11(37):5828-33. X-2, X-3, X-4. [pmid: 16270393].
2291 Strate LL, Liu YL, Huang ES, et al. Use of aspirin or nonsteroidal anti-inflammatory drugs increases risk for diverticulitis and diverticular bleeding. Gastroenterology. May. 2011;140(5):1427-33. X-4. [pmid: 21320500].
2292 Stray N, Weberg R. A prospective study of same day bi-directional endoscopy in the evaluation of patients with occult gastrointestinal bleeding. Scand J Gastroenterol. Jul. 2006;41(7):844-50. X-2, X-3, X-4. [pmid: 16785199].
2293 Stroehmann I. A rheumatologist's viewpoint. Eur J Rheumatol Inflamm. 1991;11(3):7-11. X-1. [pmid: 1365482].
2294 Strom BL, Berlin JA, Kinman JL, et al. Parenteral ketorolac and risk of gastrointestinal and operative site bleeding. A postmarketing surveillance study. JAMA. Feb. 7. 1996;275(5):376-82. X-4. [pmid: 8569017].
2295 Strom BL, Carson JL, Schinnar R, et al. The effect of indication on the risk of hypersensitivity reactions associated with tolmetin sodium vs other nonsteroidal antiinflammatory drugs. J Rheumatol. Apr. 1988;15(4):695-9. X-11. [pmid: 3397980].
2296 Strom BL, Carson JL, Schinnar R, et al. Nonsteroidal anti-inflammatory drugs and neutropenia. Arch Intern Med. Sep. 27. 1993;153(18):2119-24. X-4. [pmid: 8379803].
2297 Strom BL, Schinnar R, Bilker WB, et al. Gastrointestinal tract bleeding associated with naproxen sodium vs ibuprofen. Arch Intern Med. Dec. 8-22. 1997;157(22):2626-31. X-4. [pmid: 9531232].
2298 Sturdee DW, Ulrich LG, Barlow DH, et al. The endometrial response to sequential and continuous combined oestrogen-progestogen replacement therapy. BJOG. Nov. 2000;107(11):1392-400. X-7. [pmid: 11117768].
2299 Sturgeon SR, Brinton LA, Berman ML, et al. Intrauterine device use and endometrial cancer risk. Int J Epidemiol. Jun. 1997;26(3):496-500. X-2, X-4. [pmid: 9222773].
2300 Sturkenboom M, Nicolosi A, Cantarutti L, et al. Incidence of mucocutaneous reactions in children treated with niflumic acid, other nonsteroidal antiinflammatory drugs, or nonopioid analgesics. Pediatrics. Jul. 2005;116(1):e26-33. X-4. [pmid: 15930187].
2301 Sturkenboom MC, Burke TA, Dieleman JP, et al. Underutilization of preventive strategies in patients receiving NSAIDs. Rheumatology (Oxford). Nov. Suppl 3. 2003;42:iii23-31. X-2, X-3, X-4. [pmid: 14585915].
2302 Sturkenboom MC, Burke TA, Tangelder MJ, et al. Adherence to proton pump inhibitors or H2-receptor antagonists during the use of non-steroidal anti-inflammatory drugs. Aliment Pharmacol Ther. Dec. 2003;18(11-12):1137-47. X-2, X-3, X-4. [pmid: 14653834].
2303 Sturkenboom MC, Romano F, Simon G, et al. The iatrogenic costs of NSAID therapy: a population study. Arthritis Rheum. Apr. 15. 2002;47(2):132-40. X-4. [pmid: 11954006].
2304 Su BH, Lin HC, Chiu HY, et al. Comparison of ibuprofen and indometacin for early-targeted treatment of patent ductus arteriosus in extremely premature infants: a randomised controlled trial. Arch Dis Child Fetal Neonatal Ed. Mar. 2008;93(2):F94-9. X-2, X-3, X-4. [pmid: 17768157].
2305 Suarez RD, Grobman WA, Parilla BV. Indomethacin tocolysis and intraventricular hemorrhage. Obstet Gynecol. Jun. 2001;97(6):921-5. X-2, X-4. [pmid: 11384697].
2306 Sucato DJ, Lovejoy JF, Agrawal S, et al. Postoperative ketorolac does not predispose to pseudoarthrosis following posterior spinal fusion and instrumentation for adolescent idiopathic scoliosis. Spine (Phila Pa 1976). May. 1. 2008;33(10):1119-24. X-2, X-4. [pmid: 18449047].
2307 Sucato GS, Land SR, Murray PJ, et al. Adolescents' experiences using the contraceptive patch versus pills. J Pediatr Adolesc Gynecol. Aug. 2011;24(4):197-203. X-2, X-3. [pmid: 21454110].
2308 Sudano I, Flammer AJ, Periat D, et al. Acetaminophen increases blood pressure in patients with coronary artery disease. Circulation. Nov. 2. 2010;122(18):1789-96. X-2, X-3, X-4. [pmid: 20956208].
2309 Sugiyama T, Nishikawa K, Komatsu Y, et al. Attributable risk of H. pylori in peptic ulcer disease: does declining prevalence of infection in general population explain increasing frequency of non-H. pylori ulcers?. Dig Dis Sci. Feb. 2001;46(2):307-10. X-2, X-3, X-4. [pmid: 11281179].
2310 Suh DC, Hunsche E, Shin HC, et al. Co-prescribing of proton pump inhibitors among chronic users of NSAIDs in the UK. Rheumatology (Oxford). Apr. 2008;47(4):458-63. X-2, X-3, X-4. [pmid: 18263598].
2311 Suissa S. Statistical methods in pharmacoepidemiology. Principles in managing error. Drug Saf. Sep-Oct. 1991;6(5):381-9. X-1. [pmid: 1930744].
2312 Suissa S, Ernst P, Hudson M, et al. Newer disease-modifying antirheumatic drugs and the risk of serious hepatic adverse events in patients with rheumatoid arthritis. Am J Med. Jul. 15. 2004;117(2):87-92. X-4. [pmid: 15234643].
2313 Suissa S, Spitzer WO, Rainville B, et al. Recurrent use of newer oral contraceptives and the risk of venous thromboembolism. Hum Reprod. Apr. 2000;15(4):817-21. X-4. [pmid: 10739826].
2314 Sukel MP, van der Linden MW, Chen C, et al. Large-scale stopping and switching treatment with COX-2 inhibitors after the rofecoxib withdrawal. Pharmacoepidemiol Drug Saf. Jan. 2008;17(1):9-19. X-4. [pmid: 17963198].
2315 Suleiman UL, Harrison M, Britton A, et al. H2-receptor antagonists may increase the risk of cardio-oesophageal adenocarcinoma: a case-control study. Eur J Cancer Prev. Jun. 2000;9(3):185-91. X-2, X-4. [pmid: 10954258].
2316 Suman VJ, Van Winter JT, Evans MP, et al. Levonorgestrel contraceptive implants in female patients 14 to 21 years old. Mayo Clin Proc. Jan. 1998;73(1):10-6. X-2, X-3, X-4. [pmid: 9443673].
2317 Suri V, Aggarwal N, Kaur R, et al. Safety of intrauterine contraceptive device (copper T 200 B) in women with cardiac disease. Contraception. Oct. 2008;78(4):315-8. X-2, X-4. [pmid: 18847580].
2318 Suwanmalee O, Taneepanichskul S. A clinical study of transdermal contraceptive patch in Thai women. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S1-4. X-2, X-4. [pmid: 17726805].
2319 Svanes C, Soreide JA, Skarstein A, et al. Smoking and ulcer perforation. Gut. Aug. 1997;41(2):177-80. X-2, X-4. [pmid: 9301495].
2320 Sweet BV, Townsend KA, Tsai CY. Risk assessment of NSAID-induced gastrointestinal toxicity in ambulatory care patients. Am J Health Syst Pharm. Sep. 15. 2004;61(18):1917-21. X-2, X-4. [pmid: 15487881].
2321 Sweileh WM. Potential adverse effects of a low-dose aspirin-diuretic combination on kidney function. Int J Clin Pharmacol Ther. Nov. 2007;45(11):601-5. X-2, X-4. [pmid: 18077925].
2322 Swigris JJ, Olson AL, Fischer A, et al. Mycophenolate mofetil is safe, well tolerated, and preserves lung function in patients with connective tissue disease-related interstitial lung disease. Chest. Jul. 2006;130(1):30-6. X-2, X-4. [pmid: 16840379].
2323 Swislocki AL, Khuu Q, Liao E, et al. Safety and efficacy of metformin in a restricted formulary. Am J Manag Care. Jan. 1999;5(1):62-8. X-2, X-4. [pmid: 10345968].
2324 Sy FS, Osteria TS, Opiniano V, et al. Effect of oral contraceptive on liver function tests of women with schistosomiasis in the Philippines. Contraception. Sep. 1986;34(3):283-94. X-2, X-4. [pmid: 3098499].
2325 Szczeklik A, Nizankowska E, Duplaga M. Natural history of aspirin-induced asthma. AIANE Investigators. European Network on Aspirin-Induced Asthma. Eur Respir J. Sep. 2000;16(3):432-6. X-2, X-4. [pmid: 11028656].
2326 Szer IS, Goldenstein-Schainberg C, Kurtin PS. Paucity of renal complications associated with nonsteroidal antiinflammatory drugs in children with chronic arthritis. J Pediatr. Nov. 1991;119(5):815-7. X-2. [pmid: 1941392].
2327 Tadesse E. Return of fertility after an IUD removal for planned pregnancy: a six year prospective study. East Afr Med J. Mar. 1996;73(3):169-71. X-2, X-4. [pmid: 8698014].
2328 Tadesse E, van Brandenburg WJ, Exalto N. Intrauterine devices: results of a separate clinical and ultrasound follow-up study. Eur J Obstet Gynecol Reprod Biol. May. 1985;19(5):289-95. X-2, X-4. [pmid: 3894102].
2329 Taha AS, Angerson WJ, Prasad R, et al. Upper gastrointestinal bleeding and the changing use of COX-2 non-steroidal anti-inflammatory drugs and low-dose aspirin. Aliment Pharmacol Ther. Oct. 15. 2007;26(8):1171-8. X-4. [pmid: 17894659].
2330 Taheri M, Rahimi M, Naderi M, et al. Effects of a subdermal levonorgestrel contraceptive implant (Norplant) on serum cholesterol, triglycerides, ALT and AST in Iranian women. Contraception. Jan. 2006;73(1):56-8. X-2, X-3, X-4. [pmid: 16371296].
2331 Takami T, Yoda H, Kawakami T, et al. Usefulness of indomethacin for patent ductus arteriosus in full-term infants. Pediatr Cardiol. Jan-Feb. 2007;28(1):46-50. X-2, X-3, X-4. [pmid: 17203336].
2332 Tal S, Shavit Y, Stern F, et al. Association between vitamin B12 levels and mortality in hospitalized older adults. J Am Geriatr Soc. Mar. 2010;58(3):523-6. X-2, X-4. [pmid: 20158555].
2333 Talamini G, Tommasi M, Amadei V, et al. Risk factors of peptic ulcer in 4943 inpatients. J Clin Gastroenterol. Apr. 2008;42(4):373-80. X-4. [pmid: 18277902].
2334 Talamini G, Zamboni G, Cavallini G. Antral mucosal Helicobacter pylori infection density as a risk factor of duodenal ulcer. Digestion. 1997;58(3):211-7. X-2, X-4. [pmid: 9243115].
2335 Tam WH, Yuen PM, Shan Ng DP, et al. Health status function after treatment with thermal balloon endometrial ablation and levonorgestrel intrauterine system for idiopathic menorrhagia: a randomized study. Gynecol Obstet Invest. 2006;62(2):84-8. X-2, X-4. [pmid: 16612101].
2336 Tamai H, Katoh K, Yamaguchi T, et al. The impact of tranilast on restenosis after coronary angioplasty: the Second Tranilast Restenosis Following Angioplasty Trial (TREAT-2). Am Heart J. Mar. 2002;143(3):506-13. X-2, X-3, X-4. [pmid: 11868058].
2337 Tamblyn RM, McLeod PJ, Abrahamowicz M, et al. Do too many cooks spoil the broth? Multiple physician involvement in medical management of elderly patients and potentially inappropriate drug combinations. CMAJ. Apr. 15. 1996;154(8):1177-84. X-3, X-4. [pmid: 8612253].
2338 Tammemagi CM, Freedman MT, Church TR, et al. Factors associated with human small aggressive non small cell lung cancer. Cancer Epidemiol Biomarkers Prev. Oct. 2007;16(10):2082-9. X-2, X-3, X-4. [pmid: 17932357].
2339 Tan T, Cabrita IZ, Hensman D, et al. Assessment of cardiac valve dysfunction in patients receiving cabergoline treatment for hyperprolactinaemia. Clin Endocrinol (Oxf). Sep. 2010;73(3):369-74. X-2. [pmid: 20550538].
2340 Taneepanichskul S, Intaraprasert S, Phuapradit W, et al. Use of Norplant implants in asymptomatic HIV-1 infected women. Contraception. Apr. 1997;55(4):205-7. X-2, X-4. [pmid: 9179451].
2341 Taneepanichskul S, Intaraprasert S, Theppisai U, et al. Bone mineral density in long-term depot medroxyprogesterone acetate acceptors. Contraception. Jul. 1997;56(1):1-3. X-2, X-4. [pmid: 9306024].
2342 Taneepanichskul S, Intharasakda P. Efficacy and side effects of Norplant use in Thai women above the age of 35 years. Contraception. Nov. 2001;64(5):305-7. X-2, X-4. [pmid: 11777491].
2343 Taneepanichskul S, Tanprasertkul C. Use of Norplant implants in the immediate postpartum period among asymptomatic HIV-1-positive mothers. Contraception. Jul. 2001;64(1):39-41. X-2, X-4. [pmid: 11535212].
2344 Tang OS, Tang G, Yip PS, et al. Further evaluation on long-term depot-medroxyprogesterone acetate use and bone mineral density: a longitudinal cohort study. Contraception. Oct. 2000;62(4):161-4. X-2, X-4. [pmid: 11137068].
2345 Tang T, Glanville J, Hayden CJ, et al. Combined lifestyle modification and metformin in obese patients with polycystic ovary syndrome. A randomized, placebo-controlled, double-blind multicentre study. Human Reproduction. 2006;21(1):80-9. X-2, X-3, X-4. [pmid: 16199429].
2346 Tangkiatkumjai M, Vadcharavivad S, Mahachai V. Prediction of UGIB event in NSAID users: a model development. J Med Assoc Thai. May. 2005;88(5):672-7. X-2, X-3, X-4. [pmid: 16149687].
2347 Tanis BC, van den Bosch MA, Kemmeren JM, et al. Oral contraceptives and the risk of myocardial infarction. N Engl J Med. Dec. 20. 2001;345(25):1787-93. X-2. [pmid: 11752354].
2348 Tao MH, Xu WH, Zheng W, et al. Oral contraceptive and IUD use and endometrial cancer: a population-based case-control study in Shanghai, China. Int J Cancer. Nov. 1. 2006;119(9):2142-7. X-4. [pmid: 16823853].
2349 Targownik LE, Al-Mamfud A. The prevalence of risk factors for gastrointestinal complications and use of gastroprotection among persons hospitalized for cardiovascular disease. Aliment Pharmacol Ther. Mar. 15. 2006;23(6):743-9. X-2, X-4. [pmid: 16556176].
2350 Targownik LE, Metge CJ, Leung S, et al. The relative efficacies of gastroprotective strategies in chronic users of nonsteroidal anti-inflammatory drugs. Gastroenterology. Apr. 2008;134(4):937-44. X-4. [pmid: 18294634].
2351 Tarone RE, Blot WJ, McLaughlin JK. Nonselective nonaspirin nonsteroidal anti-inflammatory drugs and gastrointestinal bleeding: relative and absolute risk estimates from recent epidemiologic studies. Am J Ther. Jan-Feb. 2004;11(1):17-25. X-1. [pmid: 14704592].
2352 Tartagni M, Schonauer LM, De Salvia MA, et al. Comparison of Diane 35 and Diane 35 plus finasteride in the treatment of hirsutism. Fertil Steril. Apr. 2000;73(4):718-23. X-2, X-3, X-4. [pmid: 10731531].
2353 Tata LJ, Fortun PJ, Hubbard RB, et al. Does concurrent prescription of selective serotonin reuptake inhibitors and non-steroidal anti-inflammatory drugs substantially increase the risk of upper gastrointestinal bleeding?. Aliment Pharmacol Ther. Aug. 1. 2005;22(3):175-81. X-4. [pmid: 16091054].
2354 Tavani A, Scotti L, Bosetti C, et al. Aspirin and risk of renal cell cancer in Italy. Eur J Cancer Prev. Jul. 2010;19(4):272-4. X-2, X-4. [pmid: 20351553].
2355 Tay HL, Evans JM, McMahon AD, et al. Aspirin, nonsteroidal anti-inflammatory drugs, and epistaxis. A regional record linkage case control study. Ann Otol Rhinol Laryngol. Aug. 1998;107(8):671-4. X-4. [pmid: 9716869].
2356 Techapornroong M, Akrawinthawong K, Cheungpasitporn W, et al. Anaphylaxis: a ten years inpatient retrospective study. Asian Pac J Allergy Immunol. Dec. 2010;28(4):262-9. X-4. [pmid: 21337910].
2357 Teeling M, O'Connor H, Feely J, et al. What therapies have replaced rofecoxib in Ireland?. Br J Clin Pharmacol. Oct. 2007;64(4):536-41. X-4. [pmid: 17555468].
2358 Teichmann A, Apter D, Emerich J, et al. Continuous, daily levonorgestrel/ethinyl estradiol vs. 21-day, cyclic levonorgestrel/ethinyl estradiol: efficacy, safety and bleeding in a randomized, open-label trial. Contraception. Dec. 2009;80(6):504-11. X-2, X-4. [pmid: 19913143].
2359 Terra SG, Somayaji V, Schwartz S, et al. A Dose-Ranging Study of the DPP-IV Inhibitor PF-734200 Added to Metformin in Subjects With Type 2 Diabetes*. Exp Clin Endocrinol Diabetes. Jul. 2011;119(7):401-7. X-2, X-3, X-4. [pmid: 21472661].
2360 Tewari S, Kaushish R, Sharma S, et al. Role of low dose aspirin in prevention of pregnancy induced hypertension. J Indian Med Assoc. Feb. 1997;95(2):43-4. 7. X-2, X-4. [pmid: 9357241].
2361 Tharavanij T, Betancourt A, Messinger S, et al. Improved long-term health-related quality of life after islet transplantation. Transplantation. Nov. 15. 2008;86(9):1161-7. X-2, X-3, X-4. [pmid: 19005394].
2362 Thiefin G, Schwalm MS. Underutilization of gastroprotective drugs in patients receiving non-steroidal anti-inflammatory drugs. Dig Liver Dis. Mar. 2011;43(3):209-14. X-4. [pmid: 21051300].
2363 Thillainayagam AV, Tabaqchali S, Warrington SJ, et al. Interrelationships between Helicobacter pylori infection, nonsteroidal antiinflammatory drugs and gastroduodenal disease. A prospective study in healthy volunteers. Dig Dis Sci. May. 1994;39(5):1085-9. X-2, X-4. [pmid: 8174421].
2364 Thomas DB, Ray RM. Depot-medroxyprogesterone acetate (DMPA) and risk of invasive adenocarcinomas and adenosquamous carcinomas of the uterine cervix. WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Contraception. Nov. 1995;52(5):307-12. X-8. [pmid: 8585888].
2365 Thomas DB, Ye Z, Ray RM. Cervical carcinoma in situ and use of depot-medroxyprogesterone acetate (DMPA). WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Contraception. Jan. 1995;51(1):25-31. X-8. [pmid: 7750280].
2366 Thome-Kromer B, Bonk I, Klatt M, et al. Toward the identification of liver toxicity markers: a proteome study in human cell culture and rats. Proteomics. Oct. 2003;3(10):1835-62. X-2, X-3, X-4. [pmid: 14625847].
2367 Thompson MR. Indomethacin and perforated duodenal ulcer. Br Med J. Feb. 16. 1980;280(6212):448. X-2. [pmid: 7370529].
2368 Thomsen RW, Riis A, Christensen S, et al. Outcome of peptic ulcer bleeding among users of traditional non-steroidal anti-inflammatory drugs and selective cyclo-oxygenase-2 inhibitors. Aliment Pharmacol Ther. Nov. 15. 2006;24(10):1431-8. X-4. [pmid: 17032286].
2369 Thomsen SF, Kyvik KO, Skadhauge LR, et al. Regular use of non-steroidal anti-inflammatory drugs increases the risk of adult-onset asthma: a population-based follow-up study. Clin Respir J. Apr. 2009;3(2):82-4. X-4. [pmid: 20298382].
2370 Thomson WM, Spencer AJ, Slade GD, et al. Is medication a risk factor for dental caries among older people?. Community Dent Oral Epidemiol. Jun. 2002;30(3):224-32. X-2, X-4. [pmid: 12000346].
2371 Thong-Ngam D, Chayanupatkul M, Klaikeaw N, et al. Effect of rebamipide on gastric ulcer healing caused by Helicobacter pylori and/or NSAIDs or non NSAIDs-non H. pylori. J Med Assoc Thai. Sep. 2009;92(9):1207-12. X-2, X-3, X-4. [pmid: 19772181].
2372 Thorogood M, Hannaford PC. The influence of oral contraceptives on the risk of multiple sclerosis. Br J Obstet Gynaecol. Dec. 1998;105(12):1296-9. X-4. [pmid: 9883921].
2373 Thrift AG, McNeil JJ, Forbes A, et al. Risk of primary intracerebral haemorrhage associated with aspirin and non-steroidal anti-inflammatory drugs: case-control study. BMJ. Mar. 20. 1999;318(7186):759-64. X-2, X-4. [pmid: 10082697].
2374 Tibble JA, Sigthorsson G, Foster R, et al. Use of surrogate markers of inflammation and Rome criteria to distinguish organic from nonorganic intestinal disease. Gastroenterology. Aug. 2002;123(2):450-60. X-2, X-3, X-4. [pmid: 12145798].
2375 Tilakaratne A, Soory M, Ranasinghe AW, et al. Effects of hormonal contraceptives on the periodontium, in a population of rural Sri-Lankan women. J Clin Periodontol. Oct. 2000;27(10):753-7. X-2. [pmid: 11034123].
2376 Tildesley G, Ehsanullah RS, Wood JR. Ranitidine in the treatment of gastric and duodenal ulcers associated with non-steroidal anti-inflammatory drugs. Br J Rheumatol. Jun. 1993;32(6):474-8. X-2, X-3, X-4. [pmid: 8508283].
2377 Tilleul P, Weickmans H, Sean PT, et al. Cost analysis applied to postoperative analgesia regimens: a comparison between parecoxib and propacetamol. Pharm World Sci. Aug. 2007;29(4):374-9. X-2, X-3, X-4. [pmid: 17310303].
2378 Tilyard MW, Dovey SM. A comparison of tiaprofenic acid, mefenamic acid and placebo in the treatment of dysmenorrhoea in general practice. Aust N Z J Obstet Gynaecol. May. 1992;32(2):165-8. X-2, X-4. [pmid: 1520205].
2379 Ting RZ, Szeto CC, Chan MH, et al. Risk factors of vitamin B(12) deficiency in patients receiving metformin. Arch Intern Med. Oct. 9. 2006;166(18):1975-9. X-2. [pmid: 17030830].
2380 Titchen T, Cranswick N, Beggs S. Adverse drug reactions to nonsteroidal anti-inflammatory drugs, COX-2 inhibitors and paracetamol in a paediatric hospital. Br J Clin Pharmacol. Jun. 2005;59(6):718-23. X-3. [pmid: 15948937].
2381 Todd J, Lawrenson R, Farmer RD, et al. Venous thromboembolic disease and combined oral contraceptives: A re-analysis of the MediPlus database. Hum Reprod. Jun. 1999;14(6):1500-5. X-4. [pmid: 10357966].
2382 Toh S, Garcia Rodriguez LA, Hernan MA. Confounding adjustment via a semi-automated high-dimensional propensity score algorithm: an application to electronic medical records. Pharmacoepidemiol Drug Saf. Aug. 2011;20(8):849-57. X-4. [pmid: 21717528].
2383 Toker MI, Erdem H, Erdogan H, et al. The effects of topical ketorolac and indomethacin on measles conjunctivitis: randomized controlled trial. Am J Ophthalmol. May. 2006;141(5):902-5. X-2, X-3, X-4. [pmid: 16527227].
2384 Toljamo KT, Niemela SE, Karttunen TJ, et al. The role of Herpes simplex and Helicobacter pylori infection in the etiology of persistent or recurrent gastric erosions: a follow-up study. Dig Dis Sci. Apr. 2002;47(4):818-22. X-2, X-3, X-4. [pmid: 11991616].
2385 Tornhamre S, Ehnhage A, Kolbeck KG, et al. Uncoupled regulation of leukotriene C4 synthase in platelets from aspirin-intolerant asthmatics and healthy volunteers after aspirin treatment. Clin Exp Allergy. Nov. 2002;32(11):1566-73. X-4. [pmid: 12569976].
2386 Torres DM, Jones FJ, Shaw JC, et al. Rosiglitazone versus rosiglitazone and metformin versus rosiglitazone and losartan in the treatment of nonalcoholic steatohepatitis in humans: a 12-month randomized, prospective, open- label trial. Hepatology. Nov. 2011;54(5):1631-9. X-2, X-3, X-4. [pmid: 21748770].
2387 Torres-Galvan MJ, Ortega N, Sanchez-Garcia F, et al. LTC4-synthase A-444C polymorphism: lack of association with NSAID-induced isolated periorbital angioedema in a Spanish population. Ann Allergy Asthma Immunol. Dec. 2001;87(6):506-10. X-2, X-3, X-4. [pmid: 11770699].
2388 Tramer MR, Moore RA, Reynolds DJ, et al. Quantitative estimation of rare adverse events which follow a biological progression: a new model applied to chronic NSAID use. Pain. Mar. 2000;85(1-2):169-82. X-1, X-2, X-4. [pmid: 10692616].
2389 Trattler W, McDonald M. Double-masked comparison of ketorolac tromethamine 0.4% versus nepafenac sodium 0.1% for postoperative healing rates and pain control in eyes undergoing surface ablation. Cornea. Jul. 2007;26(6):665-9. X-2, X-3, X-4. [pmid: 17592313].
2390 Traversa G, Bianchi C, Da Cas R, et al. Cohort study of hepatotoxicity associated with nimesulide and other non-steroidal anti-inflammatory drugs. BMJ. Jul. 5. 2003;327(7405):18-22. X-4. [pmid: 12842950].
2391 Traversa G, Walker AM, Ippolito FM, et al. Gastroduodenal toxicity of different nonsteroidal antiinflammatory drugs. Epidemiology. Jan. 1995;6(1):49-54. X-4. [pmid: 7888445].
2392 Tremaine WJ, Schroeder KW, Harrison JM, et al. A randomized, double-blind, placebo-controlled trial of the oral mesalamine (5-ASA) preparation, Asacol, in the treatment of symptomatic Crohn's colitis and ileocolitis. J Clin Gastroenterol. Dec. 1994;19(4):278-82. X-2, X-3, X-4. [pmid: 7876505].
2393 Tremollieres FA, Pouilles JM, Ribot C. Withdrawal of hormone replacement therapy is associated with significant vertebral bone loss in postmenopausal women. Osteoporos Int. 2001;12(5):385-90. X-2, X-3, X-4. [pmid: 11444087].
2394 Trenkwalder C, Hogl B, Benes H, et al. Augmentation in restless legs syndrome is associated with low ferritin. Sleep Med. Jul. 2008;9(5):572-4. X-2. [pmid: 17921065].
2395 Trewin VF, Lawrence CJ, Rae SA, et al. Development and use of a gastropathy index for ranking the safety of non-steroidal anti-inflammatory drugs in the elderly. J Clin Pharm Ther. Jun. 1994;19(3):209-14. X-4, X-7. [pmid: 7962226].
2396 Trinavarat A, Atchaneeyasakul LO, Surachatkumtonekul T, et al. Comparison of topical prednisolone acetate, ketorolac tromethamine and fluorometholone acetate in reducing inflammation after phacoemulsification. J Med Assoc Thai. Feb. 2003;86(2):143-50. X-2, X-4. [pmid: 12678152].
2397 Trinh XB, Tjalma WA, Makar AP, et al. Use of the levonorgestrel-releasing intrauterine system in breast cancer patients. Fertil Steril. Jul. 2008;90(1):17-22. X-2. [pmid: 17706209].
2398 Trombetta D, Imbesi S, Vita G, et al. Possible link between history of hypersensitivity to a specific non-steroidal anti-inflammatory drug (NSAID) and positive results following challenge test to alternative NSAIDS. Arzneimittelforschung. 2009;59(8):410-4. X-2, X-4. [pmid: 19813464].
2399 Trossarelli GF, Gennarelli G, Benedetto C, et al. Climacteric symptoms and control of the cycle in women aged 35 years or older taking an oral contraceptive with 0.150 mg desogestrel and 0.020 mg ethinylestradiol. Contraception. Jan. 1995;51(1):13-8. X-2. [pmid: 7750278].
2400 Trus T, Winthrop AL, Pipe S, et al. Optimal management of patent ductus arteriosus in the neonate weighing less than 800 g. J Pediatr Surg. Sep. 1993;28(9):1137-9. X-2, X-4. [pmid: 8308678].
2401 Tsalikis T, Stamatopoulos P, Kalachanis J, et al. Experience with the MLCu250 IUD. Adv Contracept. Dec. 1986;2(4):393-8. X-2, X-3, X-4. [pmid: 3565139].
2402 Tsesmeli NE, Kotsaftis PS, Savopoulos CG, et al. Incidence and etiology of acute non-malignant upper gastrointestinal bleeding in northern Greece. J Gastroenterol Hepatol. Jul. 2007;22(7):1009-13. X-2. [pmid: 17608846].
2403 Tsokos M, Schmoldt A. Contribution of nonsteroidal anti-inflammatory drugs to deaths associated with peptic ulcer disease: a prospective toxicological analysis of autopsy blood samples. Arch Pathol Lab Med. Dec. 2001;125(12):1572-4. X-2. [pmid: 11735692].
2404 Tsong Y. Comparing reporting rates of adverse events between drugs with adjustment for year of marketing and secular trends in total reporting. J Biopharm Stat. Mar. 1995;5(1):95-114. X-1, X-2, X-3, X-4. [pmid: 7613562].
2405 Tsubota A, Kumada H, Arase Y, et al. Combined ursodeoxycholic acid and glycyrrhizin therapy for chronic hepatitis C virus infection: a randomized controlled trial in 170 patients. Eur J Gastroenterol Hepatol. Oct. 1999;11(10):1077-83. X-2, X-4. [pmid: 10524635].
2406 Tsuchiya T, Ayaki M, Onishi T, et al. Three-year prospective randomized study of incidence of posterior capsule opacification in eyes treated with topical diclofenac and betamethasone. Ophthalmic Res. Mar-Apr. 2003;35(2):67-70. X-2, X-4. [pmid: 12646745].
2407 Tsumura H, Fujita T, Tamura I, et al. Association between adherence to evidence-based guidelines for the prescription of non-steroidal anti-inflammatory drugs and the incidence of gastric mucosal lesions in Japanese patients. J Gastroenterol. Sep. 2010;45(9):944-51. X-2. [pmid: 20499110].
2408 Tsuruoka N, Iwakiri R, Hara M, et al. NSAIDs are a significant risk factor for colonic diverticular hemorrhage in elder patients: evaluation by a case-control study. J Gastroenterol Hepatol. Jun. 2011;26(6):1047-52. X-2, X-3, X-4. [pmid: 21198829].
2409 Tu P, Qiu S, Fang H, et al. Acceptance, efficacy, and side effects of Norplant implants in four counties in north China. Stud Fam Plann. Jun. 1997;28(2):122-31. X-2, X-4. [pmid: 9216032].
2410 Tubert-Bitter P, Begaud B, Moride Y, et al. Comparing the toxicity of two drugs in the framework of spontaneous reporting: a confidence interval approach. J Clin Epidemiol. Jan. 1996;49(1):121-3. X-1, X-2, X-3, X-4. [pmid: 8598505].
2411 Tugwell PS, Wells GA, Shainhouse JZ. Equivalence study of a topical diclofenac solution (pennsaid) compared with oral diclofenac in symptomatic treatment of osteoarthritis of the knee: a randomized controlled trial. J Rheumatol. Oct. 2004;31(10):2002-12. X-2, X-4. [pmid: 15468367].
2412 Tuomikoski P, Haapalahti P, Sarna S, et al. Vasomotor hot flushes and 24-hour ambulatory blood pressure in normotensive women: A placebo-controlled trial on post-menopausal hormone therapy. Ann Med. Jul. 2010;42(5):334-43. X-2. [pmid: 20429800].
2413 Turajane T, Wongbunnak R, Patcharatrakul T, et al. Gastrointestinal and cardiovascular risk of non-selective NSAIDs and COX-2 inhibitors in elderly patients with knee osteoarthritis. J Med Assoc Thai. Dec. Suppl 6. 2009;92:S19-26. X-4. [pmid: 20128070].
2414 Tursi A, Brandimarte G, Daffina R. Long-term treatment with mesalazine and rifaximin versus rifaximin alone for patients with recurrent attacks of acute diverticulitis of colon. Dig Liver Dis. Jul. 2002;34(7):510-5. X-2, X-3, X-4. [pmid: 12236485].
2415 Tursi A, Brandimarte G, Giorgetti GM, et al. Balsalazide and/or high-potency probiotic mixture (VSL#3) in maintaining remission after attack of acute, uncomplicated diverticulitis of the colon. Int J Colorectal Dis. Sep. 2007;22(9):1103-8. X-2, X-3, X-4. [pmid: 17390144].
2416 Tworoger SS, Fairfield KM, Colditz GA, et al. Association of oral contraceptive use, other contraceptive methods, and infertility with ovarian cancer risk. Am J Epidemiol. Oct. 15. 2007;166(8):894-901. X-4. [pmid: 17656616].
2417 Tzeng JI, Mok MS. Combination of intramuscular Ketorolac and low dose epidural morphine for the relief of post-caesarean pain. Ann Acad Med Singapore. Nov. 1994;23(6 Suppl):10-3. X-2, X-4. [pmid: 7710217].
2418 Tzoulaki I, Molokhia M, Curcin V, et al. Risk of cardiovascular disease and all cause mortality among patients with type 2 diabetes prescribed oral antidiabetes drugs: retrospective cohort study using UK general practice research database. BMJ. 2009;339:b4731. X-3. [pmid: 19959591].
2419 Ubeira FM, Anadon AM, Salgado A, et al. Synergism between prior Anisakis simplex infections and intake of NSAIDs, on the risk of upper digestive bleeding: a case-control study. PLoS Negl Trop Dis. Jun. 2011;5(6):e1214. X-2. [pmid: 21738810].
2420 Ucar SK, Paterson WF, Donaldson MD, et al. Ethinyl estradiol treatment for growth limitation in girls with Marfan's syndrome--experience from a single center. Endocr Res. 2009;34(4):109-20. X-2, X-3, X-4. [pmid: 19878071].
2421 Uchikova E, Pehlivanov B. Effect of two low-dose gestodene containing monophasic oral contraceptives on hemostasis in Bulgarian women. Expert Opin Pharmacother. Aug. 2008;9(11):1839-44. X-2, X-4. [pmid: 18627323].
2422 Uchino J, Une Y, Sato Y, et al. Chemohormonal therapy of unresectable hepatocellular carcinoma. Am J Clin Oncol. Jun. 1993;16(3):206-9. X-2, X-4. [pmid: 8393272].
2423 Ullmann U, Oberwittle H, Grossmann M, et al. Repeated oral once daily intake of increasing doses of the novel synthetic genistein product Bonistein in healthy volunteers. Planta Med. Oct. 2005;71(10):891-6. X-2, X-4. [pmid: 16254818].
2424 Ulstein M, Steier AJ, Hofstad T, et al. Microflora of cervical and vaginal secretion in women using copper- and norgestrel-releasing IUCDs. Acta Obstet Gynecol Scand. 1987;66(4):321-2. X-2, X-3, X-4. [pmid: 3122515].
2425 Um SJ, Lee SK, Kim YH, et al. Clinical features of drug-induced hypersensitivity syndrome in 38 patients. J Investig Allergol Clin Immunol. 2010;20(7):556-62. X-2. [pmid: 21313995].
2426 Underwood M, Ashby D, Cross P, et al. Advice to use topical or oral ibuprofen for chronic knee pain in older people: randomised controlled trial and patient preference study. BMJ. Jan. 19. 2008;336(7636):138-42. X-2, X-3, X-4. [pmid: 18056743].
2427 Upadhyay R, Torley HI, McKinlay AW, et al. Iron deficiency anaemia in patients with rheumatic disease receiving non-steroidal anti-inflammatory drugs: the role of upper gastrointestinal lesions. Ann Rheum Dis. Jun. 1990;49(6):359-62. X-2, X-3, X-4. [pmid: 2383058].
2428 Uppalapati SS, Boylan JD, Stoltzfus J. Risk factors involved in patients with bleeding peptic ulcers: a case-control study. Dig Dis Sci. Mar. 2009;54(3):593-8. X-2, X-3, X-4. [pmid: 18648934].
2429 Ursin G, Ross RK, Sullivan-Halley J, et al. Use of oral contraceptives and risk of breast cancer in young women. Breast Cancer Res Treat. Jul. 1998;50(2):175-84. X-4. [pmid: 9822222].
2430 Usichenko TI, Edinger H, Witstruck T, et al. Millimetre wave therapy for pain relief after total knee arthroplasty: a randomised controlled trial. Eur J Pain. Jul. 2008;12(5):617-23. X-2, X-3, X-4. [pmid: 18042413].
2431 Utz JP, Limper AH, Kalra S, et al. Etanercept for the treatment of stage II and III progressive pulmonary sarcoidosis. Chest. Jul. 2003;124(1):177-85. X-2, X-3, X-4. [pmid: 12853521].
2432 Vaisbich MH, Fujimura MD, Koch VH. Bartter syndrome: benefits and side effects of long-term treatment. Pediatr Nephrol. Aug. 2004;19(8):858-63. X-2, X-3, X-4. [pmid: 15206026].
2433 Valkhoff VE, van Soest EM, Sturkenboom MC, et al. Time-trends in gastroprotection with nonsteroidal anti-inflammatory drugs (NSAIDs). Aliment Pharmacol Ther. Jun. 2010;31(11):1218-28. X-3, X-4. [pmid: 20222917].
2434 Vallette S, Serri K, Rivera J, et al. Long-term cabergoline therapy is not associated with valvular heart disease in patients with prolactinomas. Pituitary. 2009;12(3):153-7. X-2. [pmid: 18594989].
2435 Vallette S, Serri K, Serri O. Cabergoline therapy for prolactinomas: is valvular heart disease a real safety concern?. Expert Rev Cardiovasc Ther. Jan. 2010;8(1):49-54. X-1. [pmid: 20014934].
2436 Vally H, Taylor ML, Thompson PJ. The prevalence of aspirin intolerant asthma (AIA) in Australian asthmatic patients. Thorax. Jul. 2002;57(7):569-74. X-4. [pmid: 12096197].
2437 van Amerongen D. Removal rates of subdermal levonorgestrel implants. J Reprod Med. Nov. 1994;39(11):873-6. X-2, X-3, X-4. [pmid: 7853277].
2438 van den Berg AA, Honjol NM, Prabhu NV, et al. Analgesics and ENT surgery. A clinical comparison of the intraoperative, recovery and postoperative effects of buprenorphine, diclofenac, fentanyl, morphine, nalbuphine, pethidine and placebo given intravenously with induction of anaesthesia. Br J Clin Pharmacol. Dec. 1994;38(6):533-43. X-2, X-3, X-4. [pmid: 7888292].
2439 van den Hondel KE, Eijgelsheim M, Ruiter R, et al. Effect of short-term NSAID use on echocardiographic parameters in elderly people: a population-based cohort study. Heart. Apr. 2011;97(7):540-3. X-4. [pmid: 21097821].
2440 Van den Ouweland FA, Gribnau FW, Meyboom RH. Congestive heart failure due to nonsteroidal anti-inflammatory drugs in the elderly. Age Ageing. Jan. 1988;17(1):8-16. X-2. [pmid: 3364313].
2441 van der Heijden BJ, Carlus C, Narcy F, et al. Persistent anuria, neonatal death, and renal microcystic lesions after prenatal exposure to indomethacin. Am J Obstet Gynecol. Sep. 1994;171(3):617-23. X-2, X-4. [pmid: 8092206].
2442 van der Heijden PG, van Puijenbroek EP, van Buuren S, et al. On the assessment of adverse drug reactions from spontaneous reporting systems: the influence of under-reporting on odds ratios. Stat Med. Jul. 30. 2002;21(14):2027-44. X-1. [pmid: 12111885].
2443 van der Hooft CS, Jong GW, Dieleman JP, et al. Inappropriate drug prescribing in older adults: the updated 2002 Beers criteria--a population-based cohort study. Br J Clin Pharmacol. Aug. 2005;60(2):137-44. X-2, X-3, X-4. [pmid: 16042666].
2444 van der Klauw MM, Stricker BH, Herings RM, et al. A population based case-cohort study of drug-induced anaphylaxis. Br J Clin Pharmacol. Apr. 1993;35(4):400-8. X-2, X-4. [pmid: 8097922].
2445 Van der Linden MW, Gaugris S, Kuipers EJ, et al. Gastroprotection among new chronic users of non-steroidal anti-inflammatory drugs: a study of utilization and adherence in The Netherlands. Curr Med Res Opin. Jan. 2009;25(1):195-204. X-4. [pmid: 19210152].
2446 van der Linden MW, Gaugris S, Kuipers EJ, et al. COX-2 inhibitors: complex association with lower risk of hospitalization for gastrointestinal events compared to traditional NSAIDs plus proton pump inhibitors. Pharmacoepidemiol Drug Saf. Oct. 2009;18(10):880-90. X-4. [pmid: 19593747].
2447 van der Loo B, Braun J, Koppensteiner R. On-treatment function testing of platelets and long-term outcome of patients with peripheral arterial disease undergoing transluminal angioplasty. Eur J Vasc Endovasc Surg. Dec. 2011;42(6):809-16. X-2, X-3, X-4. [pmid: 21917489].
2448 van der Mooren MJ, Demacker PN, Thomas CM, et al. A 2-year study on the beneficial effects of 17 beta-oestradiol-dydrogesterone therapy on serum lipoproteins and Lp(a) in postmenopausal women: no additional unfavourable effects of dydrogesterone. Eur J Obstet Gynecol Reprod Biol. Dec. 15. 1993;52(2):117-23. X-2, X-4. [pmid: 8157140].
2449 van der Mooren MJ, Hanselaar AG, Borm GF, et al. Changes in the withdrawal bleeding pattern and endometrial histology during 17 beta-estradiol-dydrogesterone therapy in postmenopausal women: a 2 year prospective study. Maturitas. Dec. 1994;20(2-3):175-80. X-2, X-4. [pmid: 7715470].
2450 van der Steen WJ, Ho VK. Drugs versus diets: disillusions with Dutch health care. Acta Biotheor. 2001;49(2):125-40. X-1. [pmid: 11450808].
2451 van der Velde G, Hogg-Johnson S, Bayoumi AM, et al. Identifying the best treatment among common nonsurgical neck pain treatments: a decision analysis. Spine (Phila Pa 1976). Feb. 15. 2008;33(4 Suppl):S184-91. X-3, X-4. [pmid: 18204391].
2452 van der Velden T, Ping C. The introduction of Norplant in Cambodia through the private sector. Asia Pac J Public Health. 2002;14(2):69-74. X-2, X-3, X-4. [pmid: 12862410].
2453 Van Deun A, Maug AK, Salim MA, et al. Short, highly effective, and inexpensive standardized treatment of multidrug-resistant tuberculosis. Am J Respir Crit Care Med. Sep. 1. 2010;182(5):684-92. X-2, X-3, X-4. [pmid: 20442432].
2454 Van Dierendonck B, Ladipo OA, Ekwempu CC, et al. A multicenter clinical trial in Nigeria with Multiload-Cu250 (MLCu250) and Multiload-Cu375 (MLCu375) intrauterine devices. Adv Contracept. Dec. 1992;8(4):327-30. X-3, X-4. [pmid: 1290334].
2455 van Dijk KN, ter Huurne K, de Vries CS, et al. Prescribing of gastroprotective drugs among elderly NSAID users in The Netherlands. Pharm World Sci. Jun. 2002;24(3):100-3. X-3, X-4. [pmid: 12136741].
2456 Van Dis ML, Parks ET. Prevalence of oral lichen planus in patients with diabetes mellitus. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Jun. 1995;79(6):696-700. X-2. [pmid: 7621025].
2457 van Dongen H, van Aken J, Lard LR, et al. Efficacy of methotrexate treatment in patients with probable rheumatoid arthritis: a double-blind, randomized, placebo-controlled trial. Arthritis Rheum. May. 2007;56(5):1424-32. X-2, X-3, X-4. [pmid: 17469099].
2458 van Eijkeren MA, Christiaens GC, Geuze HJ, et al. Effects of mefenamic acid on menstrual hemostasis in essential menorrhagia. Am J Obstet Gynecol. May. 1992;166(5):1419-28. X-2, X-3, X-4. [pmid: 1595797].
2459 van Gelder MM, Roeleveld N, Nordeng H. Exposure to non-steroidal anti-inflammatory drugs during pregnancy and the risk of selected birth defects: a prospective cohort study. PLoS One. 2011;6(7):e22174. X-4. [pmid: 21789231].
2460 van Haselen RA, Fisher PA. A randomized controlled trial comparing topical piroxicam gel with a homeopathic gel in osteoarthritis of the knee. Rheumatology (Oxford). Jul. 2000;39(7):714-9. X-2, X-4. [pmid: 10908688].
2461 van Jaarsveld CH, Jahangier ZN, Jacobs JW, et al. Toxicity of anti-rheumatic drugs in a randomized clinical trial of early rheumatoid arthritis. Rheumatology (Oxford). Dec. 2000;39(12):1374-82. X-2. [pmid: 11136881].
2462 van Kets H, Vrijens M, Van Trappen Y, et al. The frameless GyneFix intrauterine implant: a major improvement in efficacy, expulsion and tolerance. Adv Contracept. Jun. 1995;11(2):131-42. X-1, X-2, X-3, X-4. [pmid: 7491854].
2463 van Kets HE, Thiery M, van der Pas H, et al. Long-term experience with Multiload intrauterine devices. Adv Contracept. Sep. 1989;5(3):179-88. X-1, X-4. [pmid: 2633607].
2464 Van Kets HE, Van der Pas H, Delbarge W, et al. A randomized comparative study of the TCu380A and Cu-Safe 300 IUDs. Adv Contracept. Jun. 1995;11(2):123-9. X-2, X-4. [pmid: 7491853].
2465 Van Lancker P, Vandekerckhove B, Cooman F. The analgesic effect of preoperative administration of propacetamol, tenoxicam or a mixture of both in arthroscopic, outpatient knee surgery. Acta Anaesthesiol Belg. 1999;50(2):65-9. X-2, X-3, X-4. [pmid: 10418644].
2466 van Lumig PP, Driessen RJ, Roelofs-Thijssen MA, et al. Relevance of laboratory investigations in monitoring patients with psoriasis on etanercept or adalimumab. Br J Dermatol. Aug. 2011;165(2):375-82. X-2, X-3, X-4. [pmid: 21428975].
2467 Van Marter LJ, Leviton A, Allred EN, et al. Persistent pulmonary hypertension of the newborn and smoking and aspirin and nonsteroidal antiinflammatory drug consumption during pregnancy. Pediatrics. May. 1996;97(5):658-63. X-2. [pmid: 8628603].
2468 van Oijen MG, Dieleman JP, Laheij RJ, et al. Peptic ulcerations are related to systemic rather than local effects of low-dose aspirin. Clin Gastroenterol Hepatol. Mar. 2008;6(3):309-13. X-4. [pmid: 18242146].
2469 van Oijen MG, Koetsier MI, Laheij RJ, et al. Genetic polymorphisms in UDP-glucuronosyltransferase 1A6 are not associated with NSAIDs-related peptic ulcer haemorrhage. Drug Metab Lett. Aug. 2009;3(3):199-204. X-2, X-3, X-4. [pmid: 19799547].
2470 van Oijen MG, Laheij RJ, Koetsier M, et al. Effect of a specific cyclooxygenase-gene polymorphism (A-842G/C50T) on the occurrence of peptic ulcer hemorrhage. Dig Dis Sci. Dec. 2006;51(12):2348-52. X-2, X-3, X-4. [pmid: 17078001].
2471 van Overmeire B, Brus F, van Acker KJ, et al. Aspirin versus indomethacin treatment of patent ductus arteriosus in preterm infants with respiratory distress syndrome. Pediatr Res. Dec. 1995;38(6):886-91. X-2, X-3, X-4. [pmid: 8618789].
2472 Van Overmeire B, Slootmaekers V, De Loor J, et al. The addition of indomethacin to betamimetics for tocolysis: any benefit for the neonate?. Eur J Obstet Gynecol Reprod Biol. Mar. 1998;77(1):41-5. X-2, X-4. [pmid: 9550199].
2473 Van Overmeire B, Smets K, Lecoutere D, et al. A comparison of ibuprofen and indomethacin for closure of patent ductus arteriosus. N Engl J Med. Sep. 7. 2000;343(10):674-81. X-2, X-4. [pmid: 10974130].
2474 Van Overmeire B, Van de Broek H, Van Laer P, et al. Early versus late indomethacin treatment for patent ductus arteriosus in premature infants with respiratory distress syndrome. J Pediatr. Feb. 2001;138(2):205-11. X-2, X-4. [pmid: 11174617].
2475 van Puijenbroek EP, Egberts AC, Heerdink ER, et al. Detecting drug-drug interactions using a database for spontaneous adverse drug reactions: an example with diuretics and non-steroidal anti-inflammatory drugs. Eur J Clin Pharmacol. Dec. 2000;56(9-10):733-8. X-3, X-4. [pmid: 11214785].
2476 van Puijenbroek EP, Egberts AC, Meyboom RH, et al. Different risks for NSAID-induced anaphylaxis. Ann Pharmacother. Jan. 2002;36(1):24-9. X-4. [pmid: 11816253].
2477 van Rooijen M, Silveira A, Hamsten A, et al. Sex hormone--binding globulin--a surrogate marker for the prothrombotic effects of combined oral contraceptives. Am J Obstet Gynecol. Feb. 2004;190(2):332-7. X-2. [pmid: 14981370].
2478 Van Roon EN, Jansen TL, Mourad L, et al. Leflunomide in active rheumatoid arthritis: a prospective study in daily practice. Br J Clin Pharmacol. Jun. 2004;57(6):790-7. X-2, X-4. [pmid: 15151525].
2479 van Soest EM, Sturkenboom MC, Dieleman JP, et al. Adherence to gastroprotection and the risk of NSAID-related upper gastrointestinal ulcers and haemorrhage. Aliment Pharmacol Ther. Jul. 15. 2007;26(2):265-75. X-4. [pmid: 17593072].
2480 van Soest EM, Valkhoff VE, Mazzaglia G, et al. Suboptimal gastroprotective coverage of NSAID use and the risk of upper gastrointestinal bleeding and ulcers: an observational study using three European databases. Gut. Dec. 2011;60(12):1650-9. X-4. [pmid: 21636644].
2481 van Staa TP, Abenhaim L, Leufkens H. A study of the effects of exposure misclassification due to the time-window design in pharmacoepidemiologic studies. J Clin Epidemiol. Feb. 1994;47(2):183-9. X-2, X-3, X-4. [pmid: 8113827].
2482 van Staa TP, Leufkens HG, Cooper C. Use of nonsteroidal anti-inflammatory drugs and risk of fractures. Bone. Oct. 2000;27(4):563-8. X-4. [pmid: 11033453].
2483 van Staa TP, Rietbrock S, Setakis E, et al. Does the varied use of NSAIDs explain the differences in the risk of myocardial infarction?. J Intern Med. Nov. 2008;264(5):481-92. X-4. [pmid: 18624902].
2484 van Staa TP, Smeeth L, Persson I, et al. What is the harm-benefit ratio of Cox-2 inhibitors?. Int J Epidemiol. Apr. 2008;37(2):405-13. X-4. [pmid: 18263647].
2485 Van Staa TP, Travis S, Leufkens HG, et al. 5-aminosalicylic acids and the risk of renal disease: a large British epidemiologic study. Gastroenterology. Jun. 2004;126(7):1733-9. X-4. [pmid: 15188168].
2486 van Vlijmen EF, Brouwer JL, Veeger NJ, et al. Oral contraceptives and the absolute risk of venous thromboembolism in women with single or multiple thrombophilic defects: results from a retrospective family cohort study. Arch Intern Med. Feb. 12. 2007;167(3):282-9. X-2. [pmid: 17296885].
2487 van Vlijmen EF, Veeger NJ, Middeldorp S, et al. Thrombotic risk during oral contraceptive use and pregnancy in women with factor V Leiden or prothrombin mutation: a rational approach to contraception. Blood. Aug. 25. 2011;118(8):2055-61. quiz 375. X-2. [pmid: 21659542].
2488 Van Wyck DB, Mangione A, Morrison J, et al. Large-dose intravenous ferric carboxymaltose injection for iron deficiency anemia in heavy uterine bleeding: a randomized, controlled trial. Transfusion. Dec. 2009;49(12):2719-28. X-2, X-4. [pmid: 19682342].
2489 Vandermeulen EP, Van Aken H, Scholtes JL, et al. Intravenous administration of tenoxicam 40 mg for post-operative analgesia: a double-blind, placebo-controlled multicentre study. Eur J Anaesthesiol. May. 1997;14(3):250-7. X-2, X-3, X-4. [pmid: 9202910].
2490 Vandraas KF, Spigset O, Mahic M, et al. Non-steroidal anti-inflammatory drugs: use and co-treatment with potentially interacting medications in the elderly. Eur J Clin Pharmacol. Aug. 2010;66(8):823-9. X-4. [pmid: 20405110].
2491 Vanek T, Jares M, Fajt R, et al. Fibrinolytic inhibitors in off-pump coronary surgery: a prospective, randomized, double-blind TAP study (tranexamic acid, aprotinin, placebo). Eur J Cardiothorac Surg. Oct. 2005;28(4):563-8. X-2, X-4. [pmid: 16125959].
2492 Vanky E, Salvesen KA, Heimstad R, et al. Metformin reduces pregnancy complications without affecting androgen levels in pregnant polycystic ovary syndrome women: results of a randomized study. Hum Reprod. Aug. 2004;19(8):1734-40. X-2, X-4. [pmid: 15178665].
2493 Vargas E, Terleira A, Hernando F, et al. Effect of adverse drug reactions on length of stay in surgical intensive care units. Crit Care Med. Mar. 2003;31(3):694-8. X-2, X-4. [pmid: 12626971].
2494 Vargyas JM, Campeau JD, Mishell DR Jr. Treatment of menorrhagia with meclofenamate sodium. Am J Obstet Gynecol. Oct. 1987;157(4 Pt 1):944-50. X-2, X-3, X-4. [pmid: 3314521].
2495 Varila E, Wahlstrom T, Rauramo I. A 5-year follow-up study on the use of a levonorgestrel intrauterine system in women receiving hormone replacement therapy. Fertil Steril. Nov. 2001;76(5):969-73. X-2, X-3, X-4. [pmid: 11704119].
2496 Vasisht KP, Chen SC, Peng Y, et al. Limitations of metformin use in patients with kidney disease: are they warranted?. Diabetes Obes Metab. Dec. 2010;12(12):1079-83. X-2, X-3. [pmid: 20977579].
2497 Veehof LJ, Stewart RE, Meyboom-de Jong B, et al. Adverse drug reactions and polypharmacy in the elderly in general practice. Eur J Clin Pharmacol. Sep. 1999;55(7):533-6. X-7. [pmid: 10501824].
2498 Vekemans M, Delvigne A, Paesmans M. Continuation rates with a levonorgestrel-releasing contraceptive implant (Norplant). A prospective study in Belgium. Contraception. Nov. 1997;56(5):291-9. X-2, X-3, X-4. [pmid: 9437557].
2499 Veldhuis HM, Vos AG, Lagro-Janssen AL. Complications of the intrauterine device in nulliparous and parous women. Eur J Gen Pract. Sep. 2004;10(3):82-7. X-2, X-4. [pmid: 15534571].
2500 Velentgas P, West W, Cannuscio CC, et al. Cardiovascular risk of selective cyclooxygenase-2 inhibitors and other non-aspirin non-steroidal anti-inflammatory medications. Pharmacoepidemiol Drug Saf. Sep. 2006;15(9):641-52. X-4. [pmid: 16392153].
2501 Velosa JA, Torres VE. Benefits and risks of nonsteroidal antiinflammatory drugs in steroid-resistant nephrotic syndrome. Am J Kidney Dis. Nov. 1986;8(5):345-50. X-2. [pmid: 3788972].
2502 Velten FW, Bayerl C, Baenkler HW, et al. Functional eicosanoid test and typing (FET) in acetylsalicylic acid intolerant patients with urticaria. J Physiol Pharmacol. Dec. Suppl 12. 2006;57:35-46. X-2, X-3, X-4. [pmid: 17244953].
2503 Venerito M, Treiber G, Wex T, et al. Effects of low-dose aspirin on gastric erosions, cyclooxygenase expression and mucosal prostaglandin-E2 do not depend on Helicobacter pylori infection. Aliment Pharmacol Ther. Apr. 15. 2006;23(8):1225-33. X-2, X-4. [pmid: 16611284].
2504 Venn A, Bruinsma F, Werther G, et al. Oestrogen treatment to reduce the adult height of tall girls: long-term effects on fertility. Lancet. Oct. 23-29. 2004;364(9444):1513-8. X-2. [pmid: 15500896].
2505 Ventura MT, Cenci L, Giuliano G, et al. Retrospective study of adverse reactions to non steroid anti-inflammatory drugs (NSAIDs): predictive value of controlled challenge with alternative drugs. Immunopharmacol Immunotoxicol. Aug. 1999;21(3):455-68. X-4. [pmid: 10466074].
2506 Venturoli S, Marescalchi O, Colombo FM, et al. A prospective randomized trial comparing low dose flutamide, finasteride, ketoconazole, and cyproterone acetate-estrogen regimens in the treatment of hirsutism. J Clin Endocrinol Metab. Apr. 1999;84(4):1304-10. X-2, X-3, X-4. [pmid: 10199771].
2507 Vercellini P, Aimi G, Panazza S, et al. A levonorgestrel-releasing intrauterine system for the treatment of dysmenorrhea associated with endometriosis: a pilot study. Fertil Steril. Sep. 1999;72(3):505-8. X-2, X-4. [pmid: 10519624].
2508 Vercellini P, Frontino G, De Giorgi O, et al. Continuous use of an oral contraceptive for endometriosis-associated recurrent dysmenorrhea that does not respond to a cyclic pill regimen. Fertil Steril. Sep. 2003;80(3):560-3. X-2, X-3, X-4. [pmid: 12969698].
2509 Verhamme KM, Dieleman JP, Van Wijk MA, et al. Nonsteroidal anti-inflammatory drugs and increased risk of acute urinary retention. Arch Intern Med. Jul. 11. 2005;165(13):1547-51. X-6. [pmid: 16009872].
2510 Verhelst J, Abs R, Maiter D, et al. Cabergoline in the treatment of hyperprolactinemia: a study in 455 patients. J Clin Endocrinol Metab. Jul. 1999;84(7):2518-22. X-2. [pmid: 10404830].
2511 Vermillion ST, Newman RB. Recent indomethacin tocolysis is not associated with neonatal complications in preterm infants. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1083-6. X-2, X-4. [pmid: 10561622].
2512 Verrico MM, Weber RJ, McKaveney TP, et al. Adverse Drug Events Involving COX-2 Inhibitors. Ann Pharmacother. Sep. 2003;37(9):1203-13. X-2, X-4. [pmid: 12921500].
2513 Vestergaard P, Rejnmark L, Mosekilde L. Osteoarthritis and risk of fractures. Calcif Tissue Int. Apr. 2009;84(4):249-56. X-3, X-4. [pmid: 19234808].
2514 Vidal X, Ibanez L, Vendrell L, et al. Risk of upper gastrointestinal bleeding and the degree of serotonin reuptake inhibition by antidepressants: a case-control study. Drug Saf. 2008;31(2):159-68. X-4. [pmid: 18217791].
2515 Viegas OA, Singh K, Koh S, et al. The effects of Norplant on clinical chemistry in Singaporean acceptors after 1 year of use: I. Haemostatic changes. Contraception. Sep. 1988;38(3):313-23. X-2, X-4. [pmid: 3139360].
2516 Vilar L, Canadas V, Arruda MJ, et al. Comparison of metformin, gliclazide MR and rosiglitazone in monotherapy and in combination for type 2 diabetes. Arq Bras Endocrinol Metabol. Mar. 2010;54(3):311-8. X-2, X-4. [pmid: 20520962].
2517 Villanacci V, Casella G, Bassotti G. The spectrum of drug-related colitides: important entities, though frequently overlooked. Dig Liver Dis. Jul. 2011;43(7):523-8. X-8. [pmid: 21324756].
2518 Viola AS, Castro S, Bahamondes MV, et al. A cross-sectional study of the forearm bone mineral density in long-term current users of the injectable contraceptive depot medroxyprogesterone acetate. Contraception. Nov. 2011;84(5):e31-7. X-2. [pmid: 22018135].
2519 Viola AS, Castro S, Marchi NM, et al. Long-term assessment of forearm bone mineral density in postmenopausal former users of depot medroxyprogesterone acetate. Contraception. Aug. 2011;84(2):122-7. X-2. [pmid: 21757052].
2520 Visser LE, van Schaik RH, van Vliet M, et al. Allelic variants of cytochrome P450 2C9 modify the interaction between nonsteroidal anti-inflammatory drugs and coumarin anticoagulants. Clin Pharmacol Ther. Jun. 2005;77(6):479-85. X-2. [pmid: 15961979].
2521 Viswanathan P, Chaudhuri A, Bhatia R, et al. Exenatide therapy in obese patients with type 2 diabetes mellitus treated with insulin. Endocr Pract. Sep. 2007;13(5):444-50. X-2, X-3, X-4. [pmid: 17872344].
2522 Vitale MG, Choe JC, Hwang MW, et al. Use of ketorolac tromethamine in children undergoing scoliosis surgery. an analysis of complications. Spine J. Jan-Feb. 2003;3(1):55-62. X-2. [pmid: 14589246].
2523 Vlajkovic G, Sindjelic R, Stefanovic I. Ketorolac as a pre-emptive analgesic in retinal detachment surgery: a prospective, randomized clinical trial. Int J Clin Pharmacol Ther. May. 2007;45(5):259-63. X-2, X-4. [pmid: 17542347].
2524 Voaklander DC, Kelly KD, Rowe BH, et al. Pain, medication, and injury in older farmers. Am J Ind Med. May. 2006;49(5):374-82. X-2, X-3, X-4. [pmid: 16526061].
2525 Vogel RI, Gross JI. The effects of nonsteroidal anti-inflammatory analgesics on pain after periodontal surgery. J Am Dent Assoc. Nov. 1984;109(5):731-4. X-2, X-4. [pmid: 6333443].
2526 Vogel U, Christensen J, Wallin H, et al. Polymorphisms in genes involved in the inflammatory response and interaction with NSAID use or smoking in relation to lung cancer risk in a prospective study. Mutat Res. Mar. 1. 2008;639(1-2):89-100. X-2, X-3, X-4. [pmid: 18164040].
2527 Vogel U, Segel S, Dethlefsen C, et al. PPARgamma Pro12Ala polymorphism and risk of acute coronary syndrome in a prospective study of Danes. BMC Med Genet. 2009;10:52. X-4. [pmid: 19500413].
2528 Vogel U, Segel S, Dethlefsen C, et al. Associations between COX-2 polymorphisms, blood cholesterol and risk of acute coronary syndrome. Atherosclerosis. Mar. 2010;209(1):155-62. X-3, X-4. [pmid: 19748095].
2529 Voke J, Keidan J, Pavord S, et al. The management of antenatal venous thromboembolism in the UK and Ireland: a prospective multicentre observational survey. Br J Haematol. Nov. 2007;139(4):545-58. X-2, X-4. [pmid: 17916101].
2530 Volpe A, Silferi M, Genazzani AD, et al. Contraception in older woman. Contraception. Mar. 1993;47(3):229-39. X-2. [pmid: 8462314].
2531 von Holst T, Lang E, Winkler U, et al. Bleeding patterns in peri and postmenopausal women taking a continuous combined regimen of estradiol with norethisterone acetate or a conventional sequential regimen of conjugated equine estrogens with medrogestone. Maturitas. Dec. 10. 2002;43(4):265-75. X-2, X-4. [pmid: 12468135].
2532 Von Korff M, Galer BS, Stang P. Chronic use of symptomatic headache medications. Pain. Aug. 1995;62(2):179-86. X-2, X-3, X-4. [pmid: 8545143].
2533 Vonbach P, Reich R, Moll F, et al. Risk factors for gastrointestinal bleeding: a hospital-based case-control study. Swiss Med Wkly. Dec. 22. 2007;137(49-50):705-10. X-2, X-4. [pmid: 18197486].
2534 Vonkeman HE, Braakman-Jansen LM, Klok RM, et al. Incremental cost effectiveness of proton pump inhibitors for the prevention of non-steroidal anti-inflammatory drug ulcers: a pharmacoeconomic analysis linked to a case-control study. Arthritis Res Ther. 2008;10(6):R144. X-4. [pmid: 19077318].
2535 Vonkeman HE, Fernandes RW, van der Palen J, et al. Proton-pump inhibitors are associated with a reduced risk for bleeding and perforated gastroduodenal ulcers attributable to non-steroidal anti-inflammatory drugs: a nested case-control study. Arthritis Res Ther. 2007;9(3):R52. X-3, X-4. [pmid: 17521422].
2536 Vonkeman HE, van de Laar MA, van der Palen J, et al. Allele variants of the cytochrome P450 2C9 genotype in white subjects from The Netherlands with serious gastroduodenal ulcers attributable to the use of NSAIDs. Clin Ther. Oct. 2006;28(10):1670-6. X-2, X-3, X-4. [pmid: 17157122].
2537 Voskuyl AE, Van de Laar MA, Moens HJ, et al. Extra-articular manifestations of rheumatoid arthritis: risk factors for serious gastrointestinal events. Ann Rheum Dis. Nov. 1993;52(11):771-5. X-4. [pmid: 8250607].
2538 Voutilainen M, Sokka T, Juhola M, et al. Nonsteroidal anti-inflammatory drug-associated upper gastrointestinal lesions in rheumatoid arthritis patients. Relationships to gastric histology, Helicobacter pylori infection, and other risk factors for peptic ulcer. Scand J Gastroenterol. Aug. 1998;33(8):811-6. X-2, X-3. [pmid: 9754727].
2539 Vree ML, Schmidt J. A large observational clinical evaluation of a desogestrel-containing combiphasic oral contraceptive in Germany. Eur J Contracept Reprod Health Care. Jun. 2001;6(2):108-14. X-4. [pmid: 11518448].
2540 Vreeburg EM, de Bruijne HW, Snel P, et al. Previous use of non-steroidal anti-inflammatory drugs and anticoagulants: the influence on clinical outcome of bleeding gastroduodenal ulcers. Eur J Gastroenterol Hepatol. Jan. 1997;9(1):41-4. X-2. [pmid: 9031897].
2541 Vuorma S, Teperi J, Aalto AM, et al. A randomized trial among women with heavy menstruation -- impact of a decision aid on treatment outcomes and costs. Health Expect. Dec. 2004;7(4):327-37. X-2, X-3. [pmid: 15544685].
2542 Wadelius M, Stjernberg E, Wiholm BE, et al. Polymorphisms of NAT2 in relation to sulphasalazine-induced agranulocytosis. Pharmacogenetics. Feb. 2000;10(1):35-41. X-2, X-3, X-4. [pmid: 10739170].
2543 Wahl PM, Rodgers K, Schneeweiss S, et al. Validation of claims-based diagnostic and procedure codes for cardiovascular and gastrointestinal serious adverse events in a commercially-insured population. Pharmacoepidemiol Drug Saf. Jun. 2010;19(6):596-603. X-2, X-3, X-4. [pmid: 20140892].
2544 Wahn U, Bos JD, Goodfield M, et al. Efficacy and safety of pimecrolimus cream in the long-term management of atopic dermatitis in children. Pediatrics. Jul. 2002;110(1 Pt 1):e2. X-2, X-3, X-4. [pmid: 12093983].
2545 Waikakul S, Waikakul W. A post marketing survey on the side-effects of loxoprofen. J Med Assoc Thai. Jul. 1999;82(7):721-6. X-2, X-4. [pmid: 10511775].
2546 Walker AM, Szneke P, Bianchi LA, et al. 5-Aminosalicylates, sulfasalazine, steroid use, and complications in patients with ulcerative colitis. Am J Gastroenterol. May. 1997;92(5):816-20. X-4. [pmid: 9149192].
2547 Walker PC, Alrawi A, Mitchell JF, et al. Medication use as a risk factor for falls among hospitalized elderly patients. Am J Health Syst Pharm. Dec. 1. 2005;62(23):2495-9. X-2. [pmid: 16303905].
2548 Walker SL, Kennedy F, Niamh N, et al. Nimesulide associated fulminant hepatic failure. Pharmacoepidemiol Drug Saf. Nov. 2008;17(11):1108-12. X-2, X-4. [pmid: 18821716].
2549 Wallander MA, Johansson S, Ruigomez A, et al. Dyspepsia in general practice: incidence, risk factors, comorbidity and mortality. Fam Pract. Oct. 2007;24(5):403-11. X-3, X-4. [pmid: 17728288].
2550 Wallenstein EJ, Fife D. Temporal patterns of NSAID spontaneous adverse event reports: the Weber effect revisited. Drug Saf. 2001;24(3):233-7. X-3, X-4. [pmid: 11347725].
2551 Waller PC, Ramsay LE. Arthritis and drug therapy in the hypertension clinic. Biomed Pharmacother. 1988;42(3):207-11. X-2, X-3, X-4. [pmid: 3052606].
2552 Wallerstedt SM, Gleerup H, Sundstrom A, et al. Risk of clinically relevant bleeding in warfarin-treated patients--influence of SSRI treatment. Pharmacoepidemiol Drug Saf. May. 2009;18(5):412-6. X-2, X-4. [pmid: 19301238].
2553 Walling M. A multicenter efficacy and safety study of an oral contraceptive containing 150 micrograms desogestrel and 30 micrograms ethinyl estradiol. Contraception. Oct. 1992;46(4):313-26. X-2, X-4. [pmid: 1486770].
2554 Walsh JS, Eastell R, Peel NF. Effects of Depot medroxyprogesterone acetate on bone density and bone metabolism before and after peak bone mass: a case-control study. J Clin Endocrinol Metab. Apr. 2008;93(4):1317-23. X-2. [pmid: 18230659].
2555 Walsh JS, Eastell R, Peel NF. Depot medroxyprogesterone acetate use after peak bone mass is associated with increased bone turnover but no decrease in bone mineral density. Fertil Steril. Feb. 2010;93(3):697-701. X-2. [pmid: 19013564].
2556 Walsh T, Grimes D, Frezieres R, et al. Randomised controlled trial of prophylactic antibiotics before insertion of intrauterine devices. IUD Study Group. Lancet. Apr. 4. 1998;351(9108):1005-8. X-3, X-4. [pmid: 9546505].
2557 Walter RB, Milano F, Brasky TM, et al. Long-term use of acetaminophen, aspirin, and other nonsteroidal anti-inflammatory drugs and risk of hematologic malignancies: results from the prospective Vitamins and Lifestyle (VITAL) study. J Clin Oncol. Jun. 10. 2011;29(17):2424-31. X-4. [pmid: 21555699].
2558 Wan LS, Stiber A, Lam LY. The levonorgestrel two-rod implant for long-acting contraception: 10 years of clinical experience. Obstet Gynecol. Jul. 2003;102(1):24-6. X-2, X-4. [pmid: 12850601].
2559 Wang J, Donnan PT, MacDonald TM. An approximate Bayesian risk-analysis for the gastro-intestinal safety of ibuprofen. Pharmacoepidemiol Drug Saf. Dec. 2002;11(8):695-701. X-4, X-8. [pmid: 12512246].
2560 Wang J, Mullins CD, Mamdani M, et al. New diagnosis of hypertension among celecoxib and nonselective NSAID users: a population-based cohort study. Ann Pharmacother. Jun. 2007;41(6):937-43. X-4. [pmid: 17488830].
2561 Wang ML, Miao F, Tang YH, et al. Special diaphragm-like strictures of small bowel unrelated to non-steroidal anti-inflammatory drugs. World J Gastroenterol. Aug. 21. 2011;17(31):3596-604. X-2. [pmid: 21987606].
2562 Wang SL, Wu SC, Xin XM, et al. Three years' experience with levonorgestrel-releasing intrauterine device and Norplant-2 implants: a randomized comparative study. Adv Contracept. Jun. 1992;8(2):105-14. X-2, X-3, X-4. [pmid: 1519493].
2563 Wang YP, Shi B, Chen YX, et al. Drug-induced liver disease: an 8-year study of patients from one gastroenterological department. J Dig Dis. Aug. 2009;10(3):195-200. X-2, X-4. [pmid: 19659787].
2564 Ward MM, Kuzis S. Medication toxicity among patients with ankylosing spondylitis. Arthritis Rheum. Jun. 15. 2002;47(3):234-41. X-2, X-4. [pmid: 12115151].
2565 Warner JJ, Weideman RA, Kelly KC, et al. The risk of acute myocardial infarction with etodolac is not increased compared to naproxen: a historical cohort analysis of a generic COX-2 selective inhibitor. J Cardiovasc Pharmacol Ther. Dec. 2008;13(4):252-60. X-2, X-4. [pmid: 18787084].
2566 Watson DJ, Bolognese JA, Yu C, et al. Use of gastroprotective agents and discontinuations due to dyspepsia with the selective cyclooxygenase-2 inhibitor etoricoxib compared with non-selective NSAIDs. Curr Med Res Opin. Dec. 2004;20(12):1899-908. X-4. [pmid: 15701208].
2567 Watson MG, Shenoi PM. Drug-induced epistaxis?. J R Soc Med. Mar. 1990;83(3):162-4. X-2. [pmid: 2325058].
2568 Weale AE, Warwick DJ, Durant N, et al. Is there a clinical interaction between low molecular weight heparin and non-steroidal analgesics after total hip replacement?. Ann R Coll Surg Engl. Jan. 1995;77(1):35-7. X-2, X-4. [pmid: 7717643].
2569 Weaver GA, Harper RL, Storey JA, et al. Nonsteroidal antiinflammatory drugs are associated with gastric outlet obstruction. J Clin Gastroenterol. Apr. 1995;20(3):196-8. X-2, X-4. [pmid: 7797825].
2570 Weber-Diehl F, Unger R, Lachnit U. Triphasic combination of ethinyl estradiol and gestodene. Long-term clinical trial. Contraception. Jul. 1992;46(1):19-27. X-4. [pmid: 1424620].
2571 Webster J, Piscitelli G, Polli A, et al. Dose-dependent suppression of serum prolactin by cabergoline in hyperprolactinaemia: a placebo controlled, double blind, multicentre study. European Multicentre Cabergoline Dose-finding Study Group. Clin Endocrinol (Oxf). Dec. 1992;37(6):534-41. X-2. [pmid: 1286524].
2572 Webster J, Piscitelli G, Polli A, et al. The efficacy and tolerability of long-term cabergoline therapy in hyperprolactinaemic disorders: an open, uncontrolled, multicentre study. European Multicentre Cabergoline Study Group. Clin Endocrinol (Oxf). Sep. 1993;39(3):323-9. X-2. [pmid: 7900937].
2573 Weckx LL, Ruiz JE, Duperly J, et al. Efficacy of celecoxib in treating symptoms of viral pharyngitis: a double-blind, randomized study of celecoxib versus diclofenac. J Int Med Res. Mar-Apr. 2002;30(2):185-94. X-2, X-4. [pmid: 12025527].
2574 Weil J, Colin-Jones D, Langman M, et al. Prophylactic aspirin and risk of peptic ulcer bleeding. BMJ. Apr. 1. 1995;310(6983):827-30. X-2, X-3, X-4. [pmid: 7711618].
2575 Weil J, Langman MJ, Wainwright P, et al. Peptic ulcer bleeding: accessory risk factors and interactions with non-steroidal anti-inflammatory drugs. Gut. Jan. 2000;46(1):27-31. X-2, X-4. [pmid: 10601050].
2576 Weinbroum AA. Superiority of postoperative epidural over intravenous patient-controlled analgesia in orthopedic oncologic patients. Surgery. Nov. 2005;138(5):869-76. X-2, X-3, X-4. [pmid: 16291387].
2577 Weir MA, Gomes T, Mamdani M, et al. Impaired renal function modifies the risk of severe hypoglycaemia among users of insulin but not glyburide: a population-based nested case-control study. Nephrol Dial Transplant. Jun. 2011;26(6):1888-94. X-4, X-7. [pmid: 20974644].
2578 Weisberg F, Bouchard C, Moreau M, et al. Preference for and satisfaction of Canadian women with the transdermal contraceptive patch versus previous contraceptive method: an open-label, multicentre study. J Obstet Gynaecol Can. Apr. 2005;27(4):350-9. X-2, X-3, X-4. [pmid: 15937609].
2579 Wells M, Sturdee DW, Barlow DH, et al. Effect on endometrium of long term treatment with continuous combined oestrogen-progestogen replacement therapy: follow up study. BMJ. Aug. 3. 2002;325(7358):239. X-2, X-4. [pmid: 12153918].
2580 Wemme H, Pohlenz J, Schonberger W. Effect of oestrogen/gestagen replacement therapy on liver enzymes in patients with Ullrich-Turner syndrome. Eur J Pediatr. Oct. 1995;154(10):807-10. X-2. [pmid: 8529677].
2581 Wen SW, Yang T, Krewski D, et al. Patterns of pregnancy exposure to prescription FDA C D and X drugs in a Canadian population. J Perinatol. May. 2008;28(5):324-9. X-4. [pmid: 18288118].
2582 Wen YK. Impact of acute kidney injury on metformin-associated lactic acidosis. Int Urol Nephrol. Dec. 2009;41(4):967-72. X-2. [pmid: 19280360].
2583 Werler MM, Bosco JL, Shapira SK. Maternal vasoactive exposures, amniotic bands, and terminal transverse limb defects. Birth Defects Res A Clin Mol Teratol. Jan. 2009;85(1):52-7. X-2, X-3, X-4. [pmid: 19067400].
2584 Wernli KJ, Hampton JM, Trentham-Dietz A, et al. Use of antidepressants and NSAIDs in relation to mortality in long-term breast cancer survivors. Pharmacoepidemiol Drug Saf. Feb. 2011;20(2):131-7. X-4. [pmid: 21254283].
2585 Wessinger S, Kaplan M, Choi L, et al. Increased use of selective serotonin reuptake inhibitors in patients admitted with gastrointestinal haemorrhage: a multicentre retrospective analysis. Aliment Pharmacol Ther. Apr. 1. 2006;23(7):937-44. X-2, X-3, X-4. [pmid: 16573796].
2586 Westerlund T, Allebeck P, Marklund B, et al. Evaluation of a model for counseling patients with dyspepsia in Swedish community pharmacies. Am J Health Syst Pharm. Jul. 1. 2003;60(13):1336-41. X-2, X-3, X-4. [pmid: 12901035].
2587 Westhoff C, Truman C, Kalmuss D, et al. Depressive symptoms and Depo-Provera. Contraception. Apr. 1998;57(4):237-40. X-2, X-4. [pmid: 9649914].
2588 Westhoff C, Truman C, Kalmuss D, et al. Depressive symptoms and Norplant contraceptive implants. Contraception. Apr. 1998;57(4):241-5. X-2, X-4. [pmid: 9649915].
2589 Wetmore CM, Ichikawa L, LaCroix AZ, et al. Association between caffeine intake and bone mass among young women: potential effect modification by depot medroxyprogesterone acetate use. Osteoporos Int. Apr. 2008;19(4):519-27. X-2, X-4. [pmid: 18004611].
2590 Wharam PC, Speedy DB, Noakes TD, et al. NSAID use increases the risk of developing hyponatremia during an Ironman triathlon. Med Sci Sports Exerc. Apr. 2006;38(4):618-22. X-2. [pmid: 16679974].
2591 Whelan CT, Kaboli P, Zhang Q, et al. Upper gastrointestinal hemorrhage: have new therapeutics made a difference?. J Hosp Med. Sep. 2009;4(7):E6-10. X-2. [pmid: 19753582].
2592 White E, Malone KE, Weiss NS, et al. Breast cancer among young U.S. women in relation to oral contraceptive use. J Natl Cancer Inst. Apr. 6. 1994;86(7):505-14. X-4. [pmid: 8133534].
2593 Wiegratz I, Stahlberg S, Manthey T, et al. Effect of extended-cycle regimen with an oral contraceptive containing 30 mcg ethinylestradiol and 2 mg dienogest on bleeding patterns, safety, acceptance and contraceptive efficacy. Contraception. Aug. 2011;84(2):133-43. X-2. [pmid: 21757054].
2594 Wiegratz I, Stahlberg S, Manthey T, et al. Effects of combined oral contraceptive ethinylestradiol (30 microg) and dienogest (2 mg) on carbohydrate metabolism during 1 year of conventional or extended-cycle use. Horm Metab Res. May. 2010;42(5):358-63. X-2, X-4. [pmid: 20213585].
2595 Wierod FS, Frandsen NJ, Jacobsen JD, et al. Risk of haemorrhage from transurethral prostatectomy in acetylsalicylic acid and NSAID-treated patients. Scand J Urol Nephrol. Apr. 1998;32(2):120-2. X-2. [pmid: 9606784].
2596 Wijnands M, van Riel P, van 't Hof M, et al. Longterm treatment with nonsteroidal antiinflammatory drugs in rheumatoid arthritis: a prospective drug survival study. J Rheumatol. Feb. 1991;18(2):184-7. X-2, X-3, X-4. [pmid: 2023212].
2597 Wilcox CM, Alexander LN, Cotsonis GA, et al. Nonsteroidal antiinflammatory drugs are associated with both upper and lower gastrointestinal bleeding. Dig Dis Sci. May. 1997;42(5):990-7. X-4. [pmid: 9149053].
2598 Wilcox CM, Clark WS. Features associated with painless peptic ulcer bleeding. Am J Gastroenterol. Aug. 1997;92(8):1289-92. X-2, X-4. [pmid: 9260791].
2599 Wilcox CM, Shalek KA, Cotsonis G. Striking prevalence of over-the-counter nonsteroidal anti-inflammatory drug use in patients with upper gastrointestinal hemorrhage. Arch Intern Med. Jan. 10. 1994;154(1):42-6. X-2, X-3. [pmid: 8267488].
2600 Wildemeersch D, Janssens D, Andrade A. The Femilis LNG-IUS: contraceptive performance-an interim analysis. Eur J Contracept Reprod Health Care. Apr. 2009;14(2):103-10. X-2. [pmid: 19340705].
2601 Wildemeersch D, Janssens D, Vrijens M, et al. Ease of insertion, contraceptive efficacy and safety of new T-shaped levonorgestrel-releasing intrauterine systems. Contraception. Jun. 2005;71(6):465-9. X-2. [pmid: 15914138].
2602 Wildemeersch D, Rowe PJ. Assessment of menstrual blood loss in Belgian users of a new T-shaped levonorgestrel-releasing intrauterine system. Contraception. Jun. 2005;71(6):470-3. X-2, X-3, X-4. [pmid: 15914139].
2603 Wildemeersch D, Schacht E. Contraception with a novel ‘frameless’ intrauterine levonorgestrel-releasing drug delivery system: a pilot study. Eur J Contracept Reprod Health Care. Dec. 2000;5(4):234-40. X-2, X-4. [pmid: 11245550].
2604 Wildemeersch D, Schacht E, Wildemeersch P. Treatment of primary and secondary dysmenorrhea with a novel ‘frameless’ intrauterine levonorgestrel-releasing drug delivery system: a pilot study. Eur J Contracept Reprod Health Care. Dec. 2001;6(4):192-8. X-2, X-4. [pmid: 11848648].
2605 Wildemeersch D, Schacht E, Wildemeersch P. Performance and acceptability of intrauterine release of levonorgestrel with a miniature delivery system for hormonal substitution therapy, contraception and treatment in peri and postmenopausal women. Maturitas. Mar. 28. 2003;44(3):237-45. X-2, X-3. [pmid: 12648887].
2606 Wilder-Smith CH, Hill L, Dyer RA, et al. Postoperative sensitization and pain after cesarean delivery and the effects of single im doses of tramadol and diclofenac alone and in combination. Anesth Analg. Aug. 2003;97(2):526-33. table of contents. X-2, X-3, X-4. [pmid: 12873948].
2607 Wildner-Christensen M, Hansen JM, De Muckadell OB. Risk factors for dyspepsia in a general population: non-steroidal anti-inflammatory drugs, cigarette smoking and unemployment are more important than Helicobacter pylori infection. Scand J Gastroenterol. Feb. 2006;41(2):149-54. X-4. [pmid: 16484119].
2608 Wile DJ, Toth C. Association of metformin, elevated homocysteine, and methylmalonic acid levels and clinically worsened diabetic peripheral neuropathy. Diabetes Care. Jan. 2010;33(1):156-61. X-2. [pmid: 19846797].
2609 Wilkinson SM, Smith AG, Davis MJ, et al. Suspected cutaneous drug toxicity in rheumatoid arthritis--an evaluation. Br J Rheumatol. Sep. 1993;32(9):798-803. X-2, X-4. [pmid: 8103699].
2610 Williams AN, Simon RA, Woessner KM, et al. The relationship between historical aspirin-induced asthma and severity of asthma induced during oral aspirin challenges. J Allergy Clin Immunol. Aug. 2007;120(2):273-7. X-2, X-4. [pmid: 17481713].
2611 Williams D, O'Kelly P, Kelly A, et al. Lack of symptom benefit following presumptive Helicobacter pylori eradication therapy in primary care. Aliment Pharmacol Ther. Nov. 2001;15(11):1769-75. X-3, X-4. [pmid: 11683691].
2612 Williams HJ, Ward JR, Egger MJ, et al. Comparison of naproxen and acetaminophen in a two-year study of treatment of osteoarthritis of the knee. Arthritis Rheum. Sep. 1993;36(9):1196-206. X-2, X-4. [pmid: 8216413].
2613 Willison DJ, Gaebel KA, Borden EK, et al. Experience in the development of a postmarketing surveillance network: the pharmacy medication monitoring program. Ann Pharmacother. Dec. 1995;29(12):1208-13. X-2, X-3, X-4. [pmid: 8672822].
2614 Wills BK, Bryant SM, Buckley P, et al. Can acute overdose of metformin lead to lactic acidosis?. Am J Emerg Med. Oct. 2010;28(8):857-61. X-2. [pmid: 20887905].
2615 Wilson J. A randomised trial and a comparative study of the copper 7 200 and the multiload copper 250 intrauterine devices. Aust N Z J Obstet Gynaecol. Feb. 1982;22(1):34-7. X-2, X-3, X-4. [pmid: 7049154].
2616 Wilson JA, Romagnuolo J, Byrne TK, et al. Predictors of endoscopic findings after Roux-en-Y gastric bypass. Am J Gastroenterol. Oct. 2006;101(10):2194-9. X-2, X-3. [pmid: 17032183].
2617 Wilson JC. A prospective New Zealand study of fertility after removal of copper intrauterine contraceptive devices for conception and because of complications: a four-year study. Am J Obstet Gynecol. Feb. 1989;160(2):391-6. X-2, X-4. [pmid: 2916624].
2618 Wilson JC. A New Zealand randomized comparative study of three IUDs (Nova-T, MLCu375, MLAgCu250): 1-, 2- and 3-year results. Adv Contracept. Jun. 1992;8(2):153-9. X-2, X-3, X-4. [pmid: 1519497].
2619 Wilson RG, Smith AN, Macintyre IM. Complications of diverticular disease and non-steroidal anti-inflammatory drugs: a prospective study. Br J Surg. Oct. 1990;77(10):1103-4. X-2. [pmid: 2121310].
2620 Wilting I, Movig KL, Moolenaar M, et al. Drug-drug interactions as a determinant of elevated lithium serum levels in daily clinical practice. Bipolar Disord. Jun. 2005;7(3):274-80. X-2, X-4. [pmid: 15898965].
2621 Wingrave SJ. Progestogen effects and their relationship to lipoprotein changes. A report from the Oral Contraception Study of the Royal College of General Practitioners. Acta Obstet Gynecol Scand Suppl. 1982;105:33-6. X-4. [pmid: 6805242].
2622 Winkelmayer WC, Waikar SS, Mogun H, et al. Nonselective and cyclooxygenase-2-selective NSAIDs and acute kidney injury. Am J Med. Dec. 2008;121(12):1092-8. X-7. [pmid: 19028206].
2623 Winkler UH. The effect of tranexamic acid on the quality of life of women with heavy menstrual bleeding. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2001;99(2):238-43. X-2, X-3. [pmid: 11788179].
2624 Winkler UH, Holscher T, Schulte H, et al. Ethinylestradiol 20 versus 30 micrograms combined with 150 micrograms desogestrel: a large comparative study of the effects of two low-dose oral contraceptives on the hemostatic system. Gynecol Endocrinol. Aug. 1996;10(4):265-71. X-2, X-4. [pmid: 8908527].
2625 Witjaksono J, Lau TM, Affandi B, et al. Oestrogen treatment for increased bleeding in Norplant users: preliminary results. Hum Reprod. Oct. Suppl 2. 1996;11:109-14. X-2, X-3, X-4. [pmid: 8982752].
2626 Wittpenn JR, Silverstein S, Heier J, et al. A randomized, masked comparison of topical ketorolac 0.4% plus steroid vs steroid alone in low-risk cataract surgery patients. Am J Ophthalmol. Oct. 2008;146(4):554-60. X-2, X-3, X-4. [pmid: 18599019].
2627 Wohrl S, Vigl K, Stingl G. Patients with drug reactions -- is it worth testing?. Allergy. Aug. 2006;61(8):928-34. X-2, X-3, X-4. [pmid: 16867044].
2628 Wolfe BM, Koval JJ, Nisker JA. Impact on postmenopausal symptoms of adding continuous C-21 versus C-19 progestin to estrogen. Maturitas. Oct. 24. 1999;33(2):153-61. X-2, X-4. [pmid: 10597880].
2629 Wolfe F, Anderson J, Burke TA, et al. Gastroprotective therapy and risk of gastrointestinal ulcers: risk reduction by COX-2 therapy. J Rheumatol. Mar. 2002;29(3):467-73. X-4. [pmid: 11908558].
2630 Wolfe F, Hawley DJ. The comparative risk and predictors of adverse gastrointestinal events in rheumatoid arthritis and osteoarthritis: a prospective 13 year study of 2131 patients. J Rheumatol. Jul. 2000;27(7):1668-73. X-4. [pmid: 10914849].
2631 Wolfe F, Michaud K, Stephenson B, et al. Toward a definition and method of assessment of treatment failure and treatment effectiveness: the case of leflunomide versus methotrexate. J Rheumatol. Aug. 2003;30(8):1725-32. X-2, X-3, X-4. [pmid: 12913927].
2632 Wolkenstein P, Chosidow O, Flechet ML, et al. Patch testing in severe cutaneous adverse drug reactions, including Stevens-Johnson syndrome and toxic epidermal necrolysis. Contact Dermatitis. Oct. 1996;35(4):234-6. X-2, X-3, X-4. [pmid: 8957644].
2633 Wollter-Svensson LO, Stadberg E, Andersson K, et al. Intrauterine administration of levonorgestrel in two low doses in HRT. A randomized clinical trial during one year: effects on lipid and lipoprotein metabolism. Maturitas. Nov. 1995;22(3):199-205. X-2, X-4. [pmid: 8746877].
2634 Womack JA, Scherzer R, Cole SR, et al. Hormonal contraception and metabolic outcomes in women with or at risk for HIV infection. J Acquir Immune Defic Syndr. Dec. 2009;52(5):581-7. X-2, X-3. [pmid: 19950431].
2635 Wong A, Sibbald A, Ferrero F, et al. Antipyretic effects of dipyrone versus ibuprofen versus acetaminophen in children: results of a multinational, randomized, modified double-blind study. Clin Pediatr (Phila). Jun. 2001;40(6):313-24. X-2, X-3, X-4. [pmid: 11824173].
2636 Wood SL, Jarrell JJ, Swaby C, et al. Endocrine disruptors and spontaneous premature labor: a case control study. Environ Health. 2007;6:35. X-2, X-3, X-4. [pmid: 18005447].
2637 Woods ER, Grace E, Havens KK, et al. Contraceptive compliance with a levonorgestrel triphasic and a norethindrone monophasic oral contraceptive in adolescent patients. Am J Obstet Gynecol. Mar. 1992;166(3):901-7. X-2, X-4. [pmid: 1550161].
2638 Woutersz TB, Korba VD. Five-year, multicenter study of a triphasic, low-dose, combination oral contraceptive. Int J Fertil. Nov-Dec. 1988;33(6):406-10. X-4. [pmid: 2906915].
2639 Wright RL, Frost CJ, Turok DK. A qualitative exploration of emergency contraception users' willingness to select the copper IUD. Contraception. Jan. 2012;85(1):32-5. X-2, X-3, X-4. [pmid: 22067808].
2640 Wroblewski M, Ostberg H. Ulcer disease among geriatric inpatients with positive faecal occult blood test and/or iron deficiency anaemia. A prospective study. Scand J Gastroenterol. May. 1990;25(5):489-95. X-2. [pmid: 2359977].
2641 Wu CJ, Hsu PI, Lo GH, et al. Comparison of cetraxate-based and pantoprazole-based triple therapies in the treatment of Helicobacter pylori infection. J Chin Med Assoc. Apr. 2004;67(4):161-7. X-2, X-3, X-4. [pmid: 15244013].
2642 Wu CS, Wang SH, Chen PC, et al. Does famotidine have similar efficacy to misoprostol in the treatment of non-steroidal anti-inflammatory drug-induced gastropathy?. Int J Clin Pract. Oct. 1998;52(7):472-4. X-2, X-3, X-4. [pmid: 10622088].
2643 Wu CY, Poon SK, Chen GH, et al. Interaction between Helicobacter pylori and non-steroidal anti-inflammatory drugs in peptic ulcer bleeding. Scand J Gastroenterol. Mar. 1999;34(3):234-7. X-2, X-4. [pmid: 10232865].
2644 Wu CY, Wu MS, Chen CJ, et al. The interaction of H. pylori infection and NSAIDs in cyclooxygenase-2 mRNA expression in gastric antral, corpus mucosa, and gastric ulcer. J Clin Gastroenterol. Jan. 2005;39(1):50-5. X-2. [pmid: 15599211].
2645 Wu S, Godfrey EM, Wojdyla D, et al. Copper T380A intrauterine device for emergency contraception: a prospective, multicentre, cohort clinical trial. BJOG. Sep. 2010;117(10):1205-10. X-4. [pmid: 20618314].
2646 Wurnig C, Eyb R, Auersperg V. Indomethacin for prevention of ectopic ossification in cementless hip arthroplasties. A prospective 1-year study of 100 cases. Acta Orthop Scand. Dec. 1992;63(6):628-30. X-2, X-4. [pmid: 1471510].
2647 Wysenbeek AJ, Klein Z, Nakar S, et al. Assessment of cognitive function in elderly patients treated with naproxen. A prospective study. Clin Exp Rheumatol. Oct-Dec. 1988;6(4):399-400. X-2, X-4. [pmid: 3229030].
2648 Wysowski DK, Green L. Serious adverse events in Norplant users reported to the Food and Drug Administration's MedWatch Spontaneous Reporting System. Obstet Gynecol. Apr. 1995;85(4):538-42. X-2, X-4. [pmid: 7898829].
2649 Xia HH, Phung N, Kalantar JS, et al. Demographic and endoscopic characteristics of patients with Helicobacter pylori positive and negative peptic ulcer disease. Med J Aust. Nov. 20. 2000;173(10):515-9. X-2, X-3, X-4. [pmid: 11194733].
2650 Xiang AH, Kawakubo M, Kjos SL, et al. Long-acting injectable progestin contraception and risk of type 2 diabetes in Latino women with prior gestational diabetes mellitus. Diabetes Care. Mar. 2006;29(3):613-7. X-2. [pmid: 16505515].
2651 Xiao B, Wu SC, Chong J, et al. Therapeutic effects of the levonorgestrel-releasing intrauterine system in the treatment of idiopathic menorrhagia. Fertil Steril. Apr. 2003;79(4):963-9. X-2, X-3. [pmid: 12749438].
2652 Yamada A, Sugimoto T, Kondo S, et al. Assessment of the risk factors for colonic diverticular hemorrhage. Dis Colon Rectum. Jan. 2008;51(1):116-20. X-4. [pmid: 18085336].
2653 Yamamoto T, Mishina Y, Ebato T, et al. Prevalence of erosive esophagitis among Japanese patients taking low-dose aspirin. J Gastroenterol Hepatol. Apr. 2010;25(4):792-4. X-4. [pmid: 20074160].
2654 Yamamoto T, Umegae S, Matsumoto K. High-dose mesalazine treatment for ulcerative colitis patients who relapse under low-dose maintenance therapy. Dig Liver Dis. May. 2011;43(5):386-90. X-2, X-3, X-4. [pmid: 21195041].
2655 Yanagi RM, Wilson A, Newfeld EA, et al. Indomethacin treatment for symptomatic patent ductus arteriosus: a double-blind control study. Pediatrics. May. 1981;67(5):647-52. X-2, X-3, X-4. [pmid: 7019841].
2656 Yanchick J, Magelli M, Bodie J, et al. Time to significant pain reduction following DETP application vs placebo for acute soft tissue injuries. Curr Med Res Opin. Aug. 2010;26(8):1993-2002. X-2, X-4. [pmid: 20575621].
2657 Yang CP, Cherng CH, Wong CS, et al. Effects of intravenous ketorolac and fentanyl combined with midazolam on analgesia and side effects during extracorporeal shock wave lithotripsy. Acta Anaesthesiol Sin. Mar. 2002;40(1):9-12. X-2, X-4. [pmid: 11989050].
2658 Yang MS, Lee SH, Kim TW, et al. Epidemiologic and clinical features of anaphylaxis in Korea. Ann Allergy Asthma Immunol. Jan. 2008;100(1):31-6. X-4. [pmid: 18254479].
2659 Yang YX, Hennessy S, Propert K, et al. Chronic proton pump inhibitor therapy and the risk of colorectal cancer. Gastroenterology. Sep. 2007;133(3):748-54. X-4. [pmid: 17678926].
2660 Yaniv E, Shvero J, Hadar T. Hemostatic effect of tranexamic acid in elective nasal surgery. Am J Rhinol. Mar-Apr. 2006;20(2):227-9. X-2, X-3, X-4. [pmid: 16686395].
2661 Yasmin E, Glanville J, Barth J, et al. Effect of dose escalation of metformin on clinical features, insulin sensitivity and androgen profile in polycystic ovary syndrome. Eur J Obstet Gynecol Reprod Biol. May. 2011;156(1):67-71. X-2, X-3. [pmid: 21277073].
2662 Ye Z, Thomas DB, Ray RM. Combined oral contraceptives and risk of cervical carcinoma in situ. WHO Collaborative Study of Neoplasia and Steroid Contraceptives. Int J Epidemiol. Feb. 1995;24(1):19-26. X-4. [pmid: 7797343].
2663 Yeh TF, Goldbarg H, Pildes RS. Follow-up of premature infants treated with indomethacin. J Pediatr. Aug. 1981;99(2):336. X-1, X-2. [pmid: 7252709].
2664 Yeh TF, Goldbarg HR, Henek T, et al. Intravenous indomethacin therapy in premature infants with patent ductus arteriosus. Causes of death and one-year follow-up. Am J Dis Child. Sep. 1982;136(9):803-7. X-2, X-3, X-4. [pmid: 7114004].
2665 Yeomans N, Lanas A, Labenz J, et al. Efficacy of esomeprazole (20 mg once daily) for reducing the risk of gastroduodenal ulcers associated with continuous use of low-dose aspirin. Am J Gastroenterol. Oct. 2008;103(10):2465-73. X-2, X-3, X-4. [pmid: 18637091].
2666 Yeomans N, Wilson I, Langstrom G, et al. Quality of life in chronic NSAID users: a comparison of the effect of omeprazole and misoprostol. Scand J Rheumatol. 2001;30(6):328-34. X-2, X-4. [pmid: 11846050].
2667 Yigit N, Kacar M, Yigit H, et al. The effects of copper contraceptive intrauterine device on the uterine blood flow: A prospective transvaginal Doppler study. J Clin Ultrasound. Sep. 2009;37(7):380-4. X-2, X-3. [pmid: 19455700].
2668 Yilmaz H, Gurel S, Ozdemir O. Turkish patients with osteoarthritis: their awareness of the side effects of NSAIDs. Turk J Gastroenterol. Jun. 2005;16(2):89-92. X-4. [pmid: 16252199].
2669 Yilmaz S, Bayan K, Dursun M, et al. Does adding misoprostol to standard intravenous proton pump inhibitor protocol improve the outcome of aspirin/NSAID-induced upper gastrointestinal bleeding?: a randomized prospective study. Dig Dis Sci. Jan. 2007;52(1):110-8. X-2, X-3, X-4. [pmid: 17151802].
2670 Yki-Jarvinen H, Ryysy L, Nikkila K, et al. Comparison of bedtime insulin regimens in patients with type 2 diabetes mellitus. A randomized, controlled trial. Ann Intern Med. Mar. 2. 1999;130(5):389-96. X-2, X-4. [pmid: 10068412].
2671 Ylikorkala O, Wahlstrom T, Caubel P, et al. Intermittent progestin administration as part of hormone replacement therapy: long-term comparison between estradiol 1 mg combined with intermittent norgestimate and estradiol 2 mg combined with constant norethisterone acetate. Acta Obstet Gynecol Scand. Jul. 2002;81(7):654-60. X-2, X-4. [pmid: 12190841].
2672 Yoon NM, Cavaghan MK, Brunelle RL, et al. Exenatide added to insulin therapy: a retrospective review of clinical practice over two years in an academic endocrinology outpatient setting. Clin Ther. Jul. 2009;31(7):1511-23. X-2, X-3, X-4. [pmid: 19695400].
2673 Yoong WC, Tuck SM, Yardumian A. Red cell deformability in oral contraceptive pill users with sickle cell anaemia. Br J Haematol. Mar. 1999;104(4):868-70. X-2, X-4. [pmid: 10192452].
2674 Younossi ZM, Strum WB, Schatz RA, et al. Effect of combined anticoagulation and low-dose aspirin treatment on upper gastrointestinal bleeding. Dig Dis Sci. Jan. 1997;42(1):79-82. X-2, X-4. [pmid: 9009119].
2675 Yu JO, Gundel RE. Use of Acular LS in the pain management of keratoconus: a pilot study. Optom Vis Sci. Feb. 2010;87(2):125-30. X-2, X-4. [pmid: 19996813].
2676 Zabinski RA, Burke TA, Johnson J, et al. An economic model for determining the costs and consequences of using various treatment alternatives for the management of arthritis in Canada. Pharmacoeconomics. Suppl 1. 2001;19:49-58. X-2, X-4. [pmid: 11280105].
2677 Zackova M, Taddei S, Calo P, et al. Ketorolac vs tramadol in the treatment of postoperative pain during maxillofacial surgery. Minerva Anestesiol. Sep. 2001;67(9):641-6. X-2, X-3, X-4. [pmid: 11731754].
2678 Zalel Y, Shulman A, Lidor A, et al. The local progestational effect of the levonorgestrel-releasing intrauterine system: a sonographic and Doppler flow study. Hum Reprod. Nov. 2002;17(11):2878-80. X-2, X-4. [pmid: 12407042].
2679 Zalev AH, Gardiner GW, Warren RE. NSAID injury to the small intestine. Abdom Imaging. Jan-Feb. 1998;23(1):40-4. X-2. [pmid: 9437061].
2680 Zancan A, Locatelli C, Ramella F, et al. A new model of pharmacovigilance? A pilot study. Biomed Pharmacother. Jul. 2009;63(6):451-5. X-2, X-3, X-4. [pmid: 18790597].
2681 Zandbelt MM, Houbiers JG, van den Hoogen FH, et al. Intranasal administration of recombinant human cartilage glycoprotein-39. A phase I escalating cohort study in patients with rheumatoid arthritis. J Rheumatol. Sep. 2006;33(9):1726-33. X-2, X-4. [pmid: 16960935].
2682 Zanettini R, Antonini A, Gatto G, et al. Valvular heart disease and the use of dopamine agonists for Parkinson's disease. N Engl J Med. Jan. 4. 2007;356(1):39-46. X-2. [pmid: 17202454].
2683 Zanettini R, Antonini A, Gatto G, et al. Regression of cardiac valvulopathy related to ergot-derived dopamine agonists. Cardiovasc Ther. Dec. 2011;29(6):404-10. X-2. [pmid: 20553285].
2684 Zapata-Colindres JC, Zepeda-Gomez S, Montano-Loza A, et al. The association of Helicobacter pylori infection and nonsteroidal anti-inflammatory drugs in peptic ulcer disease. Can J Gastroenterol. Apr. 2006;20(4):277-80. X-2. [pmid: 16609757].
2685 Zaporozhan VN, Khait OV, Tumasyan KP. Norcolut with immune modulators in the complex treatment for hyperplastic uterine processes. Clin Exp Obstet Gynecol. 1993;20(1):13-9. X-2, X-4. [pmid: 8462182].
2686 Zaraa I, Jones M, Trojjet S, et al. Severe adverse cutaneous drug eruptions: epidemiological and clinical features. Int J Dermatol. Jul. 2011;50(7):877-80. X-2. [pmid: 21699528].
2687 Zecca E, Romagnoli C, De Carolis MP, et al. Does Ibuprofen increase neonatal hyperbilirubinemia?. Pediatrics. Aug. 2009;124(2):480-4. X-2, X-4. [pmid: 19620202].
2688 Zeidler H. Epidemiology and NSAID induced gastropathy. J Rheumatol Suppl. Mar. 1991;28:2-5. X-1. [pmid: 2038013].
2689 Zembowicz A, Mastalerz L, Setkowicz M, et al. Safety of cyclooxygenase 2 inhibitors and increased leukotriene synthesis in chronic idiopathic urticaria with sensitivity to nonsteroidal anti-inflammatory drugs. Arch Dermatol. Dec. 2003;139(12):1577-82. X-2, X-3, X-4. [pmid: 14676074].
2690 Zerr DM, Alexander ER, Duchin JS, et al. A case-control study of necrotizing fasciitis during primary varicella. Pediatrics. Apr. 1999;103(4 Pt 1):783-90. X-2, X-4. [pmid: 10103303].
2691 Zhang J. Factors associated with copper T IUD removal for bleeding/pain: a multivariate analysis. Contraception. Jul. 1993;48(1):13-21. X-2, X-4. [pmid: 8403901].
2692 Zhang Y, Coogan PF, Palmer JR, et al. Risk of non-Hodgkin lymphoma and use of non-steroidal anti-inflammatory drugs. Cancer Detect Prev. 2006;30(1):99-101. X-4. [pmid: 16495019].
2693 Zhao S, Choksuchat C, Zhao Y, et al. Effects of doxycycline on serum and endometrial levels of MMP-2, MMP-9 and TIMP-1 in women using a levonorgestrel-releasing subcutaneous implant. Contraception. Jun. 2009;79(6):469-78. X-2, X-4. [pmid: 19442784].
2694 Zhao SZ, Burke TA, Whelton A, et al. Cost of heart failure among hypertensive users of nonspecific NSAIDs and COX-2-specific inhibitors. Am J Manag Care. Oct. 2002;8(15 Suppl):S414-27. X-4. [pmid: 12416791].
2695 Ziaei S, Ninavaei M, Faghihzadeh S. Urinary tract infection in the users of depot-medroxyprogesterone acetate. Acta Obstet Gynecol Scand. Oct. 2004;83(10):909-11. X-2. [pmid: 15453884].
2696 Zichella L, Sbrignadello C, Tomassini A, et al. Comparative study on the acceptability of two modern monophasic oral contraceptive preparations: 30 microgram ethinyl estradiol combined with 150 microgram desogestrel or 75 microgram gestodene. Adv Contracept. 1999;15(3):191-200. X-2, X-4. [pmid: 11019950].
2697 Zimmerman J, Arnon R, Beeri R, et al. Seasonal fluctuations in acute upper gastrointestinal bleeding: lack of effect of nonsteroidal anti-inflammatory drugs. Am J Gastroenterol. Nov. 1992;87(11):1587-90. X-2, X-3, X-4. [pmid: 1442678].
2698 Zimmerman J, Arnon R, Ligumski M, et al. Acute upper gastrointestinal bleeding in Jerusalem 1988-91: causes, characteristics and relation to nonsteroidal anti-inflammatory drugs. Isr J Med Sci. May. 1993;29(5):292-7. X-2, X-4. [pmid: 8314690].
2699 Zimmerman J, Meroz Y, Siguencia J, et al. Upper gastrointestinal hemorrhage. Comparison of the causes and prognosis in primary and secondary bleeders. Scand J Gastroenterol. Sep. 1994;29(9):795-8. X-2, X-3, X-4. [pmid: 7824858].
2700 Zimmermann T, Dietrich H, Wisser KH, et al. The efficacy and tolerability of Valette: a postmarketing surveillance study. Eur J Contracept Reprod Health Care. Sep. 1999;4(3):155-64. X-4. [pmid: 10574641].
2701 Zimran A, Kramer M, Plaskin M, et al. Incidence of hyperkalaemia induced by indomethacin in a hospital population. Br Med J (Clin Res Ed). Jul. 13. 1985;291(6488):107-8. X-1. [pmid: 3926071].
2702 Zizic TM, Sutton JD, Stevens MB. A long-term evaluation of the treatment of osteoarthritis. Am J Med. Nov. 28. 1986;81(5B):29-35. X-2, X-3, X-4. [pmid: 3538868].
2703 Zochling J, Bohl-Buhler MH, Baraliakos X, et al. Nonsteroidal anti-inflammatory drug use in ankylosing spondylitis--a population-based survey. Clin Rheumatol. Nov. 2006;25(6):794-800. X-2. [pmid: 16528455].
2704 Zweifel SA, Engelbert M, Khan S, et al. Retrospective review of the efficacy of topical bromfenac (0.09%) as an adjunctive therapy for patients with neovascular age-related macular degeneration. Retina. Nov-Dec. 2009;29(10):1527-31. X-2, X-3, X-4. [pmid: 19898185].
2705 Zziwambazza W, Merkle CJ, Moore IM, et al. The effects of norepinephrine infusion on the circulating lymphocyte counts of post-open heart surgery patients. Biol Res Nurs. Jan. 2000;1(3):199-209. X-2, X-4. [pmid: 11232215].