# Evidence Table

AUB KQ1 Evidence Table (Reference ID #121)

AUB KQ1 Evidence Table (Reference ID #631)

AUB KQ1 Evidence Table (Reference ID #1431)

AUB KQ1 Evidence Table (Reference ID #564)

AUB KQ1 Evidence Table (Reference ID #25)

AUB KQ1 Evidence Table (Reference ID #76)

AUB KQ1 Evidence Table (Reference ID #700)

AUB KQ1 Evidence Table (Reference ID #1777)

AUB KQ1 Evidence Table (Reference ID #1363)

AUB KQ1 Evidence Table (Reference ID #1675)

AUB KQ1 Evidence Table (Reference ID #1783)

AUB KQ1 Evidence Table (Reference ID #1170)

AUB KQ1 Evidence Table (Reference ID #871)

AUB KQ1 Evidence Table (Reference ID #1116)

AUB KQ1 Evidence Table (Reference ID #1184)

AUB KQ1 Evidence Table (Reference ID #123)

AUB KQ1 Evidence Table (Reference ID #1349)

AUB KQ1 Evidence Table (Reference ID #1103)

AUB KQ1 Evidence Table (Reference ID #1304, #1255)

AUB KQ1 Evidence Table (Reference ID #1767)

AUB KQ1 Evidence Table (Reference ID #1114)

AUB KQ1 Evidence Table (Reference ID #1190)

AUB KQ1 Evidence Table (Reference ID #789)

AUB KQ1 Evidence Table (Reference ID #1365)

AUB KQ1 Evidence Table (Reference ID #32)

AUB KQ1 Evidence Table (Reference ID #493)

AUB KQ1 Evidence Table (Reference ID #267)

AUB KQ1 Evidence Table (Reference ID #189)

AUB KQ1 Evidence Table (Reference ID #802)

AUB KQ1 Evidence Table (Reference ID #29)

AUB KQ1 Evidence Table (Reference ID #1381)

AUB KQ1 Evidence Table (Reference ID #935)

AUB KQ1 Evidence Table (Reference ID #1441)

AUB KQ1 Evidence Table (Reference ID #341)

AUB KQ1 Evidence Table (Reference ID #17)

AUB KQ1 Evidence Table (Reference ID #1180)

AUB KQ1 Evidence Table (Reference ID #1059)

AUB KQ1 Evidence Table (Reference ID #1179)

AUB KQ1 Evidence Table (Reference ID #415, #379)