# Risk of Bias and Quality Score for Individual Studies

Author, Year | Random Sequence Generation | Allocation Concealment | Selective Reporting | Blinding (patients and personnel) | Blinding (outcome assessment) | Incomplete Outcome Data | Other Bias | Quality Score
Abu Hashim et al., 2012^1^ | + | + | + | - | - | + | + | Fair
Andersch et al., 1988^2^ | ? | ? | ? | ? | ? | + | + | Poor
Bonnar and Sheppard, 1996^3^ | + | ? | ? | - | - | + | + | Poor
Cai and Wu, 2009^4^ | + | + | + | ? | ? | + | + | Fair
Cameron et al., 1987^5^ | ? | ? | ? | - | - | ? | ? | Poor
Cameron et al., 1990^6^ | ? | ? | + | ? | ? | + | + | Poor
Davis et al., 2000^7^ | + | + | + | + | + | + | + | Good
Elkind-Hirsch et al., 2008^8^ | + | ? | + | - | - | - | + | Poor
Endrikat et al., 2009^9^ | + | - | + | - | ? | + | - | Poor
Fleming et al., 2002^10^ | + | + | + | + | + | - | + | Fair
Fraser and McCarron, 1991^11^ | ? | ? | + | - | - | - | + | Poor
Fraser et al., 1981^12^; 1984^13^ | ? | ? | + | + | + | + | + | Fair
Fraser et al., 2011^14^ | + | + | ? | + | + | + | + | Good
Freeman et al., 2011^15^ | ? | ? | + | + | ? | + | + | Fair
Grover et al., 1990^16^ | ? | ? | ? | ? | ? | ? | - | Poor
Hall et al., 1987^17^ | + | + | + | + | + | - | + | Fair
Irvine et al., 1998^18^ | + | + | ? | ? | - | + | + | Fair
Jedel et al., 2011^19^ | + | + | + | - | ? | - | + | Poor
Jensen et al., 2011^20^ | + | + | ? | + | + | + | + | Good
Karakus et al., 2009^21^ | + | - | ? | - | ? | - | ? | Poor
Kaunitz et al., 2010^22^ | + | + | + | - | ? | + | + | Fair
Kennedy et al., 2002^23^ | + | + | + | - | - | - | + | Poor
Kriplani et al., 2006^24^ | + | ? | ? | - | - | - | + | Poor
Kucuk and Ertan, 2008^25^ | - | - | ? | ? | ? | + | + | Poor
Lahteenmaki et al., 1998^26^ | + | + | ? | ? | - | + | + | Poor
Lukes et al., 2010^27^ | + | + | + | + | + | + | + | Good
Moghetti et al., 2000^28^ | ? | ? | ? | + | + | ? | + | Poor
Najam et al., 2010^29^ | + | ? | ? | - | - | + | + | Poor
Oner and Muderris, 2011^30^ | ? | ? | + | ? | ? | - | ? | Poor
Ornstein et al., 2011^31^ | ? | ? | + | - | ? | - | - | Poor
Paoletti et al., 1996^32^ | + | ? | + | + | + | + | + | Good
Preston et al., 1995^33^ | + | + | ? | + | + | - | + | Fair
Protheroe et al., 2007^34^ | + | + | ? | - | - | + | ? | Poor
Reid and Vitaren-Kari, 2005^35^ | + | + | ? | - | - | + | + | Poor
Shabaan etal., 2011^36^ | + | - | + | - | ? | + | - | Poor
Tsang et al., 1987^37^ | ? | ? | + | + | + | - | + | Poor
van Eijkeren et al., 1992^38^ | + | + | + | + | + | - | + | Fair
Vargyas et al., 1987^39^ | + | + | + | + | + | + | + | Good
Vuorma et al., 2004^40, 41^ | + | + | + | - | - | + | + | Poor
Totals
+ | 27 | 19 | 23 | 14 | 13 | 24 | 31
? | 11 | 16 | 16 | 8 | 13 | 3 | 4
- | 1 | 4 | 0 | 17 | 13 | 12 | 4

Notes: Low risk of bias: +; High risk of bias: -; Unclear risk of bias: ?

## References

1 Abu Hashim H, Alsherbini W, Bazeed M. Contraceptive vaginal ring treatment of heavy menstrual bleeding: a randomized controlled trial with norethisterone. Contraception. Mar. 2012;85(3):246-52. [pmid: 22067765].
2 Andersch B, Milsom I, Rybo G. An objective evaluation of flurbiprofen and tranexamic acid in the treatment of idiopathic menorrhagia. Acta Obstet Gynecol Scand. 1988;67(7):645-8. [pmid: 3073625].
3 Bonnar J, Sheppard BL. Treatment of menorrhagia during menstruation: randomised controlled trial of ethamsylate, mefenamic acid, and tranexamic acid. BMJ. Sep. 7. 1996;313(7057):579-82. [pmid: 8806245].
4 Cai XM, Wu J. The mind-tranquilizing and menstruation-regulating method for acupuncture treatment of delayed menstrual cycle--a clinical controlled study. J Tradit Chin Med. Mar. 2009;29(1):35-8. [pmid: 19514186].
5 Cameron IT, Leask R, Kelly RW, et al. The effects of danazol, mefenamic acid, norethisterone and a progesterone-impregnated coil on endometrial prostaglandin concentrations in women with menorrhagia. Prostaglandins. Jul. 1987;34(1):99-110. [pmid: 3685399].
6 Cameron IT, Haining R, Lumsden MA, et al. The effects of mefenamic acid and norethisterone on measured menstrual blood loss. Obstet Gynecol. Jul. 1990;76(1):85-8. [pmid: 2359570].
7 Davis A, Godwin A, Lippman J, et al. Triphasic norgestimate-ethinyl estradiol for treating dysfunctional uterine bleeding. Obstet Gynecol. Dec. 2000;96(6):913-20. [pmid: 11084177].
8 Elkind-Hirsch K, Marrioneaux O, Bhushan M, et al. Comparison of single and combined treatment with exenatide and metformin on menstrual cyclicity in overweight women with polycystic ovary syndrome. Journal of Clinical Endocrinology and Metabolism. 2008;93(7):2670-8. [pmid: 18460557].
9 Endrikat J, Shapiro H, Lukkari-Lax E, et al. A Canadian, multicentre study comparing the efficacy of a levonorgestrel-releasing intrauterine system to an oral contraceptive in women with idiopathic menorrhagia. J Obstet Gynaecol Can. Apr. 2009;31(4):340-7. [pmid: 19497153].
10 Fleming R, Hopkinson ZE, Wallace AM, et al. Ovarian function and metabolic factors in women with oligomenorrhea treated with metformin in a randomized double blind placebo-controlled trial. J Clin Endocrinol Metab. Feb. 2002;87(2):569-74. [pmid: 11836287].
11 Fraser IS, McCarron G. Randomized trial of 2 hormonal and 2 prostaglandin-inhibiting agents in women with a complaint of menorrhagia. Aust N Z J Obstet Gynaecol. Feb. 1991;31(1):66-70. [pmid: 1872778].
12 Fraser IS, Pearse C, Shearman RP, et al. Efficacy of mefenamic acid in patients with a complaint of menorrhagia. Obstet Gynecol. Nov. 1981;58(5):543-51. [pmid: 7029369].
13 Fraser IS, McCarron G, Markham R. A preliminary study of factors influencing perception of menstrual blood loss volume. Am J Obstet Gynecol. Aug. 1. 1984;149(7):788-93. [pmid: 6380294].
14 Fraser IS, Romer T, Parke S, et al. Effective treatment of heavy and/or prolonged menstrual bleeding with an oral contraceptive containing estradiol valerate and dienogest: A randomized, double-blind Phase III trial. Human Reproduction. 2011;26(10):2698-708. [pmid: 21784734].
15 Freeman EW, Lukes A, VanDrie D, et al. A dose-response study of a novel, oral tranexamic formulation for heavy menstrual bleeding. Am J Obstet Gynecol. Oct. 2011;205(4):319 e1-7. [pmid: 21777897].
16 Grover V, Usha R, Gupta U, et al. Management of cyclical menorrhagia with prostaglandin synthetase inhibitor. Asia Oceania J Obstet Gynaecol. Sep. 1990;16(3):255-9. [pmid: 2088249].
17 Hall P, Maclachlan N, Thorn N, et al. Control of menorrhagia by the cyclo-oxygenase inhibitors naproxen sodium and mefenamic acid. Br J Obstet Gynaecol. Jun. 1987;94(6):554-8. [pmid: 3304401].
18 Irvine GA, Campbell-Brown MB, Lumsden MA, et al. Randomised comparative trial of the levonorgestrel intrauterine system and norethisterone for treatment of idiopathic menorrhagia. Br J Obstet Gynaecol. Jun. 1998;105(6):592-8. [pmid: 9647148].
19 Jedel E, Labrie F, Oden A, et al. Impact of electro-acupuncture and physical exercise on hyperandrogenism and oligo/amenorrhea in women with polycystic ovary syndrome: a randomized controlled trial. Am J Physiol Endocrinol Metab. Jan. 2011;300(1):E37-45. [pmid: 20943753].
20 Jensen JT, Parke S, Mellinger U, et al. Effective treatment of heavy menstrual bleeding with estradiol valerate and dienogest: A randomized controlled trial. Obstetrics and Gynecology. 2011;117(4):777-87. [pmid: 21422847].
21 Karakus S, Kiran G, Ciralik H. Efficacy of micronised vaginal progesterone versus oral dydrogestrone in the treatment of irregular dysfunctional uterine bleeding: a pilot randomised controlled trial. Aust N Z J Obstet Gynaecol. Dec. 2009;49(6):685-8. [pmid: 20070724].
22 Kaunitz AM, Bissonnette F, Monteiro I, et al. Levonorgestrel-releasing intrauterine system or medroxyprogesterone for heavy menstrual bleeding: a randomized controlled trial. Obstet Gynecol. Sep. 2010;116(3):625-32. [pmid: 20733445].
23 Kennedy AD, Sculpher MJ, Coulter A, et al. Effects of decision aids for menorrhagia on treatment choices, health outcomes, and costs: a randomized controlled trial. JAMA. Dec. 4. 2002;288(21):2701-8. [pmid: 12460093].
24 Kriplani A, Kulshrestha V, Agarwal N, et al. Role of tranexamic acid in management of dysfunctional uterine bleeding in comparison with medroxyprogesterone acetate. J Obstet Gynaecol. Oct. 2006;26(7):673-8. [pmid: 17071438].
25 Kucuk T, Ertan K. Continuous oral or intramuscular medroxyprogesterone acetate versus the levonorgestrel releasing intrauterine system in the treatment of perimenopausal menorrhagia: a randomized, prospective, controlled clinical trial in female smokers. Clin Exp Obstet Gynecol. 2008;35(1):57-60. [pmid: 18390083].
26 Lahteenmaki P, Haukkamaa M, Puolakka J, et al. Open randomised study of use of levonorgestrel releasing intrauterine system as alternative to hysterectomy. BMJ. Apr. 11. 1998;316(7138):1122-6. [pmid: 9552948].
27 Lukes AS, Moore KA, Muse KN, et al. Tranexamic acid treatment for heavy menstrual bleeding: a randomized controlled trial. Obstet Gynecol. Oct. 2010;116(4):865-75. [pmid: 20859150].
28 Moghetti P, Castello R, Negri C, et al. Metformin effects on clinical features, endocrine and metabolic profiles, and insulin sensitivity in polycystic ovary syndrome: a randomized, double-blind, placebo-controlled 6-month trial, followed by open, long-term clinical evaluation. J Clin Endocrinol Metab. Jan. 2000;85(1):139-46. [pmid: 10634377].
29 Najam R, Agarwal D, Tyagi R, et al. Comparison of traneximic acid with a combination of traneximic acid and mefenamic acid in reducing menstrual blood loss in ovulatory dysfunctional uterine bleeding (DUB). Journal of Clinical and Diagnostic Research. 2010;4(5):3020-5.
30 Oner G, Muderris II. Clinical, endocrine and metabolic effects of metformin vs N-acetyl-cysteine in women with polycystic ovary syndrome. Eur J Obstet Gynecol Reprod Biol. Nov. 2011;159(1):127-31. [pmid: 21831508].
31 Ornstein RM, Copperman NM, Jacobson MS. Effect of Weight Loss on Menstrual Function in Adolescents with Polycystic Ovary Syndrome. Journal of Pediatric and Adolescent Gynecology. 2011;24(3):161-5. [pmid: 21419674].
32 Paoletti AM, Cagnacci A, Depan GF, et al. The chronic administration of cabergoline normalizes androgen secretion and improves menstrual cyclicity in women with polycystic ovary syndrome. Fertility and Sterility. 1996;66(4):527-32. [pmid: 8816612].
33 Preston JT, Cameron IT, Adams EJ, et al. Comparative study of tranexamic acid and norethisterone in the treatment of ovulatory menorrhagia. Br J Obstet Gynaecol. May. 1995;102(5):401-6. [pmid: 7612535].
34 Protheroe J, Bower P, Chew-Graham C, et al. Effectiveness of a computerized decision aid in primary care on decision making and quality of life in menorrhagia: Results of the MENTIP randomized controlled trial. Medical Decision Making. 2007;27(5):575-84. [pmid: 17898242].
35 Reid PC, Virtanen-Kari S. Randomised comparative trial of the levonorgestrel intrauterine system and mefenamic acid for the treatment of idiopathic menorrhagia: a multiple analysis using total menstrual fluid loss, menstrual blood loss and pictorial blood loss assessment charts. BJOG. Aug. 2005;112(8):1121-5. [pmid: 16045528].
36 Shaaban MM, Zakherah MS, El-Nashar SA, et al. Levonorgestrel-releasing intrauterine system compared to low dose combined oral contraceptive pills for idiopathic menorrhagia: a randomized clinical trial. Contraception. Jan. 2011;83(1):48-54. [pmid: 21134503].
37 Tsang BK, Domingo MT, Spence JE, et al. Endometrial prostaglandins and menorrhagia: influence of a prostaglandin synthetase inhibitor in vivo. Can J Physiol Pharmacol. Oct. 1987;65(10):2081-4. [pmid: 3123043].
38 van Eijkeren MA, Christiaens GC, Geuze HJ, et al. Effects of mefenamic acid on menstrual hemostasis in essential menorrhagia. Am J Obstet Gynecol. May. 1992;166(5):1419-28. [pmid: 1595797].
39 Vargyas JM, Campeau JD, Mishell DR Jr. Treatment of menorrhagia with meclofenamate sodium. Am J Obstet Gynecol. Oct. 1987;157(4 Pt 1):944-50. [pmid: 3314521].
40 Vuorma S, Teperi J, Aalto AM, et al. A randomized trial among women with heavy menstruation -- impact of a decision aid on treatment outcomes and costs. Health Expect. Dec. 2004;7(4):327-37. [pmid: 15544685].
41 Vuorma S, Rissanen P, Aalto AM, et al. Impact of patient information booklet on treatment decision--a randomized trial among women with heavy menstruation. Health Expect. Dec. 2003;6(4):290-7. [pmid: 15040791].