# Literature Search Strategies

Table A1 KQ1 search strategy and results from PubMed (pubmed.gov interface)

Terms | | Results
#1 | uterine hemorrhage[mh:noexp] OR metrorrhagia[mh] OR menstruation disturbances[mh:noexp] OR menorrhagia[mh] OR oligomenorrhea[mh] OR menorrhagia[tiab] OR metrorrhagia[tiab] OR menometrorrhagia[tiab] OR polymenorrhea[tiab] OR oligomenorrhea[tiab] OR hypermenorrhea[tiab] OR dysfunctional uterine bleeding[tiab] OR excessive uterine bleeding[tiab] OR abnormal uterine bleeding[tiab] OR irregular uterine bleeding[tiab] OR ((ovulation dysfunction[tiab] OR ovulatory dysfunction[tiab]) AND (bleeding[tiab] OR hemorrhage[tiab] OR haemorrhage[tiab])) OR ((anovulation[mh] OR anovulation[tiab] OR anovulatory[tiab]) AND (hemorrhage[tiab] OR haemorrhage[tiab] OR bleeding[tiab])) | 20,586
#2 | therapy[sh:noexp] OR drug therapy[mh] OR drug therapy[sh] OR contraceptives, oral[mh] OR contraceptive agents, female[pa] OR progestins[mh] OR progestins[pa] OR contraceptive devices, female[mh:noexp] OR intrauterine devices[mh] OR anti-inflammatory agents, non-steroidal[mh] OR anti-inflammatory agents, non-steroidal[pa] OR antifibrinolytic agents[mh] OR antifibrinolytic agents[pa] OR complementary therapies[mh] OR cam[sb] OR diet therapy[mh] OR diet therapy[sh] OR exercise therapy[mh] OR psychotherapy[mh] | 3,994,137
#3 | #1 AND #2 AND english[la] AND humans[mh] AND 1980:2012[dp] | 4,846
#4 | #3 AND editorial[pt] | 30
#5 | #3 AND letter[pt] | 190
#6 | #3 AND comment[pt] | 100
#7 | #3 AND case reports[pt] | 872
#8 | #3 AND review[pt] | 1,078
#9 | #3 AND news[pt] | 11
#10 | #3 AND newspaper article[pt] | 5
#11 | #3 AND historical article[pt] | 12
#12 | #3 AND clinical conference[pt] | 7
#13 | #3 AND practice guideline[pt] | 23
#14 | #3 AND meta-analysis[pt] | 43
#15 | #3 AND congresses[pt] | 6
#16 | #3 AND consensus development conference[pt] | 11
#17 | #3 AND retracted publication[pt] | 3
#18 | #3 AND jsubsetk | 21
#19 | #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 | 2,090^*^
#20 | #3 NOT #19 | 2,756
#21 | #20 AND (random allocation[mh] OR double-blind method[mh] OR single-blind method[mh] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR clinical trial[pt] OR clinical trial[tiab] OR random[tiab] OR randomized[tiab] OR randomised[tiab] OR randomly[tiab] OR assigned[tiab] OR allocated[tiab] OR control[tiab] OR controlled[tiab] OR controls[tiab]) | 1,374

Key: [dp] publication date; jsubsetk consumer health subset; [la] language; [mh] medical subject heading; [pa] pharmacological action; [pt] publication type; [sb] subset search; [sh] subheading; [tiab] keyword in title or abstract.

* Note: numbers may not tally as some articles are excluded in more than one category.

Table A2 KQ1 search strategy and results from CINAHL (EBSCOhost interface)

Terms | | Results
#1 | (MH “Uterine Hemorrhage”) OR (MH “Metrorrhagia”) OR (MH “Menorrhagia”) OR (MH “Menstruation Disorders”) OR menorrhagia OR metrorrhagia OR menometrorrhagia OR polymenorrhea OR oligomenorrhea OR hypermenorrhea OR dysfunctional uterine bleeding OR excessive uterine bleeding OR abnormal uterine bleeding OR irregular uterine bleeding OR ovulation dysfunction OR ovulatory dysfunction OR ((anovulation OR anovulatory OR cyclic OR cyclical) AND (hemorrhage OR haemorrhage OR bleeding)) | 1,933
#2 | (MH “Therapeutics”) OR therapeutic OR therapeutics OR therapy OR therapies OR treatment OR treatments OR management OR (MH “Drug Therapy+”) OR drug therapy OR (MH “Contraceptives, Oral+”) OR oral contraceptive OR oral contraceptives OR (MH “Intrauterine Devices”) OR intrauterine device OR intrauterine devices OR intrauterine system OR intrauterine systems OR IUD OR IUS OR vaginal ring OR (MH “Progestational Hormones+”) OR progestin OR progestins OR progestogen OR progestogens OR (MH “Antiinflammatory Agents, Non-Steroidal+”) OR non-steroidal anti-inflammatory OR nonsteroidal anti-inflammatory OR non-steroidal antiinflammatory OR nonsteroidal antiinflammatory OR NSAID OR NSAIDs OR (MH “Antifibrinolytic Agents”) OR antifibrinolytic OR anti-fibrinolytic OR antifibrinolytics OR anti-fibrinolytics OR tranexamic acid OR aminocaproic acid OR (MH “Natural and Biologically Based Therapies+”) OR (MH “Acupuncture+”) OR (MH “Alternative Therapies”) OR alternative medicine OR complementary medicine OR herbal medicine OR chinese medicine OR acupuncture OR phytotherapy OR (MH “Life Style Changes”) OR (MH “Exercise+”) OR (MH “Therapeutic Exercise+”) OR exercise OR (MH “Weight Loss”) OR weight loss OR (MH “Stress Management”) OR stress reduction | 888,917
#3 | #1 AND #2 | 1,267
#4 | #3 AND limiters: English language; Human | 376
#5 | #3 AND limiters: English language; Human; Exclude MEDLINE records | 33

Table A3 KQ1 search strategy and results from EMBASE (OVID interface)

Terms | | Results
#1 | exp uterus bleeding/ OR menstruation disorder/ OR exp “menorrhagia and metrorrhagia”/ OR (uterine hemorrhage OR metrorrhagia OR menorrhagia OR menometrorrhagia OR polymenorrhea OR oligomenorrhea OR hypermenorrhea OR dysfunctional uterine bleeding OR excessive uterine bleeding OR abnormal uterine bleeding OR irregular uterine bleeding OR ((ovulation dysfunction OR ovulatory dysfunction) AND (bleeding OR hemorrhage OR hemorrhage)) OR ((anovulation OR anovulation OR anovulatory) AND (hemorrhage OR haemorrhage OR bleeding))).mp | 27,343
#2 | exp oral contraceptive agent/ OR exp intrauterine contraceptive device/ OR exp vagina ring/ OR exp gestagen/ OR exp nonsteroid antiinflammatory agent/ OR exp antifibrinolytic agent/ OR exp alternative medicine/ OR exp traditional medicine/ OR exp acupuncture/ OR exp diet therapy/ OR exp weight reduction/ OR exp stress management/ OR exp relaxation training/ | 929,093
#3 | 1 AND 2, limited to human and English language and 1980-2012 | 6,055
#4 | 3 AND review.pt | 1,823
#5 | 3 AND conference paper.pt | 273
#6 | 3 AND conference abstract.pt | 84
#7 | 3 AND editorial.pt | 96
#8 | 3 AND letter.pt | 213
#9 | 3 AND note.pt | 138
#10 | 3 AND short survey.pt | 148
#11 | 3 AND case report/ | 641
#12 | 3 AND practice guideline/ | 184
#13 | 3 AND systematic review/ | 158
#14 | 3 AND meta analysis/ | 138
#15 | 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14 | 3,365^*^
#16 | 3 NOT 15 | 2,690
#17 | 16 AND (exp clinical trial/ OR exp controlled clinical trial/) AND (exp randomization/ OR randomized controlled trial/ OR (random OR randomly OR randomized OR randomised).mp) | 573^**^

Key: / subject term; exp explode term; .mp keyword, subject term, or substance term; .pt publication type.

* Note: numbers may not tally as some articles are excluded in more than one category.

** After removal of 213 citations duplicated in PubMed, 360 unique citations retained for review

Table A4 KQ2 search strategy and results from PubMed (pubmed.gov interface)

Search terms | | Search results
#1 | levonorgestrel/ae[mh] OR intrauterine devices, medicated/ae[mh] OR norethindrone/ae[mh] OR ethinyl estradiol/ae[mh] OR medroxyprogesterone acetate/ae[mh] OR mefenamic acid/ae[mh] OR norgestrel/ae[mh] OR genistein/ae[mh] OR dydrogesterone/ae[mh] OR tranexamic acid/ae[mh] OR ethamsylate/ae[mh] OR flurbiprofen/ae[mh] OR naproxen/ae[mh] OR indomethacin/ae[mh] OR metformin/ae[mh] OR progesterone/ae[mh:noexp] OR contraceptives, oral, combined/ae[mh:noexp] OR anti-inflammatory agents, non-steroidal/ae[mh:noexp] OR ((ferric carboxymaltose[supplementary concept] OR ferrous sulfate[supplementary concept] OR exenatide[supplementary concept] OR norgestimate, ethinyl estradiol drug combination[supplementary concept] OR estradiol Valerate, dienogest drug combination[nm] OR dienogest[nm]) AND ae[sh]) | 23,134
#2 | cohort studies[mh] OR product surveillance, postmarketing[mh] OR clinical trial, phase IV[pt] OR databases, factual[mh] OR adverse drug reaction reporting systems[mh] OR case control studies[mh] OR cohort[tiab] | 1,373,280
#3 | #1 AND #2 AND eng[la] AND humans[mh] AND 1980:2012[dp] | 3,142
#4 | #3 AND review[pt] | 218
#5 | #3 AND case reports[pt] | 138
#6 | #3 AND letter[pt] | 124
#7 | #3 AND comment[pt] | 84
#8 | #3 AND meta-analysis[pt] | 51
#9 | #3 AND practice guideline[pt] | 2
#10 | #3 AND editorial[pt] | 22
#11 | #3 AND biography[pt] | 1
#12 | #3 AND congresses[pt] | 2
#13 | #3 AND consensus development conference[pt] | 2
#14 | #3 AND historical article[pt] | 2
#15 | #3 AND in vitro[pt] | 4
#16 | #3 AND news[pt] | 6
#17 | #3 AND retracted publication[pt] | 2
#18 | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17) | 2,611

Key: [tiab] title/abstract word; [mh] MeSH heading; [mh:noexp] MeSH heading not exploded to narrower terms; [la] language; [pt] publication type

Table A5 KQ2 search strategy and results from PubMed (pubmed.gov interface) for update

Search terms | | Search results
#1 | intrauterine devices, medicated/ae[mh] OR medroxyprogesterone acetate/ae[mh] OR dydrogesterone/ae[mh] OR tranexamic acid/ae[mh] OR ethamsylate/ae[mh] OR metformin/ae[mh] OR progesterone/ae[mh:noexp] OR ((exenatide[supplementary concept] OR cabergoline[supplementary concept) AND ae[sh]) | 4,055^*^
#2 | cohort studies[mh] OR product surveillance, postmarketing[mh] OR clinical trial, phase IV[pt] OR databases, factual[mh] OR adverse drug reaction reporting systems[mh] OR case control studies[mh] OR cohort[tiab] | 1,410,620
#3 | #1 AND #2 AND eng[la] AND humans[mh] AND 1980:2012[dp] | 672
#4 | #3 AND review[pt] | 35
#5 | #3 AND case reports[pt] | 25
#6 | #3 AND letter[pt] | 26
#7 | #3 AND comment[pt] | 16
#8 | #3 AND meta-analysis[pt] | 6
#9 | #3 AND practice guideline[pt] | 2
#10 | #3 AND editorial[pt] | 4
#11 | #3 AND biography[pt] | 0
#12 | #3 AND congresses[pt] | 0
#13 | #3 AND consensus development conference[pt] | 0
#14 | #3 AND historical article[pt] | 2
#15 | #3 AND in vitro[pt] | 1
#16 | #3 AND news[pt] | 0
#17 | #3 AND retracted publication[pt] | 0
#18 | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17) | 576^**^

Key: [tiab] title/abstract word; [mh] MeSH heading; [mh:noexp] MeSH heading not exploded to narrower terms; [la] language; [pt] publication type

* Search Strategy for literature update for KQ2 was revised to include on only the interventions identified for KQ1

** Includes 78 new items added with June 2012 update