# Abbreviations and Acronyms

ARHQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CINAHL: Cumulative Index to Nursing and Allied Health Literature
COC: Combined oral contraceptive
g: Gram
GnRH: Gonadotropin-releasing Hormone
HRQoL-4: Health related quality of life survey-based questionnaire
IM: Intramuscular
IUD: Intrauterine device
kg: Kilogram
KQ: Key Questions
LHRH: Luteinizing Hormone-releasing Hormone
LNG-IUS: Levonorgestrel-releasing intrauterine system
MBL: Menstrual blood loss
mcg: Microgram
MeSH: Medical Subject Heading
mg: Milligram
MIQ: Menorrhagia Impact Questionnaire
mmol: Millimolar
MPA: Medroxyprogesterone acetate
N: Number
NS: Non-significant
NSAID: Nonsteroidal anti-inflammatory drug
OR: Odds ratio
PBLAC: Pictorial Blood Loss Assessment Chart
PCOS: Polycystic ovary syndrome
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Settings
RCT: Randomized Controlled Trials
RR: Relative Risk
SOE: Strength of Evidence
TEP: Technical Expert Panel
TXA: Tranexamic acid