# Results

## Results of the Search

Figure 2 summarizes the results of our search. We identified 4,217 unique citations. We excluded 3,892 citations during the abstract screening. During full-text article screening, we excluded an additional 249 articles that did not meet one or more of the inclusion criteria. (Listing of excluded studies is included in Appendix D.) Seventy-three articles were eligible for inclusion and sixty eight addressed one of the critical outcomes and are thus included in the narrative of the report. We selected four outcomes as critical to making a decision on which to focus our synthesis: prescription of asthma controller medicines, provision of asthma action plan/self-management education, ED visits/hospitalizations, and missed days of school or work. Data abstracted for all outcomes can be found in Appendix E.

Figure 2 Summary of search (number of articles)

* Total exceeds the # in the exclusion box, as reviewers did not need to agree on reason for exclusion.

** Three distinct pairs of articles described a single intervention or cohort. For the purposes of this review, each pair was counted as a single study, yielding 73 studies reported in 76 articles.

Figure 2 describes the flow of articles through the screening and review process. 4236 unique articles were identified in the search, 4166 were screened out at the title-abstract level, 320 were screened out at the article level, 244 were excluded on full text review and 72 articles were included in the report.

## Description of Types of Studies

Of the 73 studies identified, 38 (52.1 percent) were based in the U.S. and 35 (47.9 percent) were international (Table 7). Studies were classified by predominant intervention using the process described in the Methods, into the following groups: Decision Support (n=24), Organizational Change (n=4), Feedback and Audit (n=12), Clinical pharmacy support (n=4), Education only (n=16), Quality Improvement (n=3), Multicomponent (n=8), Information Only (n=2) (Table 3). Roughly half of the studies were randomized trials (n=34), 29 were pre-post, and the remainder were cluster-randomized (n=4), controlled pre-post (n=3), cohort (n=1). (Table 4) Most interventions targeted general practitioners (n=24) or primary healthcare providers. To a lesser extent, studies involved midlevel practitioners (nurse practitioners, physician assistants), pharmacists and different combinations of providers. The most frequently reported health care process outcome was prescription of controller medication (n=44), followed by provision of an asthma action plan (n=18), prescription of a peak flow meter (n=17), and self-management education (n=12) (Table 5). Common clinical outcomes included emergency department visits (n=30) and hospitalizations (n=27), followed by use of short-acting β2 agonists (n=9), missed school days (n=8), lung function tests (n=6), symptom days (n=6), quality of life (n=6) and urgent doctor visits (n=5) (Table 6).

Table 7 Studies stratified by setting

International vs. Domestic | Number of Studies, n (%)
U.S. | 38 (52.1)
International | 35 (47.9)

Table 3 Studies stratified by intervention

Intervention Type | Number of Studies
Decision support | 24
Organizational change | 4
Feedback and audit | 12
Clinical pharmacy support | 4
Education only | 16
Quality improvement | 3
Multicomponent | 8
Information only | 2

Table 4 Studies stratified by study design

Study Design | Number of Studies
Cluster-randomized | 4
Controlled pre-post | 3
Nonrandomized controlled | 2
Pre-post | 29
Randomized | 34
Cohort | 1

Table 5 Studies stratified by health care process outcome

Health Care Process Outcome | Number of Studies (n)
Asthma action plan | 18
Documentation of asthma control/severity | 9
Environmental control practice recommendations | 6
Followup visits | 8
Prescription of peak flow meter | 17
Prescriptions for controller medicine | 44
Proportion of patients on inhaled corticosteroids | 1
Self-management education | 12
Nonurgent care asthma visit | 1

Table 6 Studies stratified by clinical outcome

Health Care Clinical Outcome | Number of Studies (n)
Emergency department visits | 30
Hospitalizations | 27
Lung function tests | 6
Missed days of school | 8
Missed days of work | 4
Parental/patient perceptions | 2
Quality of life | 6
Use of short-acting β_2_ agonists | 9
Symptom days | 6
Symptom score | 3
Urgent doctor visits | 5

## Organization of Results

The results are organized according to each KQ, the four critical outcomes (prescription of asthma controller medicines, provision of asthma action plan/self-management education, ED visits/hospitalizations, and missed days of school or work) and each type of intervention. For each KQ, a description and summary of the key findings from each type of intervention are presented, along with a table summarizing the strength of evidence.

### KQ1 In the care of pediatric or adult patients with asthma, what is the evidence that interventions designed to improve health care provider adherence to guidelines impact health care process outcomes (e.g., receiving appropriate treatment)?

#### Outcome: Prescription of Controller Medicines

##### Key Points and Evidence Grades

- There is moderate evidence for the effectiveness of decision support interventions to increase prescribing of asthma controller medicines by health care providers. Most of the evidence supporting the use of decision support interventions comes from nonrandomized studies.
- Low strength of evidence supports the effectiveness of organizational change to increase the prescribing of asthma controller medicines by health care providers.
- There is moderate evidence to support feedback/audit interventions as an effective means to increase prescribing of asthma controller medications. Most feedback and audit interventions were multifaceted, limiting our ability to discern whether the feedback and audit component was effective in increasing controller medication prescribing by practitioners.
- There is moderate evidence that clinical pharmacy support interventions increase prescribing of asthma controller medications.
- Low evidence suggests that education interventions do not increase prescription of asthma controller medications by clinicians.
- No studies examined the effect of quality improvement strategies on prescription of asthma controller medications.
- Low strength of evidence supports the effectiveness of multicomponent interventions to increase the prescribing of asthma controller medicines by health care providers.
- There is insufficient evidence to determine if information alone is effective in improving rates of asthma controller medication prescribing in asthma.

##### Decision Support

Fifteen studies of decision support interventions evaluated prescription of asthma controller medications as an outcome. These studies included six RCTs33-38 and nine pre-post studies.39-47 The control condition for the RCTs was usual care33,35,36,38 or the provision of decision support for nonasthma conditions.34,37The health care provider participants all worked in primary care settings (i.e., no allergists, pulmonologists or other sub-specialists). Most studies did not focus the intervention on one type of health care provider, but involved a combination of physicians, nurse practitioners/physician assistants and other nonphysician employees.40,42,44,46 A minority of studies involved pediatric health care providers.35,39,44 With few exceptions, there was little description of the patient populations by race/ethnicity,35,38,44 gender,35,40,44,47 or disease severity/control.39,47 The reported racial/ethnic make-up in those studies providing such data reported that a majority of patients cared for as African American, Latino and/or requiring public health insurance.35,38,39,44,46-48

The types of decision support interventions varied, and included the provision of asthma guidelines in a more accessible format (e.g., “pocket” versions),36,43,45 use of a specific algorithm, pathway or flow sheet,36,44-46 a structured template for taking a history,39,40or a reminder system to raise awareness of the health care provider about the patient's asthma status.34,35,41 The decision support interventions were often combined with other strategies, including education,33,36-38,41,46,48,49 reminders,34,38-40,43 feedback,35,43 and/or organizational change.42 A minority of interventions were computer-based.34,37,38,41,43,47,50

Ten studies found that a decision support intervention significantly increased prescribing asthma controller medicines by health care providers,33,35,38-41,43,44,46,47 while the remaining studies did not.34,36,37,42,45 Eight of the studies in which increased prescribing was observed used a pre-post study design, while 3 of the 5 RCTs observed no benefit from decision support interventions.34,36,37 The increase in prescribing of controller medicines ranged from 2 percent to 34 percent in the studies using the pre-post design, while the difference between intervention and control conditions in the RCT studies ranged from 2 percent to17 percent. The absolute difference in increased prescribing observed in the RCT studies was generally less than 10 percent. The impact of these decision support interventions to increase the prescribing of controller medicines by health care providers was modest and was observed primarily in pre-post study designs and not as consistently in RCT studies (Table 10).

Table 10 Study characteristics for health care process outcomes

Intervention | Author, Year | Study Design | Type of Provider | No. of Providers | No. of Patients | Health Care Process Outcomes
Intervention | Author, Year | Study Design | Type of Provider | No. of Providers | No. of Patients | Prescription for Controller Medicines | Self-Management Education/Asthma Action Plan
Education Only | Mahi-Taright S., 2004^74^ | Pre-post | General Practitioner | 50 | 49 | ∅ | N/A
Education Only | Cowie R. L., 2001^75^ | Pre-post | NR | NR | Arm A (Basic Education): NR Arm (Intermediate Education): NR Arm C (Intensive Education): NR | ∅ | N/A
Education Only | Davis R. S., 2004^76^ | Pre-post | Primary Healthcare | 20 | NR | ↑ | N/A
Education Only | Blackstien-Hirsch P., 2000^77^ | Pre-post | Physician | 59 | 195 | ∅ | N/A
Education Only | Shah S., 2011^68^ | RCT | General Practitioner | 150 | Arm A (control):107 Arm B: (PACE):110 | ↑ | ↑
Education Only | Smeele I. J., 1999^69^ | RCT | General Practitioner | Arm A (Control):17 Arm B (Education):17 | Arm A (Control):223 Arm B (Education):210 | ∅ | N/A
Education Only | Brown R, 2004^70^ | RCT | Pediatrician | Arm A(Control):11 Arm B(Education):12 | Arm A(Control):122 Arm B(Education):157 | ∅ | ∅
Education Only | Clark NM, 1998^71^ | RCT | Pediatrician,Physician | Arm A:37 Arm B(Education):37 | 637 | ↑ | ↑
Education Only | Stergachis A, 2002^72^ | RCT | Pharmacist | Arm A(Control):NR Arm B(Education):35 | Arm A(Control):177 Arm B(Education):153 | ∅ | N/A
Education Only | Premaratne U. N., 1999^73^ | RCT | Nurse practice nurses | NR | Arm A(control):14410 Arm B(Education):9900 | ∅ | N/A
Education Only | Holton C., 2011^92^ | RCT | General Practitioner | Arm A(Control):45 Arm B( Spirometry training):127 | Arm A(Control):157 Arm B( Spirometry training):240 | N/A | ∅
Education Only | Sulaiman N. D., 2010^93^ | RCT | General Practitioner | Arm A(Control):18 Arm B(Education and guidelines):18 Arm C(Guidelines): 15 | Arm A( Control):121 Arm B(Education and guidelines):156 Arm C(Guidelines):134 | N/A | ∅
Decision Support | Bell, 2010^38^ | RCT | Pediatrician | NR | Arm A (UP control): 5192 Arm B (UP intervention): 5040 Arm C (SP control): 3843 Arm D (up control): 5375 | ↑ | ∅
Decision Support | Cho, S.H., 2010^41^ | Pre-post | Allergist, general practitioner, physician | 377 | 2042 | ↑ | N/A
Decision Support | Cloutier M.M., 2002^46^ | Pre-post | Nurse, nurse practitioner, other, pediatrician, physician, physician assistant advanced practice nurses, family practice | 172 | 860 | ↑ | N/A
Decision Support | Cloutier M.M.,2005^44^ | Pre-post | Nurse, nurse practitioner, pediatrician, physician assistant, primary health care pediatric residents, medical students | 151 | 3748 | ↑ | N/A
Decision Support | Davis A.M., 2010^47^ | Pre-post | Physician family medicine residents | NR | 180 | ↑ | N/A
Decision Support | Eccles M, 2002^37^ | RCT | General practitioner | NR | Arm A (angina): 4851 Arm B (asthma): 4960 | ∅ | ∅
Decision Support | Fairall L., 2010^33^ | RCT | Nurse | 148 | Arm B (intervention): 1000 | ↑ | N/A
Decision Support | Halterman J.S., 2006^87^ | RCT | Nurse practitioner, pediatrician, physician | NR | Arm A (control): 124 Arm B (intervention): 122 | N/A | ↑
Decision Support | Horswell R.,2008^43^ | Pre-post | Physician | NR | NR | ↑ | N/A
Decision Support | Kattan M,, 2006^35^ | RCT | Nurse practitioner, physician assistant, primary healthcare | Arm A (standard practice): NR Arm B (decision support): 435 | Arm A (standard practice): 466 Arm B (decision support): 471 | ↑ | N/A
Decision Support | Lesho EP, 2005^45^ | Pre-post | Primary healthcare | NR | 330 | ∅ | ↑
Decision Support | Martens J.D.,2007^34^ | RCT | General practitioner | Arm A (Control): 54 Arm B (Guidelines and involved in development): 53 | Arm A: 24,160 Arm B: 35,748 | ∅ | N/A
Decision Support | McCowan C., 2001^89^ | RCT | General practitioner | NR | Arm A (control): 330 Arm B (decision support): 147 | N/A | ∅
Decision Support | Mitchell E.A.,2005^36^ | RCT | General practitioner | 270 | NR | ∅ | N/A
Decision Support | Newton W.P., 2010 42 | Pre-post | Nurse, physician practice managers, other staff | NR | NR | ∅ | ↑
Decision Support | Ragazzi H., 2011^49^ | Pre-post | Nurse, pediatrician | Practices 1 and 2: 26-28 Practice 3: NR | Practice 1: 17 Practice 2: 26 | N/A | ↑
Decision Support | Rance K., 2011^39^ | Pre-post | Nurse practitioner, pediatrician | 4 | 41 | ↑
Decision Support | Ruoff G., 2002^88^ | Pre-post | Family physicians | 17 | 122 | N/A | ↑
Decision Support | Shapiro A., 2011^40^ | Pre-post | Nurse, physician | 25 | Arm B (SBHC): 200 Arm C (NYCHP): 197 | ↑ | N/A
Decision Support | Shiffman R.N., 2000^50^ | Pre-post | Pediatrician | 11 | Arm A (Sole physician arm; patient arm, pre): 91 Arm B (patient arm): 74 | ∅ | N/A
Decision Support | To T., 2008^86^ | Pre-post | Primary healthcare | NR | 1408 | N/A | ↑
Feedback and Audit | Veninga CCM, 1999^53^ | RCT | General Practitioner | Arm A (Netherlands):181 Arm B ( Sweden):204 Arm C (Norway):199 Arm D (Slovakia):81 | NR | ↑ | N/A
Feedback and Audit | Sondergaard J., 2002^54^ | RCT | General Practitioner | Arm A (control): 141 Arm B (Individual patient count data feedback):77 Arm C (Aggregate data feedback):74 | 6437 | ∅ | N/A
Feedback and Audit | Baker R., 2003^55^ | RCT | General Practitioner | Arm A (Guidelines only):27 Arm B (Guidelines with audit criteria):27 Arm C (Guidelines with audit criteria and feedback):27 | Arm A (Guidelines only):483 Arm B (Guidelines with audit criteria):510 Arm C (Guidelines with audit criteria and feedback):489 | ↑ | ∅
Feedback and Audit | Feder G, 1995^56^ | RCT | General Practitioner | NR | Arm A (Diabetes Education):NR Arm B (Education, Reminders and Audit):NR | ↑ | ↑
Feedback and Audit | Schneider A., 2008^57^ | RCT | General Practitioner | 96 | Arm A (traditional quality circle):NR Arm B (benchmark quality circle):NR Arm C (combined arms):256 | ∅ | ↑
Feedback and Audit | Veninga CCM, 2000^58^ | RCT | General Practitioner | Arm A (UTI):91 Arm B (Education and Feedback):90 | Arm A (UTI):NR Arm B(Education and Feedback):NR | ↑ | N/A
Feedback and Audit | Coleman C. I., 2003^60^ | Pre-post | Pharmacist Prescriber | NR | Arm A (Patient specific information: Prescribers with patients on ‘high dose’):510 Arm B (Patient specific information: Prescribers with patients on ‘low dose’):135 | ∅ | ↑
Feedback and Audit | Suh D. C., 2001^61^ | Pre-post | NR | NR | Arm A: (566) Arm B(Feedback):1050 | ↑ | N/A
Feedback and Audit | Richman M. J, 2000^62^ | Pre-post | Pediatrician | 29 | 228 | N/A | ↑
Feedback and Audit | Herborg H., 2001^63^ | Non-RCT | General Practitioner, Other, Pharmacist Pharmacy assistant | Arm A (Control):64 Arm B (TOM):75 | NR | ↑ | N/A
Feedback and Audit | Hoskins G., 1997^59^ | Pre-post | General practitioner | 91 | Before intervention: 782 Education and feedback intervention: 669 | N/A | N/A
Clinical Pharmacy Support | Armour C., 2007^65^ | RCT | Pharmacist | Arm A (control): 25 Arm B (PACP): 32 | Arm A (Control): 186 Arm B (PACP): 165 | ↑ | ↑
Clinical Pharmacy Support | De Vries, 2010^66^ | Nonrandomized pre-post | Arm A: General practitioner Arm B: General practitioner, pharmacists Arm C: General practitioner, pharmacists, pediatrictian | 9 | Arm A (control): 3527 Arm B (feedback): 1447 | ↑ | N/A
Clinical Pharmacy Support | Saini B, 2004^67^ | Pre-post | Arm A: General practitioner, pharmacist Arm B: pharmacist Arm C: pharmacist | Arm A (Control 1): 13 Arm B (Control 2):12 Arm C (Education): NR | Arm A (Control 1): 22 Arm B (Control 2):28 Arm C (Education): 52 | ↑ | N/A
Information Only | Martens J. D., 2006^84^ | RCT | General Practitioner | Arm A (Control):54 Arm B (Guidelines and involved in development):53 Arm C (Guidelines only):26 | NR | ↓ | N/A
Information Only | Bryce FP, 1995^85^ | RCT | General Practitioner, Nurse | NR | Arm A (Control):1563 Arm B (Reminders and Tools):1585 | ∅ | N/A
Organizational Change | Finkelstein J. A., 2005^51^ | RCT | Pediatric medical provider | 228 | Arm A (Control):1531 Arm B (PLE Intervention):2003 Arm C (Planned Care Intervention):1635 | ∅ | N/A
Organizational Change | Thyne S.M., 2007^52^ | Pre-post | Pediatric medical providers,” “urgent care clinicians” | NR | Arm A (Time 1, 2002-2003):NR Arm B (Time 2, 2003-2004):NR Arm C (Time 3, 2004-2005):NR | ↑ | N/A
Organizational Change | Glasgow N. J., 2003^90^ | RCT | General Practitioner | Arm A (Control):12 Arm B (Intervention):12 | Arm A (Control ):73 Arm B (Intervention ):101 | N/A | ↑
Organizational Change | Patel P. H., 2004^91^ | Pre-post | Physicians, Nurses | NR | 451 | N/A | ↑
Quality Improvement | Fox P., 2007^94^ | Pre-post | Nurse, Nurse Practitioner, Physician caregivers, administrative staff | NR | Chart review sample :280 Interview sample :405 | N/A | ↑
Quality Improvement | Mangione-Smith R., 2005^95^ | Pre-post | “Health care providers” | NR | Arm A (Control):126 Arm B (Learning collaborative):385 | N/A | ↑
Quality Improvement | Homer CJ, 2005^96^ | RCT | Nurse, Physician Front office staff | NR | Arm A (Control):337 Arm B( Learning collaborative):294 | N/A | ∅
Multicomponent | Bender B. G., 2011^78^ | Pre-post | Nurse, Physician, Physician Assistant Medical assistants, practice managers, office staff | 372 | 15508 | ↑ | ↑
Multicomponent | Hagmolen, W., 2008^79^ | RCT | General Practitioner | Arm A (Guidelines only):34 Arm B (Education and Guidelines):34 Arm C (Education and Guidelines and individualized treatment advice):38 | Arm A (Guidelines only):98 Arm B (Education and Guidelines):133 Arm C (Education and Guidelines and individualized treatment advice):131 | ↑ | N/A
Multicomponent | Daniels E. C., 2005^80^ | RCT | General Practitioner, Internist, Nurse Practitioner, Pediatrician, Physician, Physician Assistant staff | 163 | Arm A(Control): 136079 Arm B(Education): 90555 | ∅ | ∅
Multicomponent | Lundborg C. S., 1999^81^ | RCT | General Practitioner | Arm A (Control ):104 Arm B (Education and Feedback):100 | Arm A (Control):1333 Arm B (Education and Feedback):1121 | ∅ | N/A
Multicomponent | Yawn BP, 2008^64^ | Pre-post | Nurse Practitioner, Physician, Physician Assistant | Education and Feedback: 211 | Education and Feedback: 840 | ↑ | ↑
Multicomponent | Frankowski B. L., 2006^97^ | Pre-post | Nurse, Pediatrician, Primary Healthcare | NR | Education and Feedback: 150 | N/A | ↑

N/A = not applicable; NR = not reported; PACE = Physician Asthma Care Education; RCT = randomized controlled trial

↑ — Statistically significant increase in outcome of interest.

↓ — Statistically significant decrease in outcome of interest.

∅ — Difference between intervention and control groups or between pre- and post-intervention not statistically significant.

In summary, moderate evidence supports the use of decision support interventions to increase prescribing of asthma controller medications (Table 8).

Table 8 Prescriptions for controller medications—strength of evidence for KQ1

Intervention | No. of Studies/No. Of Health Care Providers | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence (SOE) & Magnitude of Effect (MOE)
Decision support | 15/1,635 6 RCTs,9 pre-post | Medium | Consistent | Direct | Precise | SOE: Moderate MOE: Large: 2%-34% in pre-post studies; 2%-17% in RCTs
Organizational change | 2/228 1RCT, 1 pre-post | Medium | Consistent | Direct | Precise | SOE: Low MOE: Small: In the RCT: 8%-16% for all asthma patients; 4%-11% among patients with persistent asthma; 4%-9% for inhaled steroids (ICS) for all asthma patients; 13%-19% for ICS for patients with persistent asthma. In the pre-post study: 12% increase in ICS
Feedback and audit | 11/1,831 6 RCTs, 4 pre-post and 1 nonrandomized controlled | Medium | Consistent | Direct | Imprecise | SOE: Moderate MOE: Moderate Effect size: 0.12-0.66. Percent increase in patients treated with ICS: 15.9% feedback vs. 11% review guideline and 0% guideline only. Pre-post studies of therapeutic outcomes monitoring or a mailed fact sheet + pharmacy profile feedback study increased ICS prescribing: 52-104%, Hazard ratio range: 0.77-1.08
Clinical Pharmacy Support | 3/91 1 RCT, 1pre-post, 1 non randomized | Medium | Consistent | Direct | Precise | SOE: Moderate MOE: Moderate OR: 3.80 (95% CI: 1.4, 10.32) Percent increase in patients prescribed controller meds pre and post: 6-21%.
Education only | 10/ 451 6RCTs, 4 pre-post | Medium | Consistent | Direct | Imprecise | SOE: Low MOE: Small to large in studies: 3.5-50.3% increase in prescribing controller medicines [no benefit].
Quality improvement and Pay-for-performance | 0 | | | | | SOE: Insufficient MOE: N/A
Multicomponent interventions | 7/ >1141 4 Cluster randomized, 3 pre-post | High | Consistent | Direct | Imprecise | SOE: Low MOE: Moderate. Of 7 studies, only two pre-post studies and one RCT reported significant increases in prescribing of controller medicines (25%-49% in pre-post study; small positive MOE in RCT). Other effects were null.
Information Only | 2/107, 1 RCT, 1 quasi-experimental | High | Inconsistent | Direct | Imprecise | SOE: Insufficient

MOE = magnitude of evidence; RCT = randomized controlled trial; SOE = strength of evidence

##### Organizational Change

Two studies51,52 examined the impact of organizational change on the prescribing of asthma controller medications by health care providers. One study was an RCT,51 while the other was a pre-post study.52 Both studies included pediatric health care providers. Both studies utilized the addition of personnel to facilitate organizational change. The former study used an asthma nurse educator,51 while the latter study used a community health worker.52 Both studies also incorporated provider education as part of the organizational change intervention. The two studies reported beneficial effects on the prescribing practices of health care providers. The former study51 found that neither the peer-led education arm nor the planned care intervention (utilizing an asthma nurse educator) arms resulted in a statistically significantly higher proportion of prescriptions for inhaled steroids or asthma controller medications compared with the control arm of the study. Notably, prescribing improved in all arms of the study, including the control arm. The improvement in prescribing any type of controller medications ranged from 8 to16 percent among all patients with asthma and 4 to 11 percent among asthma patients with persistent asthma. For inhaled steroids, the ranges of improved prescribing were 4 to 9 percent and 13 to 19 percent, respectively. In the pre-post study, the investigators52 observed a 12 percent increase (an absolute change from 44 percent to 56 percent) in prescriptions for inhaled steroids among all asthma patients. The effect of organizational change on increasing prescribing asthma controller medications ranges from small to moderate in the two eligible studies reviewed (Table 10).

In summary, a low strength of evidence supports the effectiveness of organizational change in increasing the prescribing of asthma controller medicines (Table 8).

##### Feedback and Audit

We identified six RCTs53-58 and four pre-post studies59-62 and one nonrandomized controlled study63 evaluating the effect of feedback and audit on prescribing controller medications. Most feedback and audit studies were conducted in Europe53-59,63 or the U.S.60-62,64 Clinicians included primarily general practitioners53-59 along with primary care physicians57,62 unidentified prescribers,60pharmacists,63 and pharmacist and physicians61. No studies addressed specialty care such as allergy, pediatrics or pulmonary medicine. There was little description of the clinician populations by race/ethnicity, gender, or years of experience.

Most feedback and audit interventions were combined with another intervention; 7 included provider education,53,56,58-62 one included prioritized review criteria for audit,55 two included benchmarking or comparison with peers or other practices55,57 and one included pharmacy monitoring of fill data and feedback to providers as part of a therapeutic outcomes monitoring (TOM) intervention, in which pharmacists also provided counseling and medication monitoring to patients.63 For each of these studies, however the feedback and audit component was the predominant provider intervention. Comparison groups included feedback unrelated to asthma, control groups located in another community/country, or pre-post comparisons. Implementation many of the interventions appeared complex and may potentially influence the effectiveness of the interventions.

Of the six RCTs53-58four demonstrated positive effects of the intervention53,55,56,58. Increased prescribing of asthma controller medicines was reported for audit and feedback interventions using targeted key guideline messages about the inflammatory nature of asthma (such as, “use inhaled corticosteroids promptly, treat severe exacerbations with oral corticosteroids”) (5 percent to 12 percent increase from baseline, p=0.05),53 prioritized guideline review criteria on single card,55 medical record prompts for annual review of asthma management with guideline prompts,56 and individualized feedback on prescribing and decision strategies.58 The two RCTs reporting no increase in prescribing of asthma controller medications involved feedback of prescribing data54 and a trial of performance feedback.57 Of the studies using a pre-post design and a nonrandomized controlled design, two studies reported an increase in prescribing of controller medicines ranging from 52 to 104 percent.61,63 No significant increase was observed in an RCT of unsolicited mailed prescriber feedback of individual patient pharmacy count data (Incidence Rate 0.013 [95% CI: 0.01, 0.017]) versus group practice aggregate prescribing data (Incidence Rate 0.014 [95% CI: 0.01, 0.018]) as compared with controls who received feedback regarding another disease (Incidence Rate 0.018 [95% CI: 0.015,0.021]).54 No significant increase in prescribing of controller medications was also noted in an RCT comparing a traditional quality circle (TQC) intervention, in which providers were given feedback on their individual performance and the aggregate performance of group providers, with a benchmark quality circle (BQC) intervention, in which feedback on providers' individual performance was explicitly compared with a performance benchmark (the highest-performing 10 percent of providers in the benchmark arm).57

In a pre-post study of a physician education and mailed asthma management fact sheet + patient pharmacy profile for patients with short-acting bronchodilator over use or no anti-inflammatory medication use demonstrated a strong positive effect (Mean difference in number of long-acting controllers over 9 months: Intermittent asthma: 0.37 (95% CI: 0.25,0.47, p<0.001; Persistent asthma: -0.29 (95% CI: -0.47, -0.12, p=0.009).61 Yet, a mailed educational and feedback of specific patient pharmacy profile with copy of guidelines showed no effect on inhaled corticoid steroid fills post intervention, despite targeting patients with poorly controlled asthma, i.e. high short acting beta agonist users.60

The magnitude of effect for feedback and audit support on prescribing controller medications is moderate based on evidence presented in 4 of the 6 RCTs with positive effect sizes and a significant increase in the percent of patients prescribed or record of use noted for a controller medication before and after interventions. The positive effect sizes, measured as an increase in patients on inhaled corticosteroids from baseline to outcome and between intervention and control groups, ranged from a low effect size of 0.12 (relative effect size defined as [Int _outcome_ − Int _baseline]_/ Int _baseline_] − [(Control _outcome_ −Control _baseline_)/Control _baseline_]58 to a moderate effect size of 0.66 (standard effect size defined as [(Int _outcome_ − Int _baseline_) − (Control _outcome_ − Control _baseline_)]/pooled standard deviation). A significant increase in the change of percentage of patients treated with inhaled steroid from baseline to 12 months post intervention between three groups (guidelines alone, prioritized guideline review criteria and review criteria plus feedback on actual prescribing behavior) was noted as a positive increase of 15.9 percent in controller prescribing in the review criteria plus feedback group as compared with an increase of 11percent in the review criteria only and no change (0 percent) in the guideline only group.55 A positive but nonsignificant difference (2.7 difference in proportion of patients) was noted in the proportions of patients in practice with asthma “prophylaxis” after one year as compared with practices provided with diabetes guidelines (Difference in asthma prophylaxis: 2.7 (95% CI -14.4 to 19.7).56

Two RCTs reported no effect based on low hazard ratios of 0.77 (95% CI: 0.59, 1.01) to 1.08 (95% CI: 0.90, 1.3) on prescribing asthma controller medications, in a study using a mailed prescriber feedback intervention54 and no before and after differences in percentage of patients with full adherence to guideline defined as prescribed medication consistent with guidelines was low (3.2 to 8 percent, p=0.19) between a “benchmark” group who had their prescribing behavior compared with a performance benchmark or comparison with other prescribers versus a traditional or individual feedback group who did not receive comparison with other prescribers.57 Of the five pre-post and nonrandomized controlled design studies, only two reported an increase in prescribing controller medications61,63 ranging from 52 percent to 104 percent; change in prescribing over time (52 percent change over 6 months) in a therapeutic outcomes monitoring program,63 increase of 104.4 percent in patients with intermittent asthma but a decrease of ICS by 10.8 percent in patients with persistent asthma.61 The strength of the evidence of feedback and audit support on prescribing asthma controller medications is moderate with several caveats. Factors that lessen the confidence in the results include inconsistent definitions of controller medication prescribing behavior (controller only, controller + rescue medication, and prophylaxis asthma medication), wide variation in feedback and audit intervention protocols, use of varying clinical asthma and GP guidelines over a long period (1990-2007), inconsistent follow-up periods ranging from 3-12 months, and inconsistent control in the analysis for asthma severity (Table 10).

In summary, a number of feedback/audit studies show a small to moderate increase in prescribing of controller medicines by health care providers. Most feedback/audit interventions were multifaceted, thereby limiting our ability to discern if the specific feedback/audit component was effective in increasing controller medication prescribing by health care providers. In summary, moderate evidence supports the use of feedback/audit to increase the prescribing of controller medicines (Table 8).

##### Clinical Pharmacy Support

We identified one RCT65, a nonrandomized study66 and a controlled pre-post study67 evaluating the effect of clinical pharmacy support on prescribing asthma controller medications. All interventions included a pharmacist education component. All were conducted at international sites including Australia65,67 and Netherlands.66

Clinicians in all studies were pharmacists.65-67 Only one study included clinician characteristics such as gender (control: female 56 percent, intervention: female 44 percent) and most pharmacists 35 years of age or older.65

The one RCT implemented a pharmacy care program training pharmacists in risk assessment, medication adherence and spirometry use and compared with a control group of usual care.65 Among the non-RCTs, only one intervention of a specialized asthma service by community pharmacies including seeing patients by appointment, assessing and intervening on patient medication needs and goal setting was compared with two groups of control patients was strong.67 The nonrandomized study tested a minimal intervention that encouraged pharmacists to hold meetings with local general practitioners to discuss guideline care for children with asthma.66

The one RCT reported a statistically significant increase in dispensing asthma controller and reliever medication versus reliever only medications in the intervention group when compared with controls (odds ratio 3.80 (95% CI: 1.40, 10.32, p=0.01).65 Of the two other studies, increased asthma controller medication use at 6 months follow-up was also reported in an intervention of a specialized asthma service by community pharmacies including seeing patients by appointment, assessing and intervening on patient medication needs and goal setting with the patient as compared with control patients in two control groups (Preventive medication use: control 1: 90.9 percent, control 2: 78.6 percent, intervention: 97.4 percent; p=0.04), however an analysis was not reported for comparison of control 1 with intervention group.67 The second study was of a minimal intervention, encouraged pharmacists to hold meetings with local general practitioners to discuss guideline care for children with asthma. This study reported an increase in controller medications (2.7 percent children with no use of an inhaled corticosteroid medication at 12 months, p<0.05).66

The strength of evidence that clinical pharmacy support increases prescription of asthma controller medications is moderate due to consistent and precise results, despite medium risk of bias. There was a notable lack of RCTs addressing this intervention and outcome. The one RCT evaluating the effect of clinical pharmacy support on prescribing asthma controller medications versus rescue medication for children indicated a large shift from the use of rescue medication only to rescue medication plus controller medication (OR 3.80 (95% CI: 1.40, 10.32, p=0.01).65 The evidence from this study is strong based on a large sample size (n=50 pharmacies and n=351/396 patients completing study), blinding of pharmacists and high follow-up rates (Intervention: 86 percent and Control 91 percent), yet this is the only RCT evaluating a pharmacy intervention. Two studies reported moderate effect size defined as change in percentage of patients prescribed controller medication between pre and post intervention periods (6 percent to 21 percent),66,67 However the studies either lacked a large sample size and/or reported inconsistent description of controller medication use (“no inhaled corticosteroid use while on long-acting betamimetics” or “ideal asthma medication profile was reliever + preventer + symptom controller medication”) (Table 10).

In summary, moderate evidence suggests that the use of clinical pharmacy support increases prescribing of controller medications (Table 8).

##### Education Only

Ten studies of education alone as an intervention examined prescribing asthma controller medication as an outcome, including six RCTs68-73 and four with pre-post designs.74-77 Nearly all of the studies targeted primary care physicians (GPs, FPs, pediatricians) or nurses and one recruited pharmacists.72 The education interventions were varied and included small group asthma education programs,69 structured training77 seminars (including interactive),71 and grand rounds.77 Besides delivering specific asthma content, certain interventions also emphasized more general skills, such as training in communication.68,71 The studies examined prescription of asthma controller medications, including “anti-inflammatory” medications generally, as well as specific classes such as inhaled corticosteroid, leukotriene modifiers and cromolyn. The findings from all studies were consistently in the positive direction, reporting increases in controller medicines prescribing by 3.5 percent to 50.3 percent, though statistically significant increases were reported only in 3 of the studies. Most studies were at high risk of bias and the strength of the evidence was low overall. Thus, the evidence is not sufficient to conclude that the education of health care providers would increase prescribing of controller medications. A majority of provider education intervention studies showed no significant increase in prescribing of asthma controller medicines (Table 10).

In summary, provider education does not increase the prescription of asthma controller medications. However, our confidence in this conclusion is low (low strength of evidence) (Table 8).

##### Quality Improvement and Pay-for-Performance

No studies examined the effect of quality improvement strategies on prescription of asthma controller medications. Therefore, there is insufficient evidence for this outcome (Table 8).

##### Multicomponent

Seven studies evaluated the impact of multicomponent interventions.64,78-83 All interventions included a copy of the guidelines (information) and an educational component (education); additional interventions included onsite staff to aid in reorganization of practice flow (organizational change); feedback to individual providers based on chart reviews (feedback and audit), and toolkits with materials for provider use and/or distribution by providers for patient use. Four79-81,83 were cluster-randomized controlled trials (randomizing primary care practices) and three64,78,82 were pre-post studies with no comparison group. Only two of the pre-post studies64,78 and one of the three RCTs79 found an impact of their multicomponent intervention on rates of inhaled corticosteroid prescriptions. The magnitudes of effect reported by the two pre-post studies were large (reporting a 25 percent increase and a 49 percent increase, respectively, in prescribing rates); however, these studies utilized the weakest available study design. Furthermore, one of these two studies measured this outcome via provider self-report, thus introducing a substantial risk of bias. In the single RCT reporting a statistically significant impact, the magnitude of effect was small, with investigators reporting a difference of only 0.1 puffs per day per patient between groups. Two other RCTs80,81 observed an effect in the positive direction, but the observed effect did not reach statistical significance. In both these studies, the lack of statistical significance could be attributed to a comparable increase in ICS prescribing rates in the comparison group, thus raising questions about the true impact of the intervention as reported by the two uncontrolled studies (Table 10).

In summary, there is low strength of evidence supporting the effectiveness of multicomponent interventions to increase prescribing of controller medications for asthma (Table 8).

##### Information Only

Two RCTs84,85 evaluated the provision of information to providers as the only intervention. One study was a trial in which patients were randomized to have information about asthma management and treatment guidelines inserted in their medical records for provider use.85 Individual providers thus cared for patients in both arms simultaneously. This study found no difference in rates of inhaled corticosteroid prescribing between study groups. The other study84 randomized providers to be involved in guideline development or not, prior to the distribution of the guidelines to all study providers. This study reported a decrease, rather than an increase, in inhaled corticosteroid prescribing rates that was statistically significantly larger in the intervention group than the comparison group (9 fewer prescriptions per 1000 patients in the intervention group versus 1 fewer prescription per 1000 patients in the control group, p<0.01). This was the only unintended consequence we identified from the included studies in our review (Table 10).

In summary, because of inconsistent results between only two studies, there is insufficient evidence to determine if information alone is effective in improving rates of controller medication prescribing in asthma (Table 8).

#### Outcome: Self-Management Education and Asthma Action Plans

##### Key Points and Evidence Grades

- Moderate evidence supports the effectiveness of decision support interventions to increase the provision of self-management education/asthma action plans by health care providers. Most of the evidence supporting the use of decision support interventions comes from nonrandomized studies.
- The strength of evidence is low to support organizational change to increase provision of self-management education/asthma action plans by health care providers.
- The strength of evidence is low to support audit interventions to increase the use of self-management education/asthma action plans by health care providers.
- The strength of evidence is moderate to support the use of clinical pharmacy support interventions to increase the provision of self-management education and asthma action plans.
- The strength of evidence is low to support education-only interventions to increase the use of asthma action plans.
- The strength of evidence is low to support quality improvement interventions to increase prescribing of asthma action plans/self-management education by healthcare providers.
- The strength of evidence is low to support multicomponent interventions to increase the provision of self-management education/asthma action plans by health care providers.
- There is insufficient evidence to determine if information alone is effective in improving rates of provision of self-management education and asthma action plans by health care providers.

##### Decision Support

Ten studies evaluated the impact of decision support interventions on the provision of patient education/asthma action plans.37,38,42,43,45,49,86-89 Four of the studies were RCTs,37,38,87,89 while the remainder used a pre-post study design.42,43,45,49,86,88 The interventions included computerized support,37,38,42,43,89 a flow sheet/algorithm,86,88 and/or the provision of guidelines.45 These studies all focused on primary care settings and all studies involved a mix of primary care providers, such as general practitioners,37 pediatricians,49,87 or family practitioners.88 Of the two studies that reported patient sociodemographic data,38,87 the majority of patients were African American.

Seven of these studies reported a positive effect of decision support on the provision of patient education/asthma action plans.42,43,45,49,86-88 The increase in self-management education/use of asthma action plans across these studies ranged from 14 percent to 84 percent. Of the four RCTs, only one showed a positive impact.87 An increase in the provision of asthma education/asthma action plans by health care providers was observed primarily in pre-post studies (Table 10).

In summary, moderate evidence supports the use of decision support interventions to increase the provision of asthma education/asthma action plans by health care providers(Table 9).

Table 9 Self-management education and asthma action plans—strength of evidence for KQ1

Intervention | No. of Studies/No. Of Health Care Providers | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence (SOE) & Magnitude of Effect (MOE)
Decision support | 10/122-124 4 RCTs, 6 pre-post | Medium | Consistent | Direct | Precise | SOE :Moderate MOE: Large: 14% - 84%
Organizational change | 2/24 1 RCT, 1 pre-post | Medium | Consistent | Direct | Precise | SOE: Low MOE: Moderate: 10% - 14%
Feedback and audit | 5/336 3 RCTs, 2 pre-post | Medium | Inconsistent | Direct | Imprecise | SOE: Low MOE: Low [underlined: Self-management education]: Peak Flow: difference in proportions between practice groups at follow-up range from low of 0.7 (95% CI: -15.2, 16.7) Inhaler technique education: 12.9% (95% CI: 1.9, 23.9) [underlined: Asthma Action Plans]: Increase of 7.6 % in Feedback with Benchmark (Traditional: 4.5%) [underlined: Asthma Education:] Pre to post: 133% increase.
Clinical pharmacy support | 1/ 82 1 RCT, | Low | Consistent | Direct | Imprecise | SOE: Moderate MOE: Moderate [underlined: Asthma Action Plans]: change from baseline to follow-up: 40%
Education only | 5/470 5 RCTs | High | Inconsistent | Direct | Imprecise | SOE: Low MOE: Small – moderate [underlined: Asthma Action Plans:] 10%-15% , OR/RR 1.40/1
Quality improvement and pay-for-performance | 3/63 practices (providers not reported) 1 RCT, 2 pre-post | High | Inconsistent | Direct | Precise | SOE: Low MOE: Moderate: -3-33% increase
Multicomponent interventions | 6/>937 2 RCT, 4 pre-post | High | Consistent | Direct | Imprecise | SOE: Low MOE: Moderate Pre-post studies: Positive impact on provision of Asthma action plans: 27-46% increase. RCTs: smaller effect sizes (7% of providers; RR'=1.82)
Information only | 0 | N/A | N/A | N/A | N/A | SOE: Insufficient MOE: N/A

SOE = strength of evidence; MOE = magnitude of effect; N/A = not applicable; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; RR'= relative rate

##### Organizational Change

Two studies examined how organizational change influenced the provision of patient self-management education and/or asthma action plans, one using an RCT design90 while the other used a pre-post design.91 Investigators in the pre-post study91 instituted a registry to track asthma patients and an asthma case manager, while investigators in the RCT90 restructured the clinical protocol for how asthma patients are cared for during ambulatory care encounters (“3+ visit plan”). In general, the effect of organizational changes to increase self-management education/asthma action plan use by health care providers was small. In the pre-post study, there was a 10 percent increase in documentation of patient education (p<0.001) and a 14 percent increase in documentation of home asthma action plan (p<0.001), while in the RCT, the investigators observed a 10 percent increase in asthma education (p=0.01). (Table 10)

In summary, low strength of evidence supports the use of organizational change as a method to increase the provision of self-management education/asthma action plan by health care providers (Table 9).

##### Feedback and Audit

We identified three RCTs55-57 and two pre-post studies 60,62 evaluating the effect of feedback and audit interventions on the self-management education and use of asthma action plans. Results of feedback and audit interventions for increasing use of self-management education and asthma action plans are positive. Statistically significant positive effects for recording inhaler technique were noted with an RCT of a medical record annual asthma and guideline audit with prompt intervention when compared with diabetes control group.56 A significantly higher proportion of health care providers recording inhaler technique was reported in the audit and prompting intervention group (proportion difference between intervention and diabetes control group: 12.9 percent (95% CI: 1.9 percent, 23.9 percent).56 A negative change for peak flow meter use was noted in the guideline review criteria plus feedback group (decrease 3.6 percent) . In this same study, no effect in self-management was observed55 and a minimal increase of 0.7 difference in proportion (95% CI: -15.2, 16.7) after practices received asthma guidelines.56

Asthma action plan use was significantly increased in patients exposed to a benchmarking feedback intervention or benchmarking quality circle (BCQ), i.e. comparing own prescribing performance with performance of GP who performed best in the quality circles (benchmarking), as compared with Traditional Quality circles (TQC) intervention without benchmarking and compared over time between baseline (T1) and 12 months after implementing the intervention (T2) (T1-T2: Benchmark Quality Circle: increase percent use from 6.7 to14.3 percent (7.6 point increase), Traditional Quality Circle: 6.1 to 10.6 percent (4.5 point increase), p=0.008).57

There was no reported increase in providing self-management education in a benchmarking feedback intervention.57

Among the pre-post studies, spacer use was increased in patients enrolled an intervention that involved a letter based prescriber and pharmacist educational plus prescribing feedback intervention pre and post intervention (Feedback and pharmacy education intervention: increased 6-7 percent, vs. an 8-2 percent decrease in a comparator control group that received no feedback or pharmacy education with a decrease of 8-2 percent in spacer use in a comparison group with no intervention p=0.007) and no change in peak flow meter use between groups.60 A 133 percent increase in the provision of patient asthma education was reported in a feedback intervention comparing individual primary care providers with peers and asthma education for their office staff (asthma education: baseline: 30 percent, 6 months:70 percent).62

Feedback/audit interventions increase asthma self-management education/asthma action plan use, although the amount of increase ranges is variable. The magnitude of effect for feedback and audit support to increase the provision of self-management education/asthma action plans is low based on a negative to low differences in proportions for practices recording peak flow meter use. A moderate increase was noted for inhaler technique: 12.9 (95% CI: 1.9, 23.9),56 and a small increase in change of asthma action plan use (7.6 percent) in a benchmarking feedback group (Table 10).57

In summary, a low strength of evidence support of the use of feedback and audit interventions to increase the provision of self-management education/asthma action plans by health care providers (Table 9).

##### Clinical Pharmacy Support

We identified one RCT65 evaluating the effect of clinical pharmacy support on the self-management education and asthma action plans. Patients receiving care by pharmacists enrolled in Pharmacy Asthma Care Program had increased asthma action plan noted as percent change from baseline to 6 months (asthma action plan provision mean change from baseline: 40.4 percent (95% CI: 31.9, 48.9), p=0.001, however there are no comparison data for the control group (Table 10).65

In summary, based on the one study, there is moderate evidence to support the use of clinical pharmacy interventions to increase self-management education/asthma action plan use by health care providers (Table 9).

##### Education Only

There were five RCTs of education only interventions68,70,71,92,93 that examined provision of a written asthma action plan as an outcome. Most targeted general practitioners and one focused on pediatricians, with a variety of education only strategies. The education interventions were varied and included small group asthma education programs, structured training, and interactive seminars. Two studies reported statistically significant increases in receipt of an asthma action plan, with increases of 10 percent (p=0.03)71 and 15 percent (p=0.046)68while the other three studies70,92,93 reported no significant increase (relative risk: 1.40, +1.1 percent and OR 1.00).One study examined not only whether patients were more likely to receive an asthma action plan93 but also whether the physicians in the intervention arm were more likely to report using a asthma action plan. However, in this study, no significant increase in physician report of asthma action plan was reported. These studies evaluating the use of health care provider education had mixed results in improving patient education/asthma action plan use by health care providers (Table 10).

In summary, low strength of evidence suggests that educational interventions can increase use of asthma action plans by health care providers (Table 9).

##### Quality Improvement and Pay-for-Performance

Three studies examined the effect of quality improvement strategies on receipt of asthma action plans.94-96 The design of the studies included an RCT,96 a pre-post study,94and a controlled, pre-post study.95 All three studies involved pediatric health care providers, including nurses, nurse practitioners and physicians. Two studies assessed participation in a Breakthrough Series collaborative,95,96 and one study assessed a combination of continuous quality improvement and the addition of a community health worker.94

Overall, the results are inconsistent, with a -3 percent to 33 percent change in the proportion of patients provided an asthma action plan. Two of the three studies94,95, both pre post studies, showed a 19 percent to 33 percent improvement in the proportion of patients who had received an asthma action plan. One of these studies,95 the controlled pre-post study, showed a 19 percent increase by survey and a difference of 33 percent by medical record review in the intervention arm. The second study showed a 28.2 percent increase in the proportion of patients who had received an asthma action plan. In one of the two pre-post studies, documented self-management education increased by 21 percent, although there was no definition of what constituted self-management education and how it was documented.95

The third study,96 an RCT, showed no significant improvement in the use of asthma action plans by providers, with a 1 percent increase in the intervention group and 4 percent increase in the control group for a -3 percent difference of difference.96 However, there was some evidence of poor adherence to the quality improvement intervention in the RCT, with decreases in participation in the learning sessions and in outcome reporting over time (Table 10).96

In summary, there is low strength of evidence that quality improvement leads to moderate increases the provision of self-management education/asthma action plans in select populations of health care providers, based on two positive observational studies and one negative RCT with evidence of suboptimal engagement by participants (Table 9).

##### Multicomponent

Six studies64,78,80,82,83,97 examined the impact of multicomponent interventions on rates at which providers created asthma action plans for their patients. Two studies80,83 were cluster-randomized trials of primary care practices, while the remaining four studies64,78,82,97 were pre-post studies. The interventions varied in their content, but most included an educational component. Other elements of these interventions included: (1) training in communication techniques, provision of a spirometer and training in use of spirometer78; (2) laminated posters of asthma guidelines and medications, feedback on asthma action plan use, and monthly calls from an intervention team to troubleshoot communication problems97; (3) asthma kits (peak flow meters, spacers, educational materials) and systems-level changes (flow sheets and standing medication orders)80; (4) systematic use of a patient questionnaire and an asthma management algorithm; (5) an asthma coordinator and feedback on performance as part of continuous quality improvement efforts; (6) an educational toolbox, seminars, teleconferences, mini fellowships, opinion leader visits, clinician-specific feedback, and pay for performance.83 All four pre-post studies reported a large and statistically significant positive impact on asthma action plans over time (ranging from 27 percent–46 percent of included providers, median 42 percent), but, in the absence of comparison groups, could not account for secular trends. Both RCTs reported changes in the provision of patient education/asthma action plans in a positive direction, (one reporting an increase among seven percent of providers, the other reporting a relative rate of 1.82) but neither result achieved statistical significance (Table 10).

Based on the use of weak study designs among studies observing an intervention effect, combined with the inconsistency of results among studies, there is low evidence to support the effectiveness of multicomponent interventions in increasing the provision of patient education/asthma action plans (Table 9).

##### Information Only

No studies examined the impact of information provision alone on self-management education or asthma action plans. Therefore, there is insufficient information to assess the effect of information-only strategies on self-management education/asthma action plan use by health care providers (Table 9).

### KQ2 In the care of pediatric or adult patients with asthma, what is the evidence that interventions designed to improve health care provider adherence to guidelines impact clinical outcomes (e.g., hospitalizations, patient-reported outcomes such as symptom control)?

#### Outcome: Emergency Department Visits/Hospitalization

##### Key Points and Evidence Grades

- There is moderate strength of evidence supporting the effectiveness of decision support interventions to reduce ED visits/hospitalizations. Most of the evidence supporting the use of decision support interventions comes from nonrandomized studies.
- There is low strength of evidence that organizational change does not reduce ED visits and hospitalizations for asthma.
- The strength of evidence is insufficient to support the effectiveness of feedback and audit interventions reduce ED visits and hospitalizations.
- There is insufficient evidence to evaluate the effectiveness of clinical pharmacy support interventions to reduce ED visits and hospitalizations for asthma.
- There is low strength of evidence for no benefit of clinician education to reduce hospitalization/ED visits for asthma.
- There is low strength of evidence to suggest that quality improvement does not decrease ED visits and hospitalizations.
- There is insufficient evidence to evaluate the effect of multicomponent interventions on ED visits or hospitalizations for asthma.
- There is insufficient evidence to evaluate the effect of information-only strategies on ED visits or hospitalizations for asthma.

##### Decision Support

Of the ten studies evaluating the effect of decision support on ED visits/hospitalizations, four were RCTs,35,36,89,98 while the others were pre-post studies.42,43,45,48,50,86 The decision support interventions included computer systems,42,43,50,89checklists,98 supplemental feedback protocols,35 and structured pathways/algorithms.36,48 These interventions were combined with educational interventions, organizational changes and/or reminders. The populations in these studies were a mix of adult42,43,45,86,89,98 and pediatric patients.35,36,48,50,86

Nine studies reported a reduction in ED visits or hospitalizations,35,36,42,43,45,48,50,86,98 ranging in impact from 5 percent to 60 percent (all statistically significant) among the studies using a pre-post study design. Among the RCTs, the difference between intervention and control arms ranged from 1 percent to 7 percent. One RCT reported no reduction in ED visits/hospitalizations (Table 13).89

Table 13 Study characteristics for clinical outcomes

Intervention | Author, Year | Study Design | Type of Provider | No. of Providers | No. of Patients | Clinical Outcomes
Intervention | Author, Year | Study Design | Type of Provider | No. of Providers | No. of Patients | ED Visits/Hospitalization | Missed Days of School/Work
Education Only | Cowie R. L., 2001^75^ | Pre-post | NR | NR | Arm A (Basic Education):NR Arm (Intermediate Education):NR Arm C (Intensive Education):NR | ∅ | ∅
Education Only | Blackstien-Hirsch P., 2000^77^ | Pre-post | Physician | 59 | 195 | ∅ | N/A
Education Only | Shah S., 2011^68^ | RCT | General Practitioner | 150 | Arm A (control):107 Arm B (PACE):110 | N/A | ∅
Education Only | Brown R, 2004^70^ | RCT | Pediatrician | Arm A (Control):11 Arm B (Education): 12 | Arm A (Control):122 Arm B (Education):157 | ↓^*^ | ∅
Education Only | Clark NM, 1998^71^ | RCT | Pediatrician, Physician | Arm A:37 Arm B (Education):37 | 637 | ∅ | N/A
Education Only | Stergachis A, 2002^72^ | RCT | Pharmacist | Arm A (Control):NR Arm B (Education):35 | Arm A (Control):177 Arm B (Education):153 | ∅ | ∅
Education Only | Holton C., 2011^92^ | RCT | General Practitioner | Arm A (Control):45 Arm B (Spirometry training):127 | Arm A (Control):157 Arm B (Spirometry training):240 | N/A | ∅
Education Only | Sulaiman N. D., 2010^93^ | RCT | General Practitioner | Arm A (Control):18 Arm B (Education and guidelines):18 Arm C (Guidelines):15 | Arm A (Control):121 Arm B (Education and guidelines):156 Arm C (Guidelines):134 | ∅ | N/A
Education Only | Cabana M. D., 2006^100^ | RCT | Primary Healthcare | Arm A (Control):43 Arm B (PACE):51 | Arm A (Control):452 Arm B (PACE):418 | ∅ | N/A
Decision Support | Cloutier M. M., 2009^48^ | Pre-post | Pediatrician | NR | 3298 | ↓ | N/A
Decision Support | Horswell R.,2008^43^ | Pre-post | Physician | NR | NR | ↓ | N/A
Decision Support | Kattan M, 2006^35^ | RCT | Nurse practitioner, physician assistant, primary healthcare | Arm A (standard practice): NR Arm B (decision support): 435 | Arm A (standard practice): 466 Arm B (decision support): 471 | ↓ | ∅
Decision Support | Lesho EP, 2005^45^ | Pre-post | Primary healthcare | NR | 330 | ↓ | N/A
Decision Support | McCowan C., 2001^89^ | RCT | General practitioner | NR | Arm A (control): 330 Arm B (decision support): 147 | ∅ | N/A
Decision Support | Mitchell E.A., 2005^36^ | RCT | General practitioner | 270 | NR | ↓ | N/A
Decision Support | Newton W.P., 2010^42^ | Pre-post | Nurse, physician practice managers, other staff | NR | NR | ↓ | N/A
Decision Support | Renzi P.M., 2006^98^ | RCT | Primary healthcare | NR | NR | ↓ | N/A
Decision Support | Shiffman R.N., 2000^50^ | Pre-post | Pediatrician | 11 | Arm A (Sole physician arm; patient arm, pre): 91 Arm B (patient arm): 74 | | N/A
Decision Support | To T., 2008^86^ | Pre-post | Primary health care | NR | 1408 | ↓ | ↓
Feedback and Audit | Schneider A., 2008^57^ | RCT | General Practitioner | 96 | Arm A (traditional quality circle):NR Arm B (benchmark quality circle):NR Arm C (combined arms):256 | ∅ | N/A
Feedback and Audit | Richman M. J, 2000^62^ | Pre-post | Pediatrician | 29 | 228 | ∅ | ∅
Clinical Pharmacy Support | Weinberger M, 2002^99^ | RCT | Pharmacist | NR | Arm A (control): 165 Arm B (Peak flow meter monitoring control group): 233 | ∅ | N/A
Multicomponent | Lob, 2011^82^ | Quasi-experimental (longitudinal at clinic level and cross-sectional at patient level) | Physician, nurse practitioner | NR | Longitudinal Evaluation Group – Patient-level Interview : 761 Cross-sectional Random Sample - Clinic-level Chart Review, T1: 680 Cross-sectional Random Sample - Clinic-level Chart Review, T2: 680 Cross-sectional Random Sample - Clinic-level Chart Review, T3: 680 | ↓ | N/A
Information only | Bryce FP, 1995^85^ | RCT | General Practitioner, Nurse | NR | Arm A (Control):1563 Arm B (Reminders and Tools):1585 | ∅ | N/A
Organizational Change | Finkelstein J. A., 2005^51^ | RCT | Pediatric medical provider | 228 | Arm A (Control):1531 Arm B (PLE Intervention):2003 Arm C (Planned Care Intervention):1635 | ∅ | N/A
Organizational Change | Thyne S.M., 2007^52^ | Pre-post | Pediatric medical providers,” “urgent care clinicians” | NR | Arm A (Time 1, 2002-2003):NR Arm B (Time 2, 2003-2004):NR Arm C (Time 3, 2004-2005):NR | ↓^**^ | N/A
Organizational Change | Glasgow N. J., 2003^90^ | RCT | General Practitioner | Arm A(Control):12 Arm B(Intervention):12 | Arm A (Control ):73 Arm B (Intervention ):101 | ∅ | ∅
Organizational Change | Patel P. H., 2004^91^ | Pre-post | Physicians, Nurses | NR | 451 | ↓ | N/A
Quality Improvement | Mangione-Smith R., 2005^95^ | Pre-post | “Health care providers” | NR | Arm A (Control):126 Arm B (Learning collaborative):385 | ∅ | ∅
Quality Improvement | Homer CJ, 2005^96^ | RCT | Nurse, Physician Front office staff | NR | Arm A (Control):337 Arm B (Learning collaborative):294 | ∅ | N/A

N/A = not applicable; NR = not reported; PACE = Physician Asthma Care Education; RCT = randomized controlled trial

↑ — Statistically significant increase in outcome of interest.

↓ — Statistically significant decrease in outcome of interest.

∅ — Difference between intervention and control groups, or between pre- and post-intervention not statistically significant.

* Reduction in ED visit for subgroup of low income participants only but reduction in annual rate of hospitalization for entire group.

** Reduction in ED visit but p value not reported in study.

In summary, there is moderate evidence that decision support interventions targeting health care provider adherence to guidelines reduce ED visits/hospitalizations (Table 11).

Table 11 Emergency department visits/hospitalization—strength of evidence for KQ2

Intervention | No. of Studies/No. of Health Care Providers | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence (SOE) & Magnitude of Effect (MOE)
Decision support | 10/820 4 RCTs 6 Pre-post | Medium | Consistent | Direct | Imprecise | SOE : Moderate MOE: Moderate: 5% - 60% in pre-post studies; 1% - 7% in RCTs
Organizational change | 4/252 2 RCTs, 2 pre-post | Medium | Inconsistent | Direct | Imprecise | SOE: Low MOE: Large: 41% - 54% in pre-post studies; 1% - 7% in RCTs [no benefit]
Feedback and audit | 2/125 1 RCT, 1 pre-post | Medium | Inconsistent | Direct | Precise | SOE: Insufficient MOE: N/A
Clinical pharmacy support | 1/36 1 RCT | Low | Unknown | Direct | Imprecise | SOE: Insufficient MOE: N/A
Education only | 7/343 5 RCTs, 2 pre-post | High | Inconsistent | Direct | Imprecise | SOE: Low MOE: Low [no benefit] [underlined: ED visits]: Findings included reductions and increases in ED visits. [underlined: Hospitalizations]: One study demonstrated significant decrease in hospitalizations; others showed no change or an increase (5 to 10.5%).
Quality improvement and pay-for-performance | 2/56 practices (providers not reported) 1 RCT, 1 pre-post | Medium | Consistent | Direct | Imprecise | SOE: Low MOE: Low [no benefit] [underlined: ED visits]: 5% reduction [underlined: Hospitalizations]: 2% reduction [underlined: ED visits/hospitalizations]: 0.3 increase. Neither study demonstrated significant decreases in ED visits/hospitalization.
Mutlicomponent | 1/17 clinics (providers not reported) 1 cohort | High | Unknown | Direct | Imprecise | SOE: Insufficient MOE: N/A
Information only | 1/13 1 RCT | High | Unknown | Direct | Imprecise | SOE: Insufficient MOE: N/A

ED = emergency department; N/A = not applicable; SOE = strength of evidence; MOE = magnitude of effect; RCT = randomized controlled trial

##### Organizational Change

Four studies evaluating organizational change measured the impact on patient ED visits and/or hospitalizations.51,52,90,91 Two of these were RCTs,51,90while the other two were pre-post studies.52,91 Three of the studies were focused on pediatric health care providers.51,52,90 Little specific sociodemographic information is provided about the patient populations. One of the studies restructured asthma care visits90, while the remaining three studies utilized supplemental trained personnel as part of the intervention.51,52,91 Three of the studies also incorporated an educational component provided to health care providers.51,52,91

Reductions in ED visits and/or hospitalizations were reported by both of the pre-post studies (41 percent and 54 percent, respectively, p-value <0.001 for both outcomes91 and 4 percent reduction in hospitalizations—no p-value reported52), while neither RCT (1 percent, p>0.05^51^ and 7 percent, p=0.06^90^) reported statistically significant reductions in ED/hospitalization rates compared with the control arms in the study (Table 13).

In summary, organizational change does not reduce ED visits/hospitalizations. The strength of evidence for this conclusion is low (Table 11).

##### Feedback and Audit

We identified one RCT57 and one pre-post study62 that evaluated the effect of feedback and audit on ED visits and hospitalizations. Clinicians in both studies were primary care practitioners with one study providing asthma education to unspecified office staff.62 No studies addressed specialty care such as allergy, pediatrics or pulmonary medicine. There was little description of the clinicians by race/ethnicity, gender or number of years of experience.

In the RCT57, a traditional quality circle (TQC) intervention, in which providers were given feedback on their individual performance and the aggregate performance of group providers, was compared with a benchmark quality circle (BQC) intervention in which feedback on providers' individual performance was explicitly compared with a performance benchmark (the highest-performing ten percent of providers in the benchmark arm). The pre-post study62 evaluated an intervention comparing individual primary care provider's guideline practice patterns with their peers plus providing asthma education to office staff.62 The studies were conducted in Europe57 and the U.S.62

There was a decrease in ED visits in the RCT.57 Patients whose providers participated in a benchmark quality circle (BQC) had a 6.7 point decrease in ED visits (from 17.6 percent at baseline to 10.9 percent twelve months post intervention), but this decrease was smaller than the 13.6 percent decrease seen among patients whose provider participated in a traditional quality circle (TQC) (19.7 percent at baseline to 6.1 percent [p=0.064]).57 The RCT did not report a change in hospitalizations.57 A minimal reduction in ED visits (Baseline: 82 percent, 6 months: 81 percent) or hospitalizations (Baseline: 96 percent, 6 months: 94 percent) was reported in the pre-post study (Table 13).62

In summary, no conclusions could be made because of conflicting results among a small number of studies. The strength of the evidence is insufficient to determine the effect of feedback and audit interventions on ED visits/hospitalizations (Table 11).

##### Clinical Pharmacy Support

We identified one RCT99 evaluating the effect of clinical pharmacy support on having an ED visit or hospitalizations over 12 months in adult patients with asthma. The RCT evaluated the effectiveness of a pharmaceutical care program for patients with asthma conducted at community drugstores. The three arms of the RCT included (1) a pharmaceutical care program intervention consisting of pharmacist computer alert of patient specific prescription fills + patient education materials and resources + pharmacy care support, (2) control group patients receiving peak flow meter instruction from pharmacist (PFM) and (3) a usual-care group. Patients assigned to the Pharmaceutical Care group were more likely to have an ED visit or hospitalization over 12 months as compared with PFM group: odds ratio 2.16 (95% CI: 1.76, 2.63), but no difference in ED or hospitalizations was noted when compared with the usual care control group (odds ratio 1.08; (95% CI: 0.93, 1.25) p> 0.05) (Table 13).99

In summary, there is insufficient evidence to determine the effect of clinical pharmacy support interventions on ED visits/hospitalizations due to imprecise results from a single study (Table 11).

##### Education Only

There were seven studies, 5 RCTs70-72,93,100 and 2 pre-post studies,75,77 that examined the impact of education only on ED visits and hospitalizations. One only considered ED visits.93 A variety of educational approaches were used to influence general practitioners, pediatricians and pharmacists, including interactive seminars, structured training and medical grand rounds. The findings for both ED visits and hospitalizations were mixed. For ED visits, the findings included both reduction and increase in visits. One of the studies did not find a statistically significant effect for the intervention group overall, but did report statistically significant findings in a subgroup of low income participants (-1.23 visits per year, p=.001).70 For hospitalization, one study showed significant reduction in the annual rate70 (-.02 to-.03 visits per year)while the other 5 studies showed no reduction (0 change in visit rate) or increases of rates of hospitalization (+5 to 10.5 percent) (Table 13).

In summary, education-only interventions do not reduce asthma ED visit or hospitalizations. The strength of evidence for this conclusion is low (Table 11).

##### Quality Improvement and Pay-for-Performance

One RCT96examined the effect of quality improvement on ED visits and hospitalizations and one controlled pre-post study evaluated the effect of quality improvement on the combined number of ED visits and hospitalizations.95 Both studies evaluated a Breakthrough Series collaborative quality improvement strategy. These studies focused on pediatric health care providers working in community health center settings. The patients were primarily African American or Hispanic.

Neither study showed a statistically significant reduction in ED visits/hospitalizations, with a 5 percent reduction in ED visits,96 a 2 percent reduction in hospitalizations96, and an increase of 0.3 combined ED visits and hospitalizations95 reported in the quality improvement arms. However, there was some evidence of poor adherence to the quality improvement intervention in the RCT, with decreases in participation in the learning sessions and in outcome reporting over time.96 When analyses were limited to the 9 practices that attended all three learning sessions, they report that there was a significant reduction in ED visits (Table 13).

In summary, there is low strength of evidence to suggest that quality improvement does not significantly reduce ED visits/hospitalizations based on one controlled pre-post study and one RCT with evidence of suboptimal engagement by participants (Table 11).

##### Multicomponent

One study82 evaluated the impact of a multicomponent intervention in pediatric clinics on rates of ED visits and hospitalizations. This study implemented an intervention that included elements of quality improvement, decision support, organizational change, and feedback-and-audit. It recruited a cohort of patients across 17 participating sites, and collected ED and hospitalization rates using parent recall at multiple time points. This study reported large and statistically significant reductions in rates of ED visits and hospitalizations across the overall cohort of enrolled patients (69 percent reductions for both outcomes). However, 44 percent of the patient sample was lost to follow up, and significant heterogeneity in results was seen across participating clinical sites (Table 13).

In summary the strength of evidence is insufficient to determine the effect of multicomponent interventions on ED visits and/or hospitalizations (Table 11).

##### Information Only

Only one RCT study examined the impact of information provision alone.85 The study was done in Australia and measured outcomes only in children ages 1-15.^85^ Information was inserted into the charts of patients randomized to the intervention group. However, each provider managed patients in both intervention and control arms simultaneously. This study found no differences in rates of either ED visits or hospitalizations between study groups (Table 13).

In summary, based on a single study with a high risk of bias, there is insufficient evidence to evaluate the effect of information only interventions ED visits/hospitalizations (Table 11).

#### Outcome: Missed Days of Work/School

##### Key Points and Evidence Grades

- There is insufficient evidence for the effect of decision support on the number of missed days of work/school from asthma, due to inconsistent results from two studies.
- Organizational change does not reduce missed school days from asthma. The strength of evidence for this conclusion is low.
- There is insufficient evidence for the effect of feedback and audit interventions on the number of missed work or school days due to inconsistent results in the one included study.
- There is insufficient evidence for the effect of clinical pharmacy support on the number of missed work or school days due to lack of any study addressing missed days of work and school.
- There is insufficient evidence to evaluate the effect of education only strategies on missed days of work/school from asthma due to inconsistent and imprecise results.
- There is insufficient evidence to evaluate the effect of quality improvement interventions on missed days of work/school from asthma.
- There is insufficient evidence to evaluate the effect of multicomponent interventions on missed days of work/school from asthma.
- There is insufficient evidence to evaluate the effect of provision of information to health care providers on the number of missed days of work/school from asthma.

##### Decision Support

The two studies examining the impact of decision support interventions on missed work or school had differing results. One study used an RCT design35 while the other used a pre-post design.86 Both involved children, although the pre-post study.86 also included adult patients. The RCT35 reported no reduction in missed school in their study of providing supplemental morbidity information to health care providers. The pre-post study86 reported a 49 percent reduction (p<0.001) in school absenteeism and a 51 percent reduction in the odds of missed work (odds ratio 0.49 [95% CI: 0.34, 0.71]) among the patient populations in a study that utilized a combination of an asthma care map, a treatment flow chart, program standards, management flow chart and action plan (Table 13).

In summary, there is insufficient evidence for the effect of decision support on the number of missed days due to inconsistent results from two studies (Table 12).

Table 12 Missed days of work/school—strength of evidence for KQ2

Intervention | No. of Studies/No. of Health Care Providers | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence (SOE) & Magnitude of Effect (MOE)
Decision support | 2/435 1 RCT, 1 pre-post | Medium | Inconsistent | Direct | Precise | SOE: Insufficient MOE: N/A
Organizational change | 1/24 1 RCT | Low | Unknown | Direct | Imprecise | SOE: Low MOE: N/A
Feedback and audit | 1/29 1 pre-post | High | Unknown | Indirect | Imprecise | SOE: Insufficient MOE: N/A
Clinical pharmacy support | 0 | | | | | SOE: Insufficient MOE: N/A
Education only | 5/1767 4 RCTs, 1 pre-post | High | Inconsistent | Direct | Imprecise | SOE :Insufficient MOE: N/A
Quality improvement and pay-for-performance Information only | 1/13 practices (providers not reported) 1 pre-post | High | Unknown | Direct | Imprecise | SOE: Insufficient MOE: N/A
Multicomponent | 1/17 clinics (providers not reported) 1 cohort | High | Unknown | Direct | Imprecise | SOE: Insufficient MOE: N/A
Information only | 0 | | | | | SOE: Insufficient MOE: N/A

N/A = not applicable; SOE = strength of evidence; MOE = magnitude of effect; RCT = randomized controlled trial

##### Organizational Change

One RCT of organizational change, based on restructuring the clinical protocol for how asthma patients are cared for during ambulatory care encounters (“3+ visit plan”), evaluated the impact on missed school days and observed no significant reduction.90 More specifically, at 12 months, the percentage of children who missed no school was 52 percent in the intervention group and 45 percent in the control group (odds ratio 0.8 (95% CO: 0.5 – 1.2); p=0.3) (Table 13).

In summary, organizational change does not reduce missed school days from asthma. The strength of evidence for this conclusion is low (Table 12).

##### Feedback and Audit

We identified one pre-post study62 that evaluated the effect of feedback and audit on work and school days missed. The study compared individual primary care provider's guideline practice patterns with their peers plus providing asthma education to office staff.62 In the one study, the percent reporting no school absences due to asthma in past 6 months: baseline: 49 percent; 6 months: 38percent--no p-value was reported. There was zero percent reduction in parent work days missed due to child's asthma (Table 13).

In summary, the one study that evaluated feedback/audit did not report reduction in the number of missed days of work/school. The magnitude of the effect is low. In summary, there is insufficient evidence to evaluate the effect of feedback/audit interventions on the number of missed days of school or work (Table 12).

##### Clinical Pharmacy Support

We identified no studies evaluating the effect of clinical pharmacy support on the outcome of missed days of work and school. Therefore, there is insufficient evidence to evaluate the effect of clinical pharmacy support interventions on the number of missed days of school or work (Table 12).

##### Education Only

There were five studies that evaluated the effect of health care provider education on missed school or missed work as outcomes. There were 3 RCTs68,70,72 that included children missing school as an outcome. The interventions targeted general practitioners, pediatricians and pharmacists and included structured training, seminars and workshops. In all 3 trials there was consistent evidence of small positive effects that were not of statistical significance (reductions of 4 percent and 0.6 to 3.96 days). Two RCTs68,92 and one pre-post study75 examined missed work as an outcome, including one study that had a compound outcome of missing either work or school. The interventions included workshops, training in how to perform spirometry and one study had compared asthma program development with a nurse educator program or continuing education. There were no significant reductions in missed work in any studies (ranging from -10 percent to + 5.6 percent) (Table 13).

In summary, the study results were inconsistent and had imprecise estimates of the effect of these education interventions. Therefore there is insufficient evidence to evaluate the effect of education only strategies on the number of missed days of work/school from asthma (Table 12).

##### Quality Improvement and Pay-for-Performance

One controlled pre-post study examined the effect of quality improvement on missed school and missed parental work.95 This study evaluated health care provider participation in a Breakthrough Series collaborative quality improvement strategy. This study reported a nonsignificant reduction of 0.2 school days (p=0.4) and zero parental work days missed due to a child's asthma (p=0.7) (Table 13).

In summary, with only one study at high risk of bias, there is insufficient evidence to determine the effect of quality improvement interventions on school or work absenteeism (Table 12).

##### Multicomponent

One study82 evaluated the impact of a multicomponent intervention in pediatric clinics on missed days of school in children and missed days of work in their parents. This study implemented an intervention that included elements of quality improvement, decision support, organizational change, and feedback-and-audit. It recruited a cohort of patients across 17 participating sites, and collected data on missed days of school and work using parent recall at multiple time points. This study reported large and statistically significant reductions in rates of missed days of school (53 percent reduction in patients with any missed days of school) and work (72 percent reduction in parents with any missed days of work) across the overall cohort of enrolled patients. However, 44 percent of the patient sample was lost to follow up, and significant heterogeneity in results was seen across participating clinical sites (Table 13).

In summary the strength of evidence is insufficient to determine the effect of multicomponent interventions on missed days of school or work (Table 12).

##### Information Only

No studies examined the impact of information provision alone on missed days of work or school (Table 12).

### KQ3 In the care of pediatric or adult patients with asthma, what is the evidence that interventions designed to improve health care provider adherence to guidelines impact health care process outcomes that then affect clinical outcomes?

We identified no studies providing evidence on the link between changes in health care provider behavior (health care process outcomes) to changes in clinical outcomes.