# References

1 Vital signs: asthma prevalence, disease characteristics, and self-management education: United States, 2001--2009. MMWR Morb Mortal Wkly Rep. 2011;60(17):547-52. [pmid: 21544044].
2 Expert Panel Report 3 (EPR-3): Guidelines for the Diagnosis and Management of Asthma-Summary Report 2007. J Allergy Clin Immunol. 2007;120(5 Suppl):S94-138. [pmid: 17983880].
3 Evans R, Gergen PJ, Mitchell H, et al. A randomized clinical trial to reduce asthma morbidity among inner-city children: results of the National Cooperative Inner-City Asthma Study. J Pediatr. 1999;135(3):332-8. [pmid: 10484799].
4 Sulaiman ND, Barton CA, Liaw ST, et al. Do small group workshops and locally adapted guidelines improve asthma patients' health outcomes? A cluster randomized controlled trial. Fam Pract. 2010;27(3):246-54. [pmid: 20332178].
5 Szefler SJ, Mitchell H, Sorkness CA, et al. Management of asthma based on exhaled nitric oxide in addition to guideline-based treatment for inner-city adolescents and young adults: a randomised controlled trial. Lancet. 2008;372(9643):1065-72. [pmid: 18805335].
6 Wisnivesky JP, Lorenzo J, Lyn-Cook R, et al. Barriers to adherence to asthma management guidelines among inner-city primary care providers. Ann Allergy Asthma Immunol. 2008;101(3):264-70. [pmid: 18814449].
7 Halterman JS, Aligne CA, Auinger P, et al. Inadequate therapy for asthma among children in the United States. Pediatrics. 2000;105(1 Pt 3):272-6. [pmid: 10617735].
8 Halterman JS, Yoos HL, Kaczorowski JM, et al. Providers underestimate symptom severity among urban children with asthma. Arch Pediatr Adolesc Med. 2002;156(2):141-6. [pmid: 11814375].
9 Cabana MD, Slish KK, Nan B, et al. Asking the correct questions to assess asthma symptoms. Clin Pediatr (Phila). 2005;44(4):319-25. [pmid: 15864364].
10 Cabana MD, Bruckman D, Meister K, et al. Documentation of asthma severity in pediatric outpatient clinics. Clin Pediatr (Phila). 2003;42(2):121-5. [pmid: 12659384].
11 Ortega AN, Gergen PJ, Paltiel AD, et al. Impact of site of care, race, and Hispanic ethnicity on medication use for childhood asthma. Pediatrics. 2002;109(1):E1. [pmid: 11773569].
12 Akinbami LJ, Moorman JE, Garbe PL, Sondik EJ. Status of childhood asthma in the United States, 1980-2007. Pediatrics. Suppl 3. 2009;123:S131-45. [pmid: 19221156].
13 Flores G, Snowden-Bridon C, Torres S, et al. Urban minority children with asthma: substantial morbidity, compromised quality and access to specialists, and the importance of poverty and specialty care. J Asthma. 2009;46(4):392-8. [pmid: 19484676].
14 Akinbami L. The state of childhood asthma, United States, 1980-2005. Adv Data. 2006;(381):1-24. [pmid: 17180851].
15 Cabana MD, Rand CS, Powe NR, et al. Why don't physicians follow clinical practice guidelines? A framework for improvement. JAMA. 1999;282(15):1458-65. [pmid: 10535437].
16 Bracha Y, Brottman G, Carlson A. Physicians, guidelines, and cognitive tasks. Eval Health Prof. 2011;34(3):309-35. [pmid: 21177641].
17 Rastogi D, Shetty A, Neugebauer R, et al. National Heart, Lung, and Blood Institute guidelines and asthma management practices among inner-city pediatric primary care providers. Chest. 2006;129(3):619-23. [pmid: 16537859].
18 Bhogal SK, McGillivray D, Bourbeau J, et al. Focusing the focus group: impact of the awareness of major factors contributing to non-adherence to acute paediatric asthma guidelines. J Eval Clin Pract. 2011;17(1):160-7. [pmid: 20860581].
19 Corrigan SP, Cecillon DL, Sin DD, et al. The costs of implementing the 1999 Canadian Asthma Consensus Guidelines recommendation of asthma education and spirometry for the family physician. Can Respir J. 2004;11(5):349-53. [pmid: 15332137].
20 Butz AM, Eggleston P, Huss K, et al. Children with asthma and nebulizer use: parental asthma self-care practices and beliefs. J Asthma. 2001;38(7):565-73. [pmid: 11714079].
21 Coffman JM, Cabana MD, Yelin EH. Do school-based asthma education programs improve self-management and health outcomes?. Pediatrics. 2009;124(2):729-42. [pmid: 19651589].
22 Teach SJ, Crain EF, Quint DM, et al. Improved asthma outcomes in a high-morbidity pediatric population: results of an emergency department-based randomized clinical trial. Arch Pediatr Adolesc Med. 2006;160(5):535-41. [pmid: 16651498].
23 Wise RA, Bartlett SJ, Brown ED, et al. Randomized trial of the effect of drug presentation on asthma outcomes: the American Lung Association Asthma Clinical Research Centers. J Allergy Clin Immunol. 2009;124(3):436-44. 444e1. 8. [pmid: 19632710].
24 Bratton SL, Cabana MD, Brown RW, et al. Asthma educational seminar targeting Medicaid providers. Respir Care. 2006;51(1):49-55. [pmid: 16381618].
25 Welsh EJ, Hasan M, Li P. Home-based educational interventions for children with asthma. Cochrane Database Syst Rev. 2011;(10):CD008469. [pmid: 21975783].
26 Bravata DM, Gienger AL, Holty JE, et al. Quality improvement strategies for children with asthma: a systematic review. Arch Pediatr Adolesc Med. 2009;163(6):572-81. [pmid: 19487615].
27 Bravata DM, Sundaram V, Lewis R, et al. Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies: Volume 5Asthma Care. Evidence Report/Technology Assessment No. 9. (Prepared by Stanford University Evidence-based Practice Center under Contract No. 290-02-0017). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. AHRQ Publication No. 04(07)-0051-5. 2007.
28 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.2. [updated September 2009]. The Cochrane Collaboration. 2009. Available from www.cochrane-handbook.org.
29 Cochrane Effective Practice and Organisation of Care Group. Data collection checklist. 2002. Available at http://epoc.cochrane.org/sites/epoc.cochrane.org/files/uploads/datacollectionchecklist.pdf. 2012.
30 Akinbami LJ, Sullivan SD, Campbell JD, et al. Asthma outcomes: healthcare utilization and costs. J Allergy Clin Immunol. 2012;129(3 suppl):s49-64. [pmid: 22386509].
31 Guyatt G, Oxman AD, Sultan S, et al. GRADE guidelines 11-making an overall rating of confidence in effect estimates for a single outcome and for all outcomes. J Clin Epidemiol. 2012.
32 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
33 Fairall L, Bachmann MO, Zwarenstein M, et al. Trop Med Int Health. Cost-effectiveness of educational outreach to primary care nurses to increase tuberculosis case detection and improve respiratory care: economic evaluation alongside a randomised trial. 2010;15:277-86. [pmid: 20070633].
34 Martens JD, van der Weijden T, Severens JL, et al. Effect of computer reminders on GPs' prescribing behaviour: a cluster-randomised trial. Int J Med Inform. Suppl 3. 2007;76:S403-16. [pmid: 17569575].
35 Kattan M, Crain EF, Steinbach S, et al. A randomized clinical trial of clinician feedback to improve quality of care for inner-city children with asthma. Pediatrics. 2006;117:e1095-103. [pmid: 16740812].
36 Mitchell EA, Didsbury PB, Kruithof N, et al. A randomized controlled trial of an asthma clinical pathway for children in general practice. Acta Paediatr. 2005;94:226-33. [pmid: 15981759].
37 Eccles M, McColl E, Steen N, et al. Effect of computerised evidence based guidelines on management of asthma and angina in adults in primary care: cluster randomised controlled trial. BMJ. 2002;325:941. [pmid: 12399345].
38 Bell LM, Grundmeier R, Localio R, et al. Electronic health record-based decision support to improve asthma care: a cluster-randomized trial. 2010;125:e770-7.
39 Rance K, O'Laughlen M, Ting S. Improving asthma care for African American children by increasing national asthma guideline adherence. J Pediatr Health Care. 2011;25:235-49. [pmid: 21700138].
40 Shapiro A, Gracy D, Quinones W, et al. Putting guidelines into practice: improving documentation of pediatric asthma management using a decision-making tool. Arch Pediatr Adolesc Med. 2011;165:412-8. [pmid: 21536955].
41 Cho SH, Jeong JW, Park HW, et al. Effectiveness of a computer-assisted asthma management program on physician adherence to guidelines. J Asthma. 2010;47:680-6. [pmid: 20632781].
42 Newton WP, Lefebvre A, Donahue KE, et al. Infrastructure for large-scale quality-improvement projects: early lessons from North Carolina Improving Performance in Practice. J Contin Educ Health Prof. 2010;30:106-13. [pmid: 20564712].
43 Horswell R, Butler MK, Kaiser M, et al. Disease management programs for the underserved. Dis Manag. 2008;11:145-52. [pmid: 18564026].
44 Cloutier MM, Hall CB, Wakefield DB, et al. Use of asthma guidelines by primary care providers to reduce hospitalizations and emergency department visits in poor, minority, urban children. Pediatrics. 2005;146:591-7.
45 Lesho EP, Myers CP, Ott M, et al. Do clinical practice guidelines improve processes or outcomes in primary care?. Mil Med. 2005;170:243-6. [pmid: 15828703].
46 Cloutier MM, Wakefield DB, Carlisle PS, et al. The effect of Easy Breathing on asthma management and knowledge. Arch Pediatr Adolesc Med. 2002;156:1045-51. [pmid: 12361453].
47 Davis AM, Cannon M, Ables AZ, et al. Using the electronic medical record to improve asthma severity documentation and treatment among family medicine residents. Fam Med. 2010;42:334-7. [pmid: 20455109].
48 Cloutier MM, Grosse SD, Wakefield DB, et al. The economic impact of an urban asthma management program. Am J Manag Care. 2009;15:345-51. [pmid: 19514800].
49 Ragazzi H, Keller A, Ehrensberger R, et al. Evaluation of a practice-based intervention to improve the management of pediatric asthma. J Urban Health. Suppl 1. 2011;88:38-48. [pmid: 21337050].
50 Shiffman RN, Freudigman M, Brandt CA, et al. A guideline implementation system using handheld computers for office management of asthma: effects on adherence and patient outcomes. Pediatrics. 2000;105:767-73. [pmid: 10742318].
51 Finkelstein JA, Lozano P, Fuhlbrigge AL, et al. Practice-level effects of interventions to improve asthma care in primary care settings: the Pediatric Asthma Care Patient Outcomes Research Team. Health Serv Res. 2005;40:1737-57. [pmid: 16336546].
52 Thyne SM, Marmor AK, Madden N, et al. Comprehensive asthma management for underserved children. Paediatr Perinat Epidemiol. 2007;21:29-34. [pmid: 17935573].
53 Veninga CCM, Lagerløv P, Wahlström R, et al. Evaluating an educational intervention to improve the treatment of asthma in four European countries. Am J Respir Care Med. 1999;160:1254-62.
54 Sondergaard J, Andersen M, Vach K, et al. Detailed postal feedback about prescribing to asthma patients combined with a guideline statement showed no impact: a randomised controlled trial. Eur J Clin Pharmacol. 2002;58:127-32. [pmid: 12012145].
55 Baker R, Fraser RC, Stone M, et al. Randomised controlled trial of the impact of guidelines, prioritized review criteria and feedback on implementation of recommendations for angina and asthma. Br J Gen Pract. 2003;53:284-91. [pmid: 12879828].
56 Feder G, Griffiths C, Highton C, et al. clinical guidelines introduced with practice based education improve care of asthmatic and diabetic patients? A randomised controlled trial in general practices in east London. BMJ. 1995;311:1473-8. [pmid: 8520339].
57 Schneider A, Wensing M, Biessecker K, et al. Impact of quality circles for improvement of asthma care: results of a randomized controlled trial. J Eval Clin Pract. 2008;14:185-90. [pmid: 18093108].
58 Veninga CCM, Denig P, Zwaagstra R. Journal of Clinical Epidemiology. Improving drug treatment in general practice. 2000;53:762-72. [pmid: 10941955].
59 Hoskins G, Neville RG, Smith B, et al. Does participation in distance learning and audit improve the care of patients with acute asthma attacks? The General Practitioners in Asthma Group. Health Bull (Edinb). 1997;55:150-5. [pmid: 9364102].
60 Coleman CI, Reddy P, Laster-Bradley NM, et al. Effect of practitioner education on adherence to asthma treatment guidelines. Ann Pharmacother. 2003;37:956-61. [pmid: 12841800].
61 Suh DC, Shin SK, Okpara I, et al. Impact of a targeted asthma intervention program on treatment costs in patients with asthma. Am J Manag Care. 2001;7:897-906. [pmid: 11570023].
62 Richman MJ, Poltawsky JS. Partnership for excellence in asthma care: evidence-based disease management. Stud Health Technol Inform. 2000;76:107-21. [pmid: 10947496].
63 Herborg H, Soendergaard B, Jorgensen T, et al. Improving drug therapy for patients with asthma-part 2: Use of antiasthma medications. J Am Pharm Assoc (Wash). 2001;41:551-9. [pmid: 11486981].
64 Yawn BP, Bertram S, Wollan P. Introduction of asthma APGAR tools improve asthma management in primary care practices. J Asthma Allergy. 2008:1-10. [pmid: 21436980].
65 Armour C, Bosnic-Anticevich S, Brillant M, et al. Pharmacy Asthma Care Program (PACP) improves outcomes for patients in the community. Thorax. 2007;62:496-502. [pmid: 17251316].
66 De Vries TW, van den Berg PB, Duiverman EJ, et al. Effect of a minimal pharmacy intervention on improvement of adherence to asthma guidelines. Arch Dis Child. 2010;95:302-4. [pmid: 19395402].
67 Saini B, Krass I, Armour C. Development, implementation, and evaluation of a community pharmacy-based asthma care model. Ann Pharmacother. 2004;38:1954-60. [pmid: 15479780].
68 Shah S, Sawyer SM, Toelle BG, et al. Improving paediatric asthma outcomes in primary health care: a randomised controlled trial. Med J Aust. 2011;195:405-9. [pmid: 21978349].
69 Smeele IJ, Grol RP, van Schayck CP, et al. Can small group education and peer review improve care for patients with asthma/chronic obstructive pulmonary disease?. Qual Health Care. 1999;8:92-8. [pmid: 10557684].
70 Brown R, Bratton SL, Cabana MD, Kaciroti N, Clark NM. Chest. Physician asthma education program improves outcomes for children of low-income families. 2004;126:369-74. [pmid: 15302719].
71 Clark NM, Gong M, Schork MA, et al. Impact of education for physicians on patient outcomes. Pediatrics. 1998;101(5):831-6. [pmid: 9565410].
72 Stergachis A, Gardner JS, Anderson MT, et al. Improving pediatric asthma outcomes in the community setting: does pharmaceutical care make a difference?. J Am Pharm Assoc (Wash). 2002;42:743-52. [pmid: 12269709].
73 Premaratne UN, Sterne JA, Marks GB, et al. Clustered randomised trial of an intervention to improve the management of asthma: Greenwich asthma study. BMJ. 1999;318:1251-5. [pmid: 10231256].
74 Mahi-Taright S, Belhocine M, Ait-Khaled N. Can we improve the management of chronic obstructive respiratory disease? The example of asthma in adults. Int J Tuberc Lung Dis. 2004;8:873-81. [pmid: 15260280].
75 Cowie RL, Underwood MF, Mack S. The impact of asthma management guideline dissemination on the control of asthma in the community. Can Respir J. Suppl A. 2001;8:41A-5A.
76 Davis RS, Bukstein DA, Luskin AT, et al. Changing physician prescribing patterns through problem-based learning: an interactive, teleconference case-based education program and review of problem-based learning. Ann Allergy Asthma Immunol. 2004;93:237-42. [pmid: 15478382].
77 Blackstien-Hirsch P, Anderson G, Cicutto L, et al. Implementing continuing education strategies for family physicians to enhance asthma patients' quality of life. J Asthma. 2000;37:247-57. [pmid: 10831149].
78 Bender BG, Dickinson P, Rankin A, et al. The Colorado Asthma Toolkit Program: a practice coaching intervention from the High Plains Research Network. J Am Board Fam Med. 2011;24:240-8. [pmid: 21551395].
79 Hagmolen of ten Have W, van den Berg NJ, van der Palen J, et al. Implementation of an asthma guideline for the management of childhood asthma in general practice: a randomised controlled trial. Prim Care Respir J. 2008;17:90-6. [pmid: 18274692].
80 Daniels EC, Bacon J, Denisio S, et al. Translation squared: improving asthma care for high-disparity populations through a safety net practice-based research network. J Asthma. 2005;42:499-505. [pmid: 16293546].
81 Lundborg CS, Wahlstrom R, Oke T, et al. Influencing prescribing for urinary tract infection and asthma in primary care in Sweden: a randomized controlled trial of an interactive educational intervention. J Clin Epidemiol. 1999;52:801-12. [pmid: 10465325].
82 Lob SH, Boer JH, Porter PG, et al. Promoting Best-Care Practices in Childhood Asthma: Quality Improvement in Community Health Centers. Pediatrics. 2011;128:20. Originally Published Online June 13, 2011. [doi: 10.1542/Peds.2010-1962]. [pmid: 21669890].
83 Cloutier MM, Tennen H, Wakefield DB, et al. Improving clinician self-efficacy does not increase asthma guideline use by primary care clinicians. Acad Pediatr. 2012;12(4):312-8. [pmid: 22634077].
84 Martens JD, Winkens RA, van der Weijden T, et al. Does a joint development and dissemination of multidisciplinary guidelines improve prescribing behaviour: a pre/post study with concurrent control group and a randomised trial. BMC Health Serv Res. 2006;6:145. [pmid: 17081285].
85 Bryce FP, Neville RG, Crombie IK, et al. Controlled trial of an audit facilitator in diagnosis and treatment of childhood asthma in general practice. BMJ. 1995;310:838-42. [pmid: 7711623].
86 To T, Cicutto L, Degani N, et al. Can a community evidence-based asthma care program improve clinical outcomes?: a longitudinal study. J Med Care. 2008;46:1257-66.
87 Halterman JS, Fisher S, Conn KM, et al. Improved preventive care for asthma: a randomized trial of clinician prompting in pediatric offices. Arch Pediatr Adolesc Med. 2006;160:1018-25. [pmid: 17018460].
88 Ruoff G. Effects of flow sheet implementation on physician performance in the management of asthmatic patients. Fam Med. 2002;34:514-7. [pmid: 12144005].
89 Mccowan C, Neville RG, Ricketts IW, et al. Lessons from a randomized controlled trial designed to evaluate computer decision support software to improve the management of asthma. Med InformInternet Med. 2001;26:191-201.
90 Glasgow NJ, Ponsonby AL, Yates R, et al. Proactive asthma care in childhood: general practice based randomised controlled trial. BMJ. 2003;327:659. [pmid: 14500440].
91 Patel PH, Welsh C, Foggs MB. Improved asthma outcomes using a coordinated care approach in a large medical group. Dis Manag. 2004;7:102-11. [pmid: 15228795].
92 Holton C, Crockett A, Nelson M, et al. Does spirometry training in general practice improve quality and outcomes of asthma care?. Int J Qual Health Care. 2011;23:545-53. [pmid: 21733979].
93 Sulaiman ND, Barton CA, Liaw ST, et al. Do small group workshops and locally adapted guidelines improve asthma patients' health outcomes? A cluster randomized controlled trial. Fam Practice. 2010;27:246-54.
94 Fox P, Porter PG, Lob SH, Boer JH, Rocha DA, Adelson JW. Pediatrics. Improving asthma-related health outcomes among low-income, multiethnic, school-aged children: Results of a demonstration project that combined continuous quality improvement and community health worker strategies. 2007;120:e902-e911. [pmid: 17908746].
95 Mangione-Smith R, Schonlau M, Chan KS, et al. Measuring the effectiveness of a collaborative for quality improvement in pediatric asthma care: Does implementing the chronic care model improve processes and outcomes of care?. Ambul Pediatr. 2005;5:75-82. [pmid: 15780018].
96 Homer CJ, Forbes P, Horvitz L, et al. Impact of a quality improvement program on care and outcomes for children with asthma. Arch Pediatr Adolesc Med. 2005;159:464-9. [pmid: 15867121].
97 Frankowski BL, Keating K, Rexroad A, et al. Community collaboration: concurrent physician and school nurse education and cooperation increases the use of asthma action plans. J Sch Health. 2006;76:303-6. [pmid: 16918860].
98 Renzi PM, Ghezzo H, Goulet S, Dorval E, Thivierge RL. Paper stamp checklist tool enhances asthma guidelines knowledge and implementation by primary care physicians. Can Respir J. 2006;13:193-7. [pmid: 16779463].
99 Weinberger M, Murray MD, Marrero DG, et al. Effectiveness of pharmacist care for patients with reactive airways disease: A randomized controlled trial. JAMA. 2002;288:1594-602. [pmid: 12350190].
100 Cabana MD, Slish KK, Evans D, et al. Impact of physician asthma care education on patient outcomes. Pediatrics. 2006;117:2149-57. [pmid: 16740859].
101 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58(9):894-901. [pmid: 16085192].
102 Viswanathan M, Golin CE, Jones CD, et al. Medication Adherence Interventions: Comparative Effectiveness. Closing the Quality Gap: Revisiting the State of the Science. Evidence Report No. 208. (Prepared by RTI internationaluniversity of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-E010-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2012.
103 Akl EA, Sackett K, Pretorius R, et al. Educational games for health professionals. Cochrane Database Syst Rev. 2008;(1):CD006411. [pmid: 18254103].
104 Forsetlund L, Bjorndal A, Rashidian A, et al. Continuing education meetings and workshops: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2009;(2):CD003030. [pmid: 19370580].
105 Farmer AP, Legare F, Turcot L, et al. Printed educational materials: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2008;(3):CD004398. [pmid: 18646106].
106 Thomson O'Brien MA, Oxman AD, Davis DA, et al. Educational outreach visits: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2000;(2):CD000409. [pmid: 10796542].
107 Reeves S, Zwarenstein M, Goldman J, et al. Interprofessional education: effects on professional practice and health care outcomes. Cochrane Database Syst Rev. 2008;(1):CD002213. [pmid: 18254002].
108 Gosden T, Forland F, Kristiansen IS, et al. Capitation, salary, fee-for-service and mixed systems of payment: effects on the behaviour of primary care physicians. Cochrane Database Syst Rev. 2000;(3):CD002215. [pmid: 10908531].
109 Scott A, Sivey P, Ait Ouakrim D, et al. The effect of financial incentives on the quality of health care provided by primary care physicians. Cochrane Database Syst Rev. 2011;(9):CD008451. [pmid: 21901722].
110 Sturm H, Austvoll-Dahlgren A, Aaserud M, et al. Pharmaceutical policies: effects of financial incentives for prescribers. Cochrane Database Syst Rev. 2007;(3):CD006731. [pmid: 17636851].
111 Durieux P, Trinquart L, Colombet I, et al. Computerized advice on drug dosage to improve prescribing practice. Cochrane Database Syst Rev. 2008;(3):CD002894. [pmid: 18646085].
112 Shojania KG, Jennings A, Mayhew A, et al. The effects of on-screen, point of care computer reminders on processes and outcomes of care. Cochrane Database Syst Rev. 2009;(3):CD001096. [pmid: 19588323].
113 Ivers N, Jamtvedt G, Flottorp S, et al. Audit and feedback: effects on professional practice and healthcare outcomes. Cochrane Database Syst Rev. 2012;6:CD000259. [pmid: 22696318].
114 Flodgren G, Pomey MP, Taber SA, Eccles MP. Effectiveness of external inspection of compliance with standards in improving healthcare organisation behaviour, healthcare professional behaviour or patient outcomes. Cochrane Database Syst Rev. 2011;(11):CD008992. [pmid: 22071861].
115 Ables AZ, Godenick MT, Lipsitz SR. Improving family practice residents' compliance with asthma practice guidelines. Fam Med. 2002;34:23-8. [pmid: 11838523].
116 Baker R, Fraser RC, Stone M. Evidence-based guidelines, prioritised review criteria and feedback have no effect on adherence to care recommendations for angina and asthma. Evidence-Based Healthcare. 7(3):157-8.
117 Foster JM, Hoskins G, Smith B, et al. Practice development plans to improve the primary care management of acute asthma: randomised controlled trial. BMC Fam Pract. 2007;8:23. [pmid: 17456241].
118 Gorton TA, Cranford CO, Golden WE, et al. Primary care physicians' response to dissemination of practice guidelines. Arch Fam Med. 1995;4:135-42. [pmid: 7842151].
119 Halterman JS, McConnochie KM, Conn KM, et al. A randomized trial of primary care provider prompting to enhance preventive asthma therapy. Arch Pediatr Adolesc Med. 2005;159:422-7. [pmid: 15867114].
120 Herborg H. Sbfbeal. Improving drug therapy for patients with asthma--part 1: Patient outcomes. J Am Pharm Assoc. 2001;(4):539-50.
121 Liaw ST, Sulaiman ND, Barton CA, et al. An interactive workshop plus locally adapted guidelines can improve general practitioners asthma management and knowledge: a cluster randomised trial in the Australian setting. BMC Fam Pract. 2008;9:22. [pmid: 18423050].
122 Lozano P, Finkelstein JA, Carey VJ, et al. A multisite randomized trial of the effects of physician education and organizational change in chronic-asthma care: health outcomes of the Pediatric Asthma Care Patient Outcomes Research Team II Study. 2004;158:875-83.
123 Massie J, Efron D, Cerritelli B, et al. Archives of Disease in Childhood. Implementation of evidence based guidelines for paediatric asthma management in a teaching hospital. 2004;89:660-4. [pmid: 15210500].
124 O'Laughlen MC, Hollen PJ, Rakes G, et al. Improving pediatric asthma by the MSAGR algorithm: A multicolored, simplified, asthma guideline reminder. Pediatr Asthma, Allergy and Immunol. 2008;21:119-27.