# Methods

The methods for this systematic review follow the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (available at: www.effectivehealthcare.ahrq.gov/methodsguide.cfm).

## Topic Development and Review Protocol

The topic for this report was nominated in a public process by a staff member of the Ohio Department of Health. We recruited six key informants to provide input on the selection and refinement of the questions for the systematic review. To develop the Key Questions, we reviewed existing systematic reviews, developed an analytic framework and solicited input from our key informants through email and conference calls. Our draft Key Questions were posted on Effective Health Care Program Web site for public comment on October 14^th^, 2011. The Key Questions were revised, as necessary, based on comments.

We drafted a protocol and recruited a panel of technical experts, including guidelines and methods experts, pediatricians and asthma specialists. We finalized the protocol with input from the technical expert panel and representatives from AHRQ. The protocol was posted on the Effective Health Care Program Web site on March 2, 2012.

## Search Strategy

We searched the following databases for primary studies: MEDLINE^®^, EMBASE^®^, and the Cochrane Central Register of Controlled Trials^®^, Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^), Educational Resources Information Center (ERIC^sm^), PsycINFO^®^, and Research and Development Resource Base in Continuing Medical Education (RDRB/CME) through July 2012. We developed a search strategy for MEDLINE, accessed via PubMed^®^, based on an analysis of the medical subject headings (MeSH), terms, and text words of eligible articles identified a priori (Appendix B). This strategy was translated for use in the other electronic sources. No limits were imposed based on language or date of publication. Searches were conducted in July 2012. We also completed backward citation searching using Scopus for each included article.

## Study Selection

Title and abstracts were screened independently by two trained investigators, and were excluded if both investigators agreed that the article met one or more of the exclusion criteria (see inclusion and exclusion criteria listed in Table 2 and the Abstract Review Form in Appendix C). Differences between investigators regarding abstract eligibility were resolved through consensus.

Table 2 Study inclusion and exclusion criteria

PICOTS Framework | Inclusion | Exclusion
Populations | Participants: human subjects. Health care providers: physicians, nurses, nurse practitioners, physiotherapists/physical therapists, respiratory therapists, pharmacists, and other health care providers treating children or adults [underlined: with asthma.] | - Animal models/simulations.
Intervention | Interventions to improve adherence to guidelines including decision support (health information technology and paper-based), organizational change, feedback and audit, clinical pharmacy support, education only, quality improvement/pay-for-performance, multicomponent, information only. | - Intervention does not address adherence to asthma guidelines.; - Intervention does not target health care providers.
Comparisons of interest | Usual care, as defined in each eligible study, and comparisons between interventions. | Studies lacking a comparison.
Outcomes | Health care process outcomes:; ➢ Prescriptions for controller medicine; ➢ Environmental control practice recommendations; ➢ Self-management education and asthma action plans; ➢ Documentation of level of asthma control/severity; ➢ Prescription of peak flow meter; ➢ Follow-up visits; ➢ Unintended consequences; Clinical outcomes:; ➢ Symptom days; ➢ Missed days of school and/or work; ➢ Quality of life; ➢ Emergency department visits/hospitalizations/urgent doctor visits; ➢ Lung function tests; ➢ Rescue use of short-acting B2 agonists; ➢ Parental/patient perceptions/ratings of care; ➢ Side effects of drugs; The outcomes were nondirectional; that is, all outcomes were considered whether they were beneficial or caused potential harms or unintended consequences. | Studies that do not report an outcome of interest (e.g., studies reporting acceptability of intervention only).
Type of Study | Randomized and quasi-randomized controlled trials and crossover studies. Nonrandomized studies with comparison groups including nonrandomized controlled trial or cross-over studies, controlled pre-post studies, historically controlled studies, cohort studies, case-control studies, and cross-sectional studies. Nonrandomized studies without a separate comparison group, including interrupted-time-series, noncontrolled and pre-post studies. | We excluded meeting abstracts, studies with no original data (e.g., reviews, editorials, comments, and letters) and noncomparative studies.
Timing and Setting | Studies of any duration followup that occurred in an outpatient setting employing healthcare providers were eligible for inclusion. | We excluded studies exclusively addressing inpatient or emergency department settings or guidelines.

Citations promoted on the basis of title and abstract screen underwent another independent paired-reviewer screen using the full-text article (Appendix C, Article Review Form). Differences regarding article inclusion were resolved through consensus. During full-text screen, we identified articles not in English for which we could not determine eligibility.

We included randomized and nonrandomized studies that included a comparison and that addressed interventions such as education, reminders, decision support, clinical pharmacy support, organization changes, etc. to improve adherence to guidelines in health care providers. We excluded studies that were conducted in inpatient or emergency department settings only.

## Data Abstraction and Data Management

We used DistillerSR (Evidence Partners, 2010) to manage the screening process. DistillerSR is a Web-based database management program that manages all levels of the review process. We uploaded to the system all citations identified by the search strategies.

We created standardized forms for data extraction. (Appendix C) We pilot tested the forms prior to the beginning the process of data extraction. We used Access (Microsoft, Redmond, WA) for the data abstraction process. Reviewers extracted information on general study characteristics, study participants, eligibility criteria, interventions, and the outcomes. One reviewer completed data abstraction and the second reviewer confirmed the first reviewer's data abstraction for completeness and accuracy. Reviewers completed risk of bias assessment independently. Reviewer pairs included personnel with both clinical and methodological expertise. We resolved differences between reviewer pairs regarding data through discussion and, as needed through consensus among the larger group of investigators.

## Risk of Bias Assessment

We used the Cochrane Collaboration's tool for assessing the risk of bias of controlled studies. Two trained reviewers independently assessed the included studies according to the guidelines in Chapter 8 of the Cochrane Handbook for Systematic Reviews of Interventions28 using the following criteria: sequence generation and allocation concealment (selection bias), blinding of health care providers, investigators, and outcome assessors (detection bias), incomplete outcome data (attrition bias), selective outcome reporting (reporting bias), and other sources of bias. We reported judgments for each criterion as “Low risk of bias,” “High risk of bias” or “Unclear risk of bias (information is insufficient to assess)” per criteria provided by tool. Disagreements were resolved through team discussion.

For pre-post studies, we added the two relevant criteria from the Cochrane Effective Practice and Organization of Care (EPOC) data collections checklists.29 Specifically, the questions ask if the intervention was likely to affect data collection, and if the intervention was independent of other changes.

## Data Synthesis

For each KQ, we created a detailed set of evidence tables containing all information abstracted from eligible studies. We categorized the interventions being assessed in the studies, and synthesized information by KQ based on these categories:

1. Decision support interventions are health information technology- and/or paper-based-interventions designed to support/facilitate health care provider treatment decisionmaking (e.g., classify asthma severity);
2. Organizational change interventions are designed to change the way in which an organization provides asthma care (e.g., having an asthma “champion”);
3. Feedback and audit interventions are based upon providing performance data to health care providers about their quality of asthma care;
4. Clinical pharmacy support: interventions targeting pharmacists' delivery of asthma care;
5. Education only interventions are focused on educating health care providers about the content of asthma clinical practice guidelines;
6. Quality improvement/pay-for-performance interventions are focused on quality improvement initiatives or pay-for-performance as the primary intervention;
7. Multicomponent interventions use more than one type of intervention, with no intervention clearly identifiable as the predominant intervention.
8. Information only interventions provide only information to health care providers about asthma guideline recommendations (e.g., provide a pocket guide to asthma guidelines)

Several studies utilized more than one of the above interventions. For these studies, intervention descriptions were carefully reviewed to identify the predominant interventions. Studies in which the predominant intervention was unclear were reviewed and discussed among team members until consensus on the predominant intervention was reached. Some studies used multicomponent interventions in which no intervention could be clearly identified as predominant. All of these multicomponent studies included provision of information and provider education [underlined: plus] two or more of the following: decision support, organizational change, feedback-and-audit, or quality improvement interventions.

Based on feedback from key informants and public comment, a variety of health care process and clinical outcomes were selected to evaluate the effectiveness of interventions.

The health care process outcomes included:

- Prescriptions for controller medicine
- Environmental control practice recommendations
- Self-management education and asthma action plans
- Documentation of level of asthma control/severity
- Prescription of peak flow meter
- Follow-up visits
- Unintended consequences

The clinical outcomes, assessed in patients, included:

- Symptom days
- Missed days of school and/or work
- Quality of life
- Emergency department visits/hospitalizations/urgent doctor visits
- Lung function tests
- Rescue use of short-acting β_2_ agonists
- Parental/patient perceptions/ratings of care
- Side effects of drugs

To answer Key Question 3, we sought to identify studies providing evidence on the link between changes in health care provider behavior (health care process outcomes) to changes in clinical outcomes. Ideally, relevant studies suitably answering Key Question 3 would measure health care process and clinical outcomes, as well as a measure of strength of association between the changes in health care process to the change in clinical outcomes observed in a given study.

We selected outcomes we considered as the most commonly used in practice; those relied upon by clinicians to guide decisionmaking; and those endorsed by the NIH Workshop on Asthma Outcomes on which to focus our synthesis.30 These critical outcomes identified were prescription of asthma controller medicines, provision of asthma action plan/self-management education, ED visits/hospitalizations, and missed days of school or work.31 Data abstracted for all outcomes can be found in Appendix E.

We conducted qualitative synthesis of the evidence. Our team felt that the heterogeneity in the studies, including the measures of outcomes, population included, and specifics of the interventions, precluded quantitative synthesis.

In the absence of national qualitative standards to determine magnitude of effect in clinical asthma studies, we chose magnitudes of effect by group consensus among the investigators that were felt to be clinically meaningful changes. Magnitude of effect for studies addressing each outcome was considered as: small (less than 10 percent change or difference), moderate (10-30 percent change or difference) and large (over 30 percent change or difference). These judgments were made by one reviewer, checked by another, with disagreements discussed with the full team.

## Strength of the Body of Evidence

We graded the strength of evidence for each outcome for each of the Key Questions using the grading scheme recommended by the Methods Guide for Conducting Comparative Effectiveness Reviews.32 In assigning evidence grades, we considered the four required domains including risk of bias, directness, consistency and precision. We classified the strength of evidence into four basic categories: (1) “high” grade (indicating high confidence that the evidence reflects the true effect, and further research is very unlikely to change our confidence in the estimate of the effect); (2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect, and further research may change our confidence in the estimate of the effect and may change the estimate); (3) “low” grade (indicating low confidence that the evidence reflects the true effect, and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate); and (4) “insufficient” grade (evidence is unavailable or does not permit a conclusion). Our judgments were first based on the ability to make a conclusion (if not able to make a conclusion, then “insufficient” was assigned) and then on the confidence in the conclusion (classified as low, moderate or high with increasing certainty). The author of the section first graded the evidence and this was reviewed by the principal investigator. Any disagreements were discussed with the full team.

## Applicability

An applicability statement was created in order to help different key stakeholders understand what key implications to take away from this document, to inform future activities (e.g., research studies; implementing policies). Applicability was assessed separately for the different outcomes for the entire body of evidence guided by the PICOTS framework as recommended in the Methods Guide for Comparative Effectiveness Reviews of Interventions.32We considered factors that may limit applicability of the findings (e.g., a study conducted in a non-U.S. health care setting, providers not common to the U.S. health care system).

## Peer Review and Public Comment

A full draft report was reviewed by experts and posted for public commentary from August 8, 2012, through September 5, 2012. Comments received from either invited reviewers or through the public comment website were compiled and addressed. A disposition of comments will be posted on the Effective Healthcare Program Web site 3 months after the release of the evidence report.