# Introduction

## Background

### Burden of Asthma

Asthma is a respiratory disease characterized by variable and recurring symptoms, airflow obstruction, bronchial hyper-responsiveness, and inflammation of the airways. In the U.S., an estimated 24.6 million people (8.2 percent) currently have asthma.1 Students with asthma miss more than 14 million school days every year due to illness. Furthermore, certain U.S. population subgroups have higher prevalence rates of asthma in comparison with the national average: children (9.6 percent), poor children (13.5 percent), non-Hispanic black children (17.0 percent), women (9.7 percent), and poor adults (10.6 percent).1

### Treatment of Asthma and Clinical Practice Guidelines

The current approach to asthma management includes monitoring symptoms and lung function, encouraging the use of medications that control and prevent symptoms, controlling the triggers of asthma, educating the patient, and maintaining a collaborative patient-provider relationship that includes the use of written action plans.2 The main goals of therapy are to minimize current impairment and future risk.

A number of different organizations and countries have published clinical practice guidelines to guide health care providers in the diagnosis and management of asthma. For example, the National Asthma Education and Prevention Program (NAEPP) of the National Heart, Lung, and Blood Institute (NHLBI) has published comprehensive guidelines for diagnosing and managing asthma. The most recent guidance was published in 2007 (previous versions were published in 1991, 1997, and 2002): “Expert Panel Report 3: Guidelines for the Diagnosis and Management of Asthma” is also known as EPR-3.^2^ This guideline provides treatment recommendations with the strength of the evidence base for children 0 to 4, 5 to11, and over 12 years of age and adults. EPR-3 is based on a systematic review and expert opinion.

Clinical trials have shown that treatment in alignment with asthma guideline recommendations improves clinical patient outcomes in a variety of populations, including among high-risk populations, such as inner-city, poor, and/or African American populations.3-5 The available evidence suggests that most people with asthma can be symptom-free if they receive appropriate medical care, use inhaled corticosteroids when prescribed, and modify their environment to reduce or eliminate exposure to allergens and irritants. It is not known how best to prioritize the many recommendations of asthma guidelines, though it should be noted that the evidence supporting varies considerably. For example, medication recommendations tend to be supported by multiple randomized controlled trials, while some environmental control practices, such as avoidance of furry pets, are based only on expert opinion.

### Current Asthma Management Practices

Despite the evidence of efficacy in improving outcomes, their long-standing presence (>20 years) and their wide availability, there is extensive evidence that guideline recommendations are not routinely followed by health care providers.6,7 In one study, only 34.2 percent of patients reported being given a written asthma action plan, while only 68.1 percent had been taught the appropriate response to symptoms of an asthma attack.7 In the same study, only about one-third of children or adults were using long-term control medicine such as inhaled corticosteroids. Health care providers do not appropriately assess asthma control in most children,8-11 resulting in substandard care. Minority children are up to half as likely as Caucasian children to receive inhaled steroids.12 The significance of these studies is that suboptimal outcomes persist, such as 2-fold higher rates of emergency room visits for African American children compared with their Caucasian counterparts.13In 2005, there were approximately 679,000 emergency room visits in the U.S. due to asthma in children under 15 years of age.14 Currently, asthma is the third leading cause of hospitalization among children in this age group.14

With the growing evidence that health care providers are poorly adherent to the asthma management recommendations in published clinical practice guidelines (CPGs), there has been more focused attention on the lack of adherence to best practices. In 1999, Cabana et al15 proposed a theoretical framework to understand why health care providers do not adhere to CPGs: lack of awareness of CPGs, disagreement with the CPG recommendations (e.g., use of inhaled corticosteroids), doubts about the effectiveness of the CPG recommendations (e.g., efficacy of inhaled steroids to reduce the likelihood of asthma attacks), lack of confidence in being able to carry out the best practice (e.g., confidence in ability to provide smoking cessation counseling(e.g., inability to overcome the inertia of previous practice behaviors (e.g., changing from prescribing orally administered Albuterol to prescribing inhaled Albuterol), and external barriers (e.g., time constraints during a visit, the CPGs are not user-friendly, patient preferences, organizational constraints). There is a growing understanding that the shortcomings in health care providers' adherence to asthma CPGs may also relate to the content of asthma CPGs, which do not provide health care providers with the tools and strategies necessary to follow the recommended care.16 It is possible that with the publication of additional asthma CPGs over the past 20 years, more physicians have been exposed to the asthma CPGs, resulting in greater awareness of the CPGs, fewer disagreements with CPG recommendations, and greater confidence in carrying out recommended asthma care.17,18 However, there are some barriers outlined by Cabana et al. that would not be solved by increased exposure to asthma CPGs, including the inability of health care providers to overcome practice inertia and external barriers (e.g., time constraints during a visit, CPGs that are not user-friendly, patient preferences).19 These types of unaddressed barriers to the adherence by health care providers to asthma CPGs highlight the need to evaluate strategies that may improve adherence to asthma CPGs, including those aimed directly at health care providers as well as organizational changes that would indirectly change behavior.

### Knowledge Gaps

Although most interventions targeted at improving asthma care and outcomes have been patient-focused,20-23 there have been provider-targeted interventions to improve adherence to guidelines (e.g., educational seminars, prompts).24,70,88,100,119,122 However, there is no consensus on the most effective health care provider-targeted interventions to improve adherence to guidelines.

### Potential Impact of a Comparative Effectiveness Review

Good-quality guidelines are currently available for the care of children or adults with asthma. Systematic reviews have been published on patient-targeted interventions,25,26 but little attention has been directed toward the effectiveness of clinician-focused strategies designed to enhance the implementation of guidelines in clinical practice. In 2007, the Stanford University–University of California San Francisco Evidence-based Practice Center published a report on asthma care, titled “Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies: Volume 5—Asthma Care.”27 This report showed that, despite the availability of evidence-based guidelines for the management of pediatric and adult asthma, a significant gap remains between accepted best practices for asthma care and the actual care delivered to patients with asthma in the U.S. The report authors examined the published literature through May 2006 on quality improvement strategies to improve the processes and outcomes of outpatient care for children and adults with asthma. The interventions included from their search had been tested between 1976 and 2004, so studies published after 2004 would not have been included. Furthermore, the interventions used in those studies were directed at patient adherence to provider-prescribed care, rather than at provider adherence to asthma guidelines.

The purpose of this systematic review is to evaluate the effectiveness of interventions designed to improve health care provider adherence to asthma guidelines.

## Key Questions

Our Key Questions (KQs) are listed below, with the PICOTS (Population, Intervention, Comparator, Outcomes, Timing, Setting) elements listed in Table 1 and the questions displayed in Figure 1.

KQ1: In the care of pediatric or adult patients with asthma, what is the evidence that interventions designed to improve health care provider adherence to guidelines impact health care process outcomes (e.g., receiving appropriate treatment)?

KQ2: In the care of pediatric or adult patients with asthma, what is the evidence that interventions designed to improve health care provider adherence to guidelines impact clinical outcomes (e.g., hospitalizations, patient reported outcomes such as symptom control)?

KQ3: In the care of pediatric or adult patients with asthma, what is the evidence that interventions designed to improve health care provider adherence to guidelines impact health care process outcomes that then affect clinical outcomes?

Table 1 Characteristics of the target studies according to the PICOTS framework

Population(s) | Physicians, nurses, physiotherapists/physical therapists, respiratory therapists, pharmacists and other health care providers treating children (0 to 18 years of age) or adults (over 18 years of age) with asthma.
Interventions | Interventions to improve adherence to guidelines. Includes: decision support (health information technology and paper-based), organizational change, feedback and audit, clinical pharmacy support, education only, quality improvement/pay-for-performance, multicomponent, information only.
Comparators | Usual care, as defined by eligible study, and comparisons between interventions.
Outcomes | Health care process outcomes (including: prescriptions for controller medicine, environmental control practice recommendations, self-management education, asthma action plans, documentation of level of asthma severity, prescription of peak flow meter, and follow-up visits) Clinical outcomes (including: symptom days, missed days of school and/or work, quality of life, emergency department visits/hospitalizations/urgent doctor visits, lung function tests, rescue use of short-acting β_2_ agonists, parental/patient perceptions/ratings of care, and side effects of drugs). The outcomes are nondirectional. That is, outcomes deemed good, as well as those deemed to be potential harms or unintended consequences, were considered.
Timing | Studies with all duration of followup were considered for the review.
Setting | Outpatient settings in which health care providers work, but not emergency room or in-patient settings.

Figure 1 Analytic framework for guidelines on the care of adults and children with asthma

KQ = Key Question

Figure 1 shows our analytic framework presenting the Key Questions (KQ) in terms of: 1) the populations (physicians, nurses, physio/physical therapists, respiratory therapists, pharmacists, and other healthcare providers); 2) the interventions aimed at our given populations; 3) the healthcare process outcomes (prescriptions for controller medicine, environmental control practice recommendations, self-management education and asthma action plans, documentation of level of asthma control/severity, prescription of peak flow meter, follow-up visits, and unintended consequences); 4)clinical outcomes (symptom days, missed days of school and/or work, quality of life, emergency department visits/hospitalizations/urgent doctor visits, lung function tests, rescue use of short-acting β2 agonists, parental/patient perceptions/ratings of care, side effects of drugs

The relationship between each Key Question and the PICOTS format is depicted in Figure 1, below.