# Technical Expert Panel

- Michael Cabana, M.D., M.P.H.
  University of California, San Francisco
  San Francisco, CA

- Rey Panettieri, M.D.
  University of Pennsylvania
  Philadelphia, PA

- Frederic Wolf, Ph.D., M.Ed.
  University of Washington
  Seattle, WA

- Barbara Yawn, M.D., M.Sc., FAAFP
  Olmsted Medical Center
  Rochester, MN

- Jessica Zar
  American Academy of Pediatrics
  Elk Grove Village, IL

- Ilene Zuckerman, Pharm.D, Ph.D.
  University of Maryland
  Baltimore, MD