# Key Informants

- Michael Cabana, M.D., M.P.H.
  University of California, San Francisco
  San Francisco, CA

- Lisa Cicutto, Ph.D., R.N.
  National Jewish Health & University of Colorado, Denver
  Denver, CO

- Cheryl De Pinto, M.D.
  Maryland Asthma Control Program
  Maryland Department of Health and Mental Hygiene
  Baltimore, MD

- Arethusa Kirk, M.D., FAAP
  Total Health Care, Inc.
  Baltimore, MD

- Margret Schnitzer, M.S.M.
  Greater Baltimore Asthma Alliance
  Baltimore, MD

- Kate Scott, R.N., M.P.H.
  Baltimore City Health Department
  Healthy Homes and Communities Division
  Baltimore, MD