# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Christine Chang, M.D., M.P.H. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The Evidence-based Practice Center thanks Oluwatosin Ikotun, Nelson Biodun Olagbuji, and Oluwaseun Omole for their assistance with reviewing articles and data abstraction.