# Discussion

The Discussion section is divided into the following topics: Applicability; Limitations of Review; Limitations of Evidence Base; Findings in Relationship to What Is Already Known; Future Research; Implications for Clinical and Policy Decisionmaking; and Conclusions. In these sections we discuss how our findings may be relevant to various asthma stakeholders, the limitations of our systematic review and future considerations for asthma stakeholders seeking to improve health care provider adherence to asthma guidelines.

## Key Findings

The key findings from this report are outlined below, organized by general class of intervention. Subsequent tables summarize conclusions according to Key Question and by type of intervention (Tables 14–16).

Table 14 Summary of the strength of evidence in support of eight interventions designed to modify clinician adherence to asthma guidelines

Intervention | Outcome: Prescription of Controller Medications | Outcome: Patient Education/Asthma Action Plans | Outcome: ED Visits/Hospitalizations | Outcome: Missed Days of Work/School
Decision support | Benefit with large magnitude of effect. SOE moderate. | Studies consistently favor intervention with large magnitude of effect. SOE moderate. | Benefit with moderate magnitude of effect (larger in pre-post studies). SOE moderate. | Unable to conclude due to inconsistent results. SOE inconsistent.
Organizational change | Benefit with small magnitude of effect. SOE low. | Two studies show benefit with moderate magnitude of effect. SOE low. | Inconsistent results. Benefit with large magnitude of effect in pre-post studies; smaller in RCTs. SOE low. | No benefit (for missed school days). SOE low.
Feedback and audit | Benefit with moderate magnitude of effect. SOE moderate. | Benefit with low magnitude of effect. SOE low. | Benefit with low magnitude of effect. SOE low. | No conclusion due to inconsistent results in one included study. SOE insufficient.
Clinical pharmacy support | Benefit within three studies with moderate magnitude of effect. SOE moderate. | Benefit in one study with moderate magnitude of effect. SOE moderate. | Unable to make a conclusion based on one study with imprecise results. SOE insufficient. | No studies. SOE insufficient.
Education only | No benefit. SOE low. | Small to moderate increases in a minority of studies. SOE low. | No benefit. Inconsistent results (reductions and increases). Low SOE. | No conclusion due to inconsistent and imprecise results in five studies. Insufficient SOE.
QI and pay-for-performance | No studies. SOE Insufficient. | Observational studies showed benefit, while the RCT did not. Benefit with moderate magnitude of effect. SOE low. | No benefit. Low SOE. | Unable to draw conclusions. One study (with high risk of bias) reported a nonsignificant reduction in school days missed. SOE insufficient.
Multicomponent interventions | Benefit with moderate magnitude of effect. SOE low. | Benefit, with moderate magnitude of effect (larger in observational studies). SOE low. | Unable to make conclusion; while the one study reported a large reduction, the study quality was low. Insufficient SOE. | No conclusion; One study reported a large reduction, but study quality was low. SOE insufficient.
Information only | No studies. SOE Insufficient. | No studies. SOE Insufficient. | Unable to make conclusion; no difference seen, but study quality was low. SOE insufficient. | No studies. SOE insufficient.

ED = emergency department; QI = quality improvement; RCT = randomized controlled trial; SOE = strength of evidence

Table 15 Summary of strength of evidence for included studies for KQ1

Outcomes | Intervention | No. of Studies/No. of Health Care Providers | Strength of Evidence | Conclusions
Prescriptions for controller medications | Decision support | 15/1,635 6 RCTs, 9 pre-post | Moderate | Most of the evidence supporting the use of decision support Interventions comes from a number of nonrandomized studies consistently showing that decision support interventions can increase health care provider prescriptions for asthma controller medications. The magnitude of effect is large: 2%-34% in pre-post studies; 2%-17% in RCTs.
Prescriptions for controller medications | Organizational change | 2/228 1 RCT, 1 pre-post | Low | Although far fewer studies performed using organizational change (in comparison with Decision Support or Feedback/Audit), the findings consistently showed that organizational change can increase health care provider prescriptions for controller medicines, but the effect on prescriptions by health care providers is smaller. The magnitude of effect is small. In the RCT: 8%-16% for all asthma patients; 4%-11% for patients with persistent asthma; 4%-9% for inhaled steroids (ICS) for all asthma patients; 13%-19% for ICS for patients with persistent asthma. In the pre-post study: 12% increase in ICS.
Prescriptions for controller medications | Feedback and audit | 11/1,831 6 RCTs, 4 pre-post and 1 nonrandomized controlled | Moderate | These studies consistently showed that feedback/audit interventions effectively increase prescriptions for controller medicines by health care providers. The magnitude of the effect is moderate. Effect size: 0.12-0.66. Increase in prescribing controller medications ranging from 15.9% to 52-104% Hazard ratio range: 0.77-1.08.
Prescriptions for controller medications | Clinical pharmacy support | 3/91 1 RCT, 1 pre-post, 1 nonrandomized | Moderate | The three studies were consistent in showing that clinical pharmacy support interventions increase asthma controller medication prescribing The magnitude of the effect is moderate. OR: 3.80 (95% CI: 1.4, 10.32) and percent increase in patients prescribed controller meds pre and post: 6-21%.
Prescriptions for controller medications | Education only | 10/451 6 RCTs, 4 pre-post | Low | The evidence suggests that interventions based only on education of clinicians do not improve prescription of asthma controller medications. The magnitude of effect is small to large in studies (3.5-50.3% increase in prescribing controller medicines.
Prescriptions for controller medications | Quality improvement and pay-for-performance | 0 studies | Insufficient | No studies identified.
Prescriptions for controller medications | Multicomponent interventions | 7/>1,141 4 Cluster randomized, 3 pre-post | Low | Two pre-post studies and one RCT reported a significant increase in prescribing (25-49% in pre-post studies), while all other effects were null. Overall, the magnitude of effect is small.
Prescriptions for controller medications | Information only | 2/107 1 RCT, 1 quasi-experimental | Insufficient | Due to inconsistency across studies, evidence is insufficient to determine the effect of information alone on prescribing of asthma controller medication.
Patient education/asthma action plans | Decision support | 10/122-124 4 RCTs, 6 pre-post | Moderate | A majority of nonrandomized studies consistently favor the use of decision support interventions to improve the provision of self-management education/asthma action plans by health care providers. The magnitude of effect is large: 14%-84%.
Patient education/asthma action plans | Organizational change | 2/24 1 RCT, 1 pre-post | Low | Both studies favor the use of organizational change to increase patient education/asthma action plan use by health care providers. However, more studies are needed to increase the strength of evidence. The magnitude of effect is moderate: 10%-14%.
Patient education/asthma action plans | Feedback and audit | 5/336 3 RCTs, 2 pre-post | Low | Despite a number of studies examining feedback/audit, inconsistent results lead to a low strength of evidence for the use of feedback/audit to improve self-management education/ asthma action plan use. The magnitude of the effect is low. [underlined: Self-management education]: difference in proportions range from low of 0.7 (95% CI: -15.2, 16.7) for peak flow meter use to 12.9 (95% CI: 1.9, 23.9) for inhaler technique education. [underlined: Asthma Action Plans]: Increase of 7.6 % in Feedback with Benchmark as compared with Traditional: 4.5%. [underlined: Asthma Education:] Range Pre to post 46-133% increase.
Patient education/asthma action plans | Clinical pharmacy support | 1/82 1 RCT | Moderate | The one study demonstrated a positive effect in the use of Clinical Pharmacy Support to improve self-management education/asthma action plan use by health care providers. The magnitude of the effect is moderate. [underlined: Asthma Action Plans]: 40-45% increase from baseline.
Patient education/asthma action plans | Education only | 5/470 5 RCTs | Low | Small increases in asthma self-management education were observed in a minority of studies, resulting in an overall low strength of evidence regarding this outcome. The magnitude of effect is small to moderate: 10%-15%. OR: 1.00; RR: 1.40.
Patient education/asthma action plans | Quality improvement and pay-for-performance | 3/63 practices (providers not reported) 1 RCT, 2 pre-post | Low | Inconsistent results with a -3 to 33% change in the provision of asthma action plans. Both observational studies reported increases of 19-33% while the negative RCT had evidence of suboptimal practice engagement.
Patient education/asthma action plans | Multicomponent interventions | 6/>937 2 RCT, 4 pre-post | Low | Magnitude of effect is moderate. Provision of asthma action plan increased 27%-46% in observational studies. Smaller effect sizes were seen in RCTs (7% of providers and RR': 1.82).
Patient education/asthma action plans | Information only | 0 | Insufficient | No studies identified.

OR = odds ration; RCT = randomized controlled trial, RR = relative risk; RR' = relative rate

Note: If the number of health care provider participants was not reported for a particular study, the “NR” value was treated as zero for that particular intervention and outcome category.

Table 16 Summary of strength of evidence for included studies for KQ2

Outcomes | Intervention | No. of Studies/No. of Health Care Providers | Strength of Evidence | Conclusions
ED Visits/Hospitalizations | Decision support | 10/820 5 RCTs, 5 Pre-post | Moderate | 9 of 10 studies reported that decision support interventions reduce ED visits/hospitalizations.
ED Visits/Hospitalizations | Organizational change | 4/252 2 RCTs, 2 pre-post | Low | Low strength of evidence organizational change does not reduce ED visits/hospitalizations.
ED Visits/Hospitalizations | Feedback and audit | 2/125 1 RCT, 1 pre-post | Insufficient | Inconsistent results from a limited number of studies have resulted in an insufficient grade of evidence to evaluate the impact of feedback and audit interventions on ED visits and hospitalizations. The magnitude of the evidence is low.
ED Visits/Hospitalizations | Clinical pharmacy support | 1/36 1 RCT | Insufficient | There is insufficient evidence available to determine the effect of clinical pharmacy support interventions on ED visits/hospitalizations.
ED Visits/Hospitalizations | Education only | 7/343 5 RCTs, 2 pre-post | Low | Overall, due to conflicting results among a number of studies, the low strength of evidence suggests that education-alone interventions do not reduce asthma ED visits and/or hospitalizations.
ED Visits/Hospitalizations | Quality improvement and pay-for-performance | 2/56 practices (providers not reported) 1 RCT, 1 pre-post | Low | Two studies show that quality improvement does not reduce ED visits and hospitalizations. More studies are needed.
ED Visits/Hospitalizations | Multicomponent | 1/17 clinics (providers not reported) 1 cohort | Insufficient | There is insufficient evidence to determine the effect of multicomponent interventions on ED visits/ hospitalizations due to high rates of participant attrition (low study quality) in the single study included.
ED Visits/Hospitalizations | Information only | 1/13 1 RCT | Insufficient | Based on a single study with a high risk of bias, there is insufficient evidence to determine the effect of information-only interventions on ED visits/hospitalizations.
Missed days of work/school | Decision support | 2/435 1 RCT, 1 pre-post | Insufficient | There is insufficient evidence to evaluate the effect of decision support interventions on the number of missed days of work/school.
Missed days of work/school | Organizational change | 1/24 1 RCT | Low | Organizational change does not reduce missed school days from asthma. The strength of evidence for this conclusion is low.
Missed days of work/school | Feedback and audit | 1/29 1 pre-post | Insufficient | There is insufficient evidence to evaluate the effect of feedback and audit interventions on the number of missed days of work and school from asthma due to inconsistent results and study design.
Missed days of work/school | Clinical pharmacy support | 0 | Insufficient | No studies identified.
Missed days of work/school | Education only | 5/1,767 4 RCTs, 1 pre-post | Insufficient | There is insufficient evidence to evaluate the effect of education-only strategies on the number of missed days of work/school from asthma due to imprecise estimates and inconsistent results.
Missed days of work/school | Quality improvement and pay-for-performance | 1/13 practices (providers not reported) 1 pre-post | Insufficient | There is insufficient evidence to evaluate the effect of quality improvement/pay-for-performance interventions on the number of missed days of work/school from asthma because of high risk of bias in the single study analyzed.
Missed days of work/school | Multicomponent | 1/17 clinics (providers not reported) 1 cohort | Insufficient | There is insufficient evidence to determine the effect of multicomponent interventions on the number of missed days of work/school from asthma due to risk of bias (high rate of attrition) and inconsistent results across clinical sites.
Missed days of work/school | Information only | 0 | Insufficient | No studies identified.

ED = emergency department; RCT = randomized controlled trial

Note: If the number of healthcare provider participants was not reported for a particular study, the “NR” value was treated as zero for that particular intervention and outcome category.

### KQ1 In the care of pediatric or adult patients with asthma, what is the evidence that Interventions designed to improve health care provider adherence to guidelines impact health care process outcomes (e.g., receiving appropriate treatment)?

The key findings are summarized in Table 15.

### KQ2 In the care of pediatric or adult patients with asthma, what is the evidence that Interventions designed to improve health care provider adherence to guidelines impact clinical outcomes (e.g., hospitalizations, patient-reported outcomes such as symptom control)?

The key findings are summarized by outcome in Table 16.

## Applicability

We assessed applicability of these studies to the potential users of this review using the PICOTS framework. The purpose of this section is to highlight the applicability of this report to various key stakeholders to whom this document may be of interest and used to direct future activities (e.g., implement policy or direct future research endeavors). We have detailed our assessment more specifically below (Table 17), according to each PICOTS element:

Table 17 Applicability

Domain | Description of Applicability of Evidence
Population - Provider | From a health care provider perspective, primary care providers were essentially the only targeted population of the studies we reviewed. The types of primary care providers were varied, but primarily focused on physicians, although some studies did include nurses, nurse practitioners and pharmacists. No studies targeted respiratory therapists and only one study included an asthma specialist (pulmonologist or allergist).
Population - Patients | A minority of studies described the patient population in detail—these often were U.S.-based studies that were conducted in settings with a high proportion of African American, Latino and/or poor patients. Therefore, we believe that at least some of the interventions reviewed could be implemented in settings that care for such patient populations.
Intervention | In terms of the interventions themselves, general descriptions of the content and administration were provided, but often without an explanation of dose or intensity needed—this would be important for: (1) those deciding what intervention to replicate for their own setting; (2) estimating the likelihood of successful implementation and long-term sustainability of a given intervention; (3) determining how likely health care providers are to buy-in and adhere to using these interventions in their routine clinical practice. In addition, three intervention types were most frequently studied: decision support, feedback/audit, and education accounted for 80% of the interventions we reviewed. There were relatively few studies of organizational change, quality improvement, information-only strategies or even using a combination of interventions.
Comparators | We often were not able to discern with any specificity what the comparative condition was in these studies, since the comparator was often described as “usual care”. This limitation was true even among the RCTs we reviewed.
Outcomes | There were a number of different health care process and clinical outcomes evaluated in these studies, although these were heavily skewed to 2–3 outcomes: prescribing of asthma controller medicines; self-management education; asthma action plans; and emergency department visits/hospitalizations accounted for the vast majority of outcomes studied. Therefore, those seeking to impact these outcomes have data available to base an intervention choice upon, while those seeking to reduce missed days of school or other infrequently studied outcomes will not have sufficient evidence upon which to base this decision.
Setting | We observed a nearly equal distribution of studies conducted in the U.S. vs. outside of the U.S. The non-U.S. study locations were quite varied and included Africa, Asia, Australia, Canada and Europe. There was relatively little detail about the specific settings in which the studies were conducted, so applicability to a specific clinical type is limited.

## Limitations of Review

There are a number of limitations of our review that should be acknowledged. First, we did not consider or search for reports of potentially relevant studies in the grey literature. This means that our evidence base could be open to publication bias. This may be particularly applicable to this topic, as many interventions aimed at changing health care provider behavior, particularly quality improvement efforts, may have been published in venues other than peer-reviewed literature. We did not complete formal assessment of publication bias as this is challenging, at best. It has been suggested that funnel plots be used to check for publication bias; however, these are difficult to interpret and considered unhelpful for comparisons and outcomes with less than 10 studies.101

We identified potentially eligible studies that were published in a language other than English (i.e., no restrictions by language in search) but were unable, due to resource limitations, to consider these articles for inclusion in the review. While this raises the possibility of introducing publication bias, we do not feel that the exclusion of the non-English reports of studies influenced our conclusions or ability to draw conclusions. In addition, there were only 20 of 3,846 abstracts and 16 of 244 articles excluded because they were not in English and we could not determine eligibility, thus representing a minority of the studies excluded. Furthermore, it is unclear if these studies would be relevant to the U.S. health care setting or U.S. health care provider.

Many studies implemented more than one intervention. We made a concerted effort to categorize studies by the predominant intervention, based on review and discussion by team members; however, our classifications may not always be identical to those intended by the original investigators. Furthermore, the frequent use of multiple interventions within a single study means that intervention-specific categories may appear to be missing some studies, as they may have been categorized with another intervention or with multicomponent interventions.

We determined that the heterogeneity in the studies (i.e., how outcomes were measured, study populations and intervention details) precluded the use of meta-analyses. A qualitative synthesis was therefore deemed more appropriate, although it did not guarantee a definitive answer for decisionmakers. It also limited our ability to examine or compare subgroups of studies; for example, comparing results from pre-post studies with those from randomized trials.

To maintain a reasonable scope for both the authors and readers of the report, we limited our qualitative synthesis to four critical outcomes. Although these outcomes were chosen as those most important for making decisions, limiting our synthesis to these outcomes meant that we could not comment on the effectiveness of these interventions in improving other elements of asthma care (e.g., environmental control practices) or asthma outcomes (e.g., symptom-free days).

We did not include studies in which interventions specifically targeted both health care providers and patients for which we could not distinguish whether changes in outcomes were due to changes amongst the providers or patients. We did not evaluate patient adherence to health care provider prescribed treatment, which might moderate the clinical outcomes measured in our review. We suggest this review be considered along with the existing EPC report on patient adherence.102

## Limitations of Evidence Base

There were relatively few published data available to evaluate the impact of interventions on most clinical outcomes (except for ED visits/hospitalizations), highlighting the need for more evidence for those seeking to implement evidence-based interventions targeting health care providers (Table 18). An important limitation is the fact that no studies answered our third Key Question (if changes in health care provider behavior (health care process outcomes) lead to changes in clinical outcomes). There is an implicit assumption that if health care providers carry out the appropriate health care process behaviors, then clinical outcomes will improve, but it would be important to know the strength of this association. Unfortunately, no studies provided data to answer this question.

There was no standardized definition for each type of intervention that was used by the authors of the studies we reviewed or for us to use in classifying studies. Therefore, there is the possibility of misclassification bias in assigning studies to an intervention type. It may be worthwhile for funding, regulatory and/or policymaking agencies to consider developing standardized definitions of these interventions. Such standardization would make it easier and more accurate to compare studies within an intervention type and between intervention types. In a similar way, standardization of baseline and outcome measures for intervention-based studies by these agencies would greatly enhance comparability between studies.

Arguably, most striking was the lack of measurement of potential negative consequences from implementing these interventions (e.g., longer patient visits, greater burden on office staff or increased financial cost). Conversely, there may be positive consequences (e.g., shorter patient visits, reduced burden on office staff, decreased cost) that were not captured in the studies we reviewed. For those considering whether to implement a given intervention, the current data will not allow them to fully evaluate the costs or benefits (financial and otherwise) and therefore the ability to make a fully informed and balanced decision is limited. There may be an opportunity for funding, regulatory and/or policymaking bodies to establish standardized measures to capture these potential negative or positive consequences.

Specific limitations in the evidence we identified is detailed using the PICOTS (Populations, Interventions, Comparator, Outcomes, Timing, and Setting) framework in the Future Research section.

## Findings in Relationship to What Is Already Known

We conducted a search for relevant Cochrane reviews and excluded 63 of 86 at the title-search screening level for lack of relevance (e.g., not provider-focused interventions). Of the remaining 23 reviews, we identified 10 reviews as relevant to the topic of asthma and/or relevant to the types of interventions included in our study. Five of the ten studies we found had asthma-related outcomes relevant to and included in our review.37,56,73,89,100 Of the five reviews that did not focus on asthma, but did evaluate relevant interventions, we observed similar modest effects among low quality intervention studies of education103-107; Pay-for-performance108-110; Reminder systems111,112;and Feedback/Audit.113,114 These findings suggest that additional evidence is needed to fully evaluate the effectiveness of these interventions in improving health care provider adherence to guidelines and, ultimately, clinical outcomes.

## Future Research

Table 18 Future research

PICOT Framework | Observation | Recommendation for Future Research
Population | Inadequate clinical and sociodemographic descriptions of the patient population. | Measure asthma control/severity, race/ethnicity, gender, socioeconomic status, etc. in patient populations to more effectively compare effectiveness between studies of interventions. Test efficacy of multifaceted individualized interventions targeting a specific group of subjects (i.e., young or older age groups, high asthma severity, and high health care utilizers).
Intervention | Few studies utilized a randomized, controlled intervention approach. | Augment number of studies with RCT design, especially as reviewed RCTs tended to yield more equivocal results.
Intervention | The reported impact on healthcare provider behaviors (even when illustrating a beneficial effect) was modest, suggesting that certain barriers to provider adherence to asthma guidelines remained unaddressed. | Develop/incorporate new strategies or combinations of strategies to increase provider adherence to guidelines. Develop strategies to incorporate successful interventions into primary care practices that address time constraints, work flow issues and limited resources
Intervention | Relatively few computer-based interventions. | Computerized systems offer an opportunity to increase efficiency in the health care process, thereby potentially improving provider adherence to guidelines. If time constraints pose a barrier to adherence, electronic/computer-based interventions may meaningfully improve delivery of asthma care.
Intervention | Strategies were generally “passive” (i.e., suggesting care to the provider; discussing asthma management generally, but not for specific patients). | Interventions should take a more active role in asthma care process (e.g., provide asthma action plans, patient education, environmental control practices), particularly processes associated with a low risk of harm and those inhibited by specific barriers such as time constraints, poor self-efficiency, lack of awareness. Focus on health care processes impeded by logistical barriers, rather than those barred by provider discord regarding recommendations or lack of outcome expectancy. This also suggests that systems-level interventions that address barriers external to the health care provider would be an important approach to effecting positive changes in health care provider behavior.
Intervention | Interventions were often narrow in scope and failed to address the comprehensive and complex tasks health care providers must execute in order to be adherent to asthma guideline recommendations (as well as “competing” guidelines including well child care, chronic comorbidities). | Test interventions that address all of the elements of the asthma health care process (or as many as is feasible). For example, an intervention that would facilitate/expedite the following elements of care in a single visit might be beneficial: (1) Rx for controller medicine, (2) environmental control practice recommendations, (3) self-management education and asthma action plans, (4) documentation of asthma control/severity, (5) Rx of peak flow meter, (6) schedule of automatic follow-up visits within 3 months of visit. Specify multifaceted interventions to include provider education + feedback + decision support (or other combinations that seem most potent mixtures of interventions). Test similar multifaceted models. Multifaceted interventions are feasible because they are more translatable than interventions limited to one modality. Caveat: multifaceted interventions are more costly.
Intervention | Inadequate description or measure of dose. | Measure or address intervention “dose.” For example, if only 50 percent of provider participate in intervention, dose is important.
Intervention | No examination of whether changes in health care provider behavior results in changes in clinical outcomes | Design studies that are more comprehensive in scope to capture changes in health care process measures and determine the strength of association with changes in clinical outcomes.
Comparisons | Pre/post designs common. Uncontrolled studies used. | Conduct more explicit comparisons of differing results between studies of different designs (i.e. direct comparisons of how results from pre-post studies differ from results from RCTs). Move beyond pre-post studies; use cluster RCTs; conduct studies with appropriate control groups.
Outcome | Heterogeneity in presentation of the outcome measures. | Develop minimum standards for presentation of outcomes (e.g., percent change in prescriptions for inhaled steroids). Other outcomes could be presented, but at minimum, one standard would facilitate comparisons between studies.
Outcome | Studies failed to link changes in health care process to clinical outcomes. | Develop studies that illustrate how specific changes in provision of care manifest improvements in patient outcomes.
Outcome | Subjectivity/variability in clinical outcome measures including: Hospitalizations, ED visits | Objective/reliable outcome measures: Administrative health care utilization data for verification of ED visits, hospitalizations; standardization of cut-points. Standardize timeframe for measurement of health care utilization outcomes, i.e. 12 months to account for seasonality effects.
Outcome | Subjectivity/variability in health care process outcomes measures including: Lack of determination of appropriateness of controller medication prescriptions Lack of assessment of patient medication adherence as an outcome and/or a modifier of outcomes | Utilize pharmacy data or electronic monitoring of medication use to objectively measure controller medication adherence by patients as a clinical outcome. Consider additional metrics as indicators of appropriate care, e.g., [underlined: Use of controller meds]: >6 fills per 12 months. [underlined: Controller-to-total asthma medication ratio:] # controller fills in past 12 months/# controller fills + all other asthma med fills. (Cut-point: >0.5).
Outcome | Lack of use of significance tests | Develop standards for inclusion of significance testing of data presented (e.g., chi-squared for proportions)
Outcome | Cost | Develop standard measures of cost of intervention to determine feasibility for practices to implement
Timeframes | | No new recommendations
Settings of care | | No new recommendations

## Implications for Clinical and Policy Decisionmaking

For health care providers and policy decisionmakers alike, there are strategies that can be implemented to improve the adherence of health care providers to asthma guideline recommendations. In particular, decision support, feedback/audit and clinical pharmacy support strategies more often were associated with improving provider adherence to guidelines than other interventions (e.g., education). With the exception of education interventions, these strategies were more often studied and more often improved provider adherence to guidelines. It is not clear from our review of the literature why some intervention types have been more studied than others. Given the multitude of tasks confronting the health care provider during an asthma care visit (e.g., provide self-management education and environmental control recommendations, prescribe controller medications or one of the three other health care process measures included in our study), it appears that no single type of intervention is capable of remediating all of the health care process outcomes to be addressed by health care providers. A combination of interventions may, however, allow simultaneous contribution to multiple elements of care. Computers, particularly electronic medical records (EMRs) may help to facilitate the need to intervene upon multiple components of asthma care, yet few studies in this review utilized the EMR as the vehicle for their intervention. With the increase in use of EMRs, interventions easily incorporated into an EMR environment may be appealing for providers seeking strategies that can be readily implemented into practice.

Further, organizational change interventions to enhance health care provider adherence to national guidelines were relatively understudied. This is important because organizational change is essentially the only systems-level type of intervention among those that we reviewed. Given the variety, complexity and barriers to completion of tasks confronting health care providers, systems-level (organizational change) interventions warrant further evaluation. An organizational change intervention may lend itself to being combined with other interventions (e.g., Decision Support and Feedback/Audit). Such “multicomponent” interventions would be expected to more likely meet the multiple care and treatment goals confronting health care providers caring for patients with asthma. It also appears that interventions that supplement or act independently of the health care provider's behavior (decision support; clinical pharmacy support) were effective in achieving the desired process outcomes (e.g., increased prescribing of controller medications). Feedback/audit interventions, in specific, may be a useful strategy to incorporate into practice in that the feedback provides health care providers with insight into their own behaviors and performance and if provided on a regular basis may facilitate adherence to providing guideline-based care.

There were some promising findings, particularly among interventions that utilized decision support, feedback/audit or clinical pharmacy support strategies to improve health care provider adherence to guidelines. These intervention strategies tended to have higher levels of strength and larger magnitudes of effect in comparison with other intervention strategies (e.g., education or information only). However, heterogeneity within each intervention category such as variation in personnel delivering intervention, length of intervention, or multiple components makes it challenging to draw valid conclusions about the key components of each intervention. Consequently highlighting the key elements of a specific type of intervention such as decision support is an area of evaluation requiring further development.

Because educational–based interventions were most likely to show no benefit, this type of intervention warrants no further evaluation as an isolated strategy. Furthermore, most studies tested a single strategy, although there were some studies that utilized multiple strategies (Table 19) but too few to draw any definitive conclusions for evaluating whether “multimodal” are more successful than single-interventions.

Table 19 Primary and secondary interventions utilized by the included studies

Author, Year | Decision Support | Organizational Change | Feedback and Audit | Clinical Pharmacy Support | Education | Quality Improvement and Pay-for-Performance | Multicomponent | Information Only
Ables AZ, 2002^115^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Armour C., 2007^65^ | N/A | N/A | N/A | P | | N/A | N/A | N/A
Baker R., 2003^116^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Baker R., 2003^55^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Bell L.M., 2010^38^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Bender B. G., 2011^78^ | N/A | N/A | N/A | N/A | | N/A | P | N/A
Blackstien-Hirsch P., 2000^77^ | S | N/A | N/A | N/A | P | N/A | N/A | N/A
Brown R, 2004^70^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Bryce FP, 1995^85^ | N/A | N/A | S | N/A | | N/A | N/A | P
Cabana M. D., 2006^100^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Cho S. H., 2010^41^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Clark NM, 1998^71^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Cloutier M. M., 2002^46^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Cloutier M. M., 2005^44^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Cloutier M.M., 2009^48^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Coleman C. I., 2003^60^ | N/A | N/A | P | N/A | N/A | N/A | N/A | N/A
Cowie R. L., 2001^75^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Daniels E. C., 2005^80^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A
Davis AM, 2010^47^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Davis R. S., 2004^76^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
de Vries T. W., 2010^66^ | N/A | N/A | S | P | S | N/A | N/A | N/A
Eccles M., 2002^37^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Fairall L., 2010^33^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Feder G, 1995^56^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Finkelstein J. A., 2005^51^ | N/A | P | S | N/A | | N/A | N/A | N/A
Foster J. M., 2007^117^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Fox P., 2007^94^ | N/A | S | N/A | N/A | N/A | P | N/A | N/A
Frankowski B. L., 2006^97^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A
Glasgow N. J., 2003^90^ | N/A | P | N/A | N/A | N/A | N/A | N/A | N/A
Gorton T. A., 1995^118^ | S | N/A | N/A | N/A | P | N/A | N/A | N/A
Hagmolen, W., 2008^79^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A
Halterman J. S., 2005^119^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Halterman J.S., 2006^87^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Herborg H., 2001^63^ & 120 | N/A | N/A | P | S | N/A | N/A | N/A | N/A
Holton C., 2011^92^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Homer CJ, 2005^96^ | N/A | N/A | N/A | N/A | N/A | P | N/A | N/A
Horswell R., 2008^43^ | P | N/A | S | N/A | N/A | N/A | N/A | N/A
Hoskins G., 1997^59^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Kattan M., 2006^35^ | P | N/A | S | N/A | N/A | N/A | N/A | N/A
Lesho E. P., 2005^45^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Liaw S. T., 2008^121^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Lozano P., 2004^122^ | N/A | S | N/A | N/A | P | N/A | N/A | N/A
Lob, 2011^82^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A
Lundborg C. S., 1999^81^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A
Mahi-Taright S., 2004^74^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Mangione-Smith R., 2005^95^ | N/A | S | N/A | N/A | N/A | P | N/A | N/A
Martens J. D., 2006^84^ | N/A | N/A | N/A | N/A | N/A | N/A | N/A | P
Martens J. D., 2007^34^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Massie J, D., 2004^123^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A
McCowan C, 2001^89^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Mitchell E. A., 2005^36^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Newton W. P., 2010^42^ | P | S | N/A | N/A | N/A | N/A | N/A | N/A
O'Laughlen MC, 2008^124^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Patel P. H., 2004^91^ | N/A | P | N/A | N/A | N/A | N/A | N/A | N/A
Premaratne U. N., 1999^73^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Ragazzi H., 2011^49^ | P | S | N/A | N/A | S | N/A | N/A | N/A
Rance K., 2011^39^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Renzi P. M., 2006^98^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Richman M. J, 2000^62^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Ruoff G., 2002^88^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Saini B, 2004^67^ | N/A | N/A | S | P | N/A | N/A | N/A | N/A
Schneider A., 2008^57^ | N/A | N/A | P | N/A | N/A | N/A | N/A | N/A
Shah S., 2011^68^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Shapiro A., 2011^40^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Shiffman R. N., 2000^50^ | P | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Smeele I. J., 1999^69^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Sondergaard J., 2002^54^ | N/A | N/A | P | N/A | N/A | N/A | N/A | N/A
Stergachis A, 2002^72^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Suh D. C., 2001^61^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Sulaiman N. D., 2010^93^ | N/A | N/A | N/A | N/A | P | N/A | N/A | N/A
Thyne S.M., 2007^52^ | N/A | P | S | N/A | S | N/A | N/A | N/A
To T., 2008^86^ | P | N/A | N/A | N/A | S | N/A | N/A | N/A
Veninga CCM, 1999^53^ | N/A | N/A | P | N/A | N/A | S | N/A | N/A
Veninga CCM, 2000^58^ | N/A | N/A | P | N/A | S | N/A | N/A | N/A
Weinberger M, 2002^99^ | N/A | N/A | S | P | N/A | S | N/A | N/A
Yawn BP, 2008^64^ | N/A | N/A | N/A | N/A | N/A | N/A | P | N/A

N/A = not applicable; P = primary intervention; S = secondary intervention(s)

In terms of outcomes (both health care process and clinical), there was significant variability in the frequency of outcome evaluation. Among the health care process measures, prescriptions of controller medicines were by far the most commonly evaluated, followed by asthma action plan/self-management education, then prescription of peak flow meters. Relatively understudied were processes related to documentation of asthma control/severity, environmental control practices and scheduling of followup visits. All of these are asthma care processes recommended in asthma guidelines, and known to be uncommonly practiced and documented. Therefore, future studies should focus more on how to improve these health care practices. In terms of clinical outcomes, we also observed unequal frequencies of study evaluation, with the most common outcomes being emergency department visits and hospitalizations, and infrequent evaluations of lung function, missed school/work, symptom-free days and quality of life. These understudied outcomes should be a focus of future studies of health care provider-targeted interventions.

Key Question 1 was the most completely addressed for the outcomes included in this report, particularly in terms of prescribing asthma controller medications. Key Question 2 was only partially addressed, as very few studies examined missed school or work as an outcome. Importantly, for Key Question 3, we found no studies that linked changes in health care provider behavior to changes in clinical outcomes among patients with asthma. More specifically, no studies measured the strength of association between behavior changes and clinical outcomes (e.g., percent predicted values; logistic regression). Having data on the associations between provider behavior and clinical outcomes would be important in understanding which changes in specific health care provider behaviors would be most beneficial in focusing on to improve patient outcomes. Standards of asthma care, such as guideline-based care based on national guidelines or health insurance payers, would be more meaningful if it was known to what extent given changes in health care provider behavior meaningfully effect changes in clinical outcomes. Future studies that examine this association between provider behavior and patient outcomes would be beneficial to a variety of stakeholders, including clinical experts creating future guidelines (to highlight best practices), funding agencies (to support unaddressed areas of research) and policymakers (who may also be interested in identifying the best evidence-based practices for providers to follow).

From a study design standpoint, approximately half of the studies used a nonrandomized design, weakening the strength of evidence for a number of interventions. If taken in the context of a need for more systems-level interventions, cluster randomized trials would be a suitable design to evaluate interventions while limiting the risk for contamination bias and improving the precision of the findings. Given the more costly nature of these study designs, funding agencies will need to appropriately support these types of intervention studies. Additionally, testing the efficacy of the more potent multifaceted interventions with targeted populations (i.e., adolescents, obese patients, high asthma severity, or high health care utilizers) may lead to identification of novel preventive and therapeutic strategies for high risk patients that would improve health care provider adherence to national asthma guidelines.

In terms of asthma guideline recommendations for care, we attempted to include all of the health care processes recommended in those documents. The National Asthma Education and Prevention Program (NAEPP) has promoted six specific elements of care through the Guideline Implementation Panel (GIP): use inhaled corticosteroids as the preferred controller medicine; use asthma action plans; determine asthma severity; determine asthma control; schedule follow-up visits; and control allergen and irritant exposures. In this report, we examined two of these six recommended areas of care including use of inhaled corticosteroids and use of asthma action plans. The remaining areas designated by GIP merit future research.

A number of studies were tested in busy primary care settings, suggesting that these interventions could be implementable by busy health care providers. However, harm was generally not measured in the studies we reviewed (only one study reported an unintended harm). Given that few studies reported on the frequency and intensity of exposure to the intervention, there is little evidence available to estimate the likelihood of sustainable implementation of these interventions into routine clinical practices. More specifically, issues of time constraints, work flow considerations and limited resources were not addressed in these studies, so we cannot be sure that these interventions can be translated into clinical practice without significant modification.

Many studies utilized a variety of health care providers, so generalizability of health care provider types is a strength. Although these studies included nurse practitioners and other mid-level/ancillary providers, there were few that were directed specifically at these providers necessitating additional interventions targeting these health care provider populations. In addition, cost implications of specific interventions may be associated with reduced use but was not addressed in this report. Lastly, relatively few studies targeted health care providers known to care for patient populations at risk for poor care and/or poor outcomes. Targeting such settings for future studies would be valuable, as there may be unique conditions to address in those settings, these patients may account for significant costs to the health care system, and these settings may be in the greatest need of assistance in improving asthma care outcomes.

## Conclusions

In conclusion, there is some evidence to support the use of decision support tools, feedback and audit, and clinical pharmacy support interventions to improve the adherence of health care providers to prescribing asthma controller medicines and to reduce ED visits/hospitalizations. However, we found an insufficient level of evidence to evaluate the effectiveness of a number of interventions. This was attributable to a number of factors, including heterogeneity in interventions, variability in approaches to measuring outcomes, and a relative paucity of studies utilizing rigorous study designs (particularly randomized controlled trials). Therefore, there is a need to further evaluate other types of health care provider-targeted interventions (e.g., multimodal) and other health care process or clinical outcomes (e.g., missed days of work/school). There is also a significant need to focus on standardized measures of outcomes and more rigorous study designs.