# Evidence Tables

The following studies were grouped together: Haymore 2005 & Herborg 2011; Lozano 2004 & Finkelstein 2005; Cloutier 2005 & Cloutier 2009

Evidence Table 1 Study characteristics of all included studies

Evidence Table 2 Healthcare provider characteristics

Evidence Table 3 Patient characteristics

Evidence Table 4 Intervention characteristics

Evidence Table 5 Clinical Outcomes Baseline and End of Treatment

Evidence Table 6 Healthcare process outcomes: Baseline and end of treatment

Evidence Table 7 Mean difference between groups- Clinical outcomes

Evidence Table 8 Mean difference between groups- Healthcare process outcomes

Evidence Table 9 Mean difference within groups- Clinical outcomes

Evidence Table 10 Mean difference within groups- Healthcare process outcomes

Evidence Table 11 Risk of bias