# Excluded Studies

Appendix D lists studies that were excluded from this review, categorized by reason for exclusion and alphabetized.

## No Original Data

Advocate's disease management program reduces readmissions for CHF and asthma. Performance improvement advisor. 2003;7(3):44-47. [pmid: 12741043].
Al-Moamary M. Annals of Thoracic Medicine… a three-year journey. Annals of Thoracic Medicine. 2009;4(1):1-2. [pmid: 19561912].
Al-Mobeireek A, Dashash NA. Prescribing for asthmatic children in primary care. Are we following the guidelines?. (multiple letters). Saudi Medical Journal. 2003;24(11):1274. [pmid: 14647574].
Anhoj J, Nielsen L. Quantitative and qualitative usage data of an Internet-based asthma monitoring tool. J Med Internet Res. 2004;6(3):e23. [pmid: 15471749].
Anthonisen NR. Database epidemiology. Canadian Respiratory Journal. 2009;16(6):181-182. [pmid: 20011724].
Bai TR. Do written self-management plans improve asthma control? The evidence is not conclusive. Canadian Respiratory Journal. 2003;10(3):155-156. [pmid: 12712226].
Bauman AE, Fardy HJ, Harris PG. Getting it right: Why bother with patient-centred care?. Medical Journal of Australia. 2003;179(5):253-256. [pmid: 12924973].
Beilby JJ, Glasgow NJ, Fardy HJ. The way forward: the International Primary Care Respiratory Group. 2nd World Conference. Melbourne. 19-22 February 2004. Med J Aust. 2004;181(2):67-8.
Benchmarking children's hospitals improves asthma home management. Healthcare Benchmarks Qual Improv. 2009;16(10):109-13. [pmid: 19769322].
Brown HJ, Miles PV. “Guidelines” for Guideline Implementation. Journal of Pediatrics. 2009;154(6):784-785. [pmid: 19446094].
Burrill R, Carroll W. Towards evidence based medicine for paediatricians: Question 3 - Do written asthma action plans reduce hospital admissions?. Archives of Disease in Childhood. 2009;94(9):742-743. [pmid: 19700432].
Cabana MD, Lewis TC. Improving physician adherence to asthma guidelines. J Clin Outcomes Manag. 2001;8(3):35-46.
Campbell J, Campbell S, Woodward G. Getting evidence into practice using an asthma desktop tool. Aust Fam Physician. 2006;35(1-2):32-3. [pmid: 16489383].
Cartier A. Thanks to a plan of action, the general practitioner can better follow the evolution of asthma, a fluctuating disease, and the unforeseen recrudescences. L'Union Médicale du Canada. 494. 1991;120(6):491-497.
Chang AB. American College of Chest Physicians cough guidelines for children: Can its use improve outcomes?. CHEST. 2008;134(6):1111-1112. [pmid: 19059951].
Chen S, Coffey S, Peisachovich E, et al. Implementing best practice guidelines onto personal digital assistants: Preliminary results and lessons learned. Journal on Information Technology in Healthcare. 2008;6(1):33-41.
Cho SH. How to organize cost-effective care for asthma patients. Respirology. 2009;14:A104.
Chong E. Pharmacist-specific summary of adult asthma guidelines. Canadian Pharmacists Journal. 2007;140(SUPPL. 3):S12-S17.
Chrystyn H. Community care of asthma: The pharmacist as counsellor?. Journal of Pharmacy and Pharmacology. 1997;49(SUPPL. 3):51-54. [pmid: 9178208].
Cicutto L. Supporting successful asthma management in schools: The role of asthma care providers. Journal of Allergy and Clinical Immunology. 2009;124(2):390-393. [pmid: 19541361].
Corjulo MT. Telephone triage for asthma medication refills. Pediatric Nursing. 2005;31(2):116-120. 124. [pmid: 15934564].
Crockett A, Leonard A. Local asthma guidelines can help reduce hospital admissions. Asthma Journal. 2001;6(1):31-34.
Dean M. Implementing the 1998 Canadian asthma guidelines. Canadian family physician M?decin de famille canadien. 2000;46:761-762. 768. 770.
DiCenso A, Virani T, Bajnok I, et al. A toolkit to facilitate the implementation of clinical practice guidelines in healthcare settings. Hospital quarterly. 2002;5(3):55-60. [pmid: 12055868].
D'Urzo AD, Tamari I, Bouchard J, et al., Jugovic. Limitations of a spirometry interpretation algorithm. Canadian Family Physician. 2011;57(10):1153-1156. [pmid: 21998232].
Eccles M, Grimshaw J, Steen N, Parkin D, Purves I, McColl E, Rousseau N. The design and analysis of a randomized controlled trial to evaluate computerized decision support in primary care: The COGENT study. Family Practice. 2000;17(2):180-186. [pmid: 10758083].
Eccles M, McColl E, Steen N, et al. Computerised evidence-based guidelines may not improve asthma or angina management in primary care. Evidence-Based Healthcare. 2003;7(2):81-82.
Einterz EM. Apollo at the front. Lancet. 2005;365(9477):2147-2148. [pmid: 15964453].
Emery JD, Purves IN, Beaumont R, et al., Parkin. Effect of computerised evidence based guidelines [3]. British Medical Journal. 2003;326(7385):394-396. [pmid: 12586680].
English RG, Fairall LR, Bateman ED. Keeping allergy on the agenda: integrated guidelines for respiratory disease in developing countries. Allergy. 2007;62(3):224-9. [pmid: 17298338].
Fardy HJ. The 3+ plan for asthma management. Aust Fam Physician. 1999;28(2):95. [pmid: 10048243].
Feifer RA, Verbrugge RR, Khalid M, et al. Improvements in asthma pharmacotherapy and self-management: an example of a population-based disease management program. Disease Management & Health Outcomes. 2004;12(2):93-102.
Global initiative for asthma: Global strategy for asthma management and prevention. Global Initiative for Asthma. 2002.
Hayes E, Djaferis M, Gattasso S, et al. Documenting to improve pediatric asthma outcomes: practical tools for nurse practitioners. Advance for nurse practitioners. 2004;12(9):51-53. 55. 56. [pmid: 15473449].
Heale J, Davis D, Norman G, et al. A randomized controlled trial assessing the impact of problem-based versus didactic teaching methods in CME. Proceedings of the . Annual Conference on Research in Medical Education. Conference on Research in Medical Education. 1988;27:72-77.
Lack of self-efficacy keeps inner-city primary care providers from following national asthma management guidelines. AHRQ Research Activities. 2009;(345):15-15.
Li JT, Oppenheimer J, Bernstein IL, et al. Attaining optimal asthma control: A practice parameter. Journal of Allergy and Clinical Immunology. 2005;116(5):S3-S11. [pmid: 16334921].
Loymans R, ter Riet G, Sterk PJ. Assessing primary care physicians' beliefs and attitudes of asthma exacerbation treatment and follow-up. Open Respiratory Medicine Journal. 2011;5(1):10. [pmid: 21503264].
Mansour ME. How do we support follow-up with the primary care provider after an emergency department visit for asthma?. Pediatrics. 2009;124(4):1206-7. [pmid: 19770174].
Marshik PL. Pharmacologic treatment of pediatric asthma. Consider disease severity as well as delivery method. Adv Nurse Pract. 2004;12(3):35-6. 41. 6. [pmid: 15038183].
McDermott MF, Walter J, Catrambone C, et al. The Chicago Emergency Department Asthma Collaborative. CHEST. 1999;116(4 SUPPL. 1):196S-197S. [pmid: 10532486].
McIvor A, Hodder R. Canadian Adult Asthma Update 2008 key messages: a focus on translating knowledge into action in primary care. Can Respir J. 2008;15(3):121-2. [pmid: 18478650].
McLean WM, MacKeigan LD. When does pharmaceutical care impact health outcomes? A comparison of community pharmacy-based studies of pharmaceutical care for patients with asthma. Annals of Pharmacotherapy. 2005;39(4):625-631. [pmid: 15741416].
Meadows M. Breathing better: action plans keep asthma in check. FDA Consumer. 2003;37(2):20-27.
Metzger WJ. The asthma guidelines: Implications for the practicing physician. American Family Physician. 1992;46(4):1060-1062.
Meyer H. Targeted Care Improvements Show Promising Results For Treating Children With Asthma. Health Affairs. 2011;30(3):404-407. [pmid: 21383352].
Mihaltan F. Asthma--between “control” and “severity”. Pneumologia. 2008;57(4):192-3. [pmid: 19186680].
Modell M, Iliffe S, Austin A, Leaning MS. From guidelines to decision support in the management of asthma. Stud Health Technol Inform. 1995;16:105-13. [pmid: 10163705].
Oppedisano R, Kavuru MS. Asthma patient education: a primer for the primary care physician. Compr Ther. 1996;22(11):695-702. [pmid: 8978975].
Partridge MR. Introduction to the Global Initiative for Asthma and the new guidelines. West Indian Med J. Suppl 7. 2003;52:6-9. [pmid: 15042755].
Partridge MR. The implementation of asthma guidelines in general practice. Respir Med. 1997;91(10):575-7. [pmid: 9488888].
Philpot EE, Kwasnicki JM. The impact of the NHLBI guidelines on asthma management in the prescribing habits of physicians at two community hospitals. J Allergy Clin Immunol. 1993;91.
Rance K, Trent C. Broccoli and pixie stix. Profile of a pediatric asthma program. Adv Nurse Pract. 2004;12(3):47-8. [pmid: 15038184].
Reed CE. Inhaled corticosteroids: why do physicians and patients fail to comply with guidelines for managing asthma?. Mayo Clin Proc. 2004;79(4):453-5. [pmid: 15065608].
Roberts DH, Gilmartin GS, Neeman N, et al. Design and measurement of quality improvement indicators in ambulatory pulmonary care: Creating a “culture of quality” in an academic pulmonary division. CHEST. 2009;136(4):1134-1140. [pmid: 19809055].
Schonberger HJAM, Van Schayck CP. Prevention of asthma in genetically predisposed children in primary care - From clinical efficacy to a feasible intervention programme. Clinical and Experimental Allergy. 1998;28(11):1325-1331. [pmid: 9824403].
Scullion JE. A specialist nurse led liaison model of care reduced unscheduled care for acute asthma in a deprived multiethnic area. Evidence Based Nursing. 2004;7(3):77-77. [pmid: 15252905].
Self TH, Kelso TM, Abou-Shala N, et al. Clinical pharmacist initiated programs for improving outcomes in adult. African American asthmatics. 1992.
Sladek K. Education program in asthma. Pneumonol Alergol Pol. Suppl 1. 2002;70:87-90. [pmid: 12518647].
Soumerai SB, Majumdar SR, Lipton HL. Evaluating and improving physician prescribing. Pharmacoepidemiology. 2000:483-503.
Specialized asthma unit improves care, cuts costs. Health Care Cost Reengineering Rep. 1998;3(7):97-101. [pmid: 10182020].
Thomson MA, O'Brien AD, Oxman DA, et al. Educational outreach visits: Effects on professional practice and health care outcomes. Educational Outreach Visits: Effects on Professional Practice and Health Care Outcomes. 2000.
Two approaches toward systematic change boost asthma care. Dis Manag Advis. 2005;11(1):4-8. 1. [pmid: 15766056].
Van Rees-Wortelboer MM. The Stimulation Program Health Examination. VII. Evaluation of the part on ‘General Practice and CARA’ Nederlands. Tijdschrift voor Geneeskunde. 1996;140(12):672-675.
Weinberger MM. What is the problem with asthma care for children?. Arch Pediatr Adolesc Med. 2011;165(5):473-5. [pmid: 21536964].
Weir SS. Disease management in primary care: rapid cycle quality improvement of asthma care. N C Med J. 2005;66(3):221-2. [pmid: 16130948].
Williams D, Portnoy JM, Meyerson K. Strategies for improving asthma outcomes: a case-based review of successes and pitfalls. J Manag Care Pharm. 2010;16(1 Suppl C):S3-14. quiz S16-7. [pmid: 20146547].
Wroth TH, Boals JC. 4th Application of quality-improvement methods in a community practice: the Sandhills Pediatrics Asthma Initiative. North Carolina medical journal. 2005;66(3):218-220. [pmid: 16130947].
Yawn BP. Participatory research in rural primary care. Minn Med. 2004;87(9):52-4. [pmid: 15495878].
Zeitz HJ, Davis WJ, Kniker WT, et al. Problem-based learning (PBL) for asthma continuing medical education (CME). Ann Allergy Asthma Immunol. 1996;76:121.

## Non-English

Andersen M, Kragstrup J, Sorensen J. How participation in a clinical trial affects doctors' choice of treatment. Ugeskr Laeger. 2006;168(46):3987-91. [pmid: 17125649].
Eimers M, Van Der Aalst A, Pelzer B, Teichert M, De Wit H. Does a good PTAM lead to improved prescribing?. Huisarts en Wetenschap. 2008;51(7):340-345.
Geijer RMM, Van Hensbergen W, Bottema BJAM, et al. Standard for the treatment of asthma in adults of the Dutch Association for General Practitioners. Huisarts en Wetenschap. 2001;44(4):153-164.
Geraedts M, Selbmann HK, Meisner C. Effects of a regional intervention to promote asthma guidelines implementation. Gesundheitswesen. 2002;64(5):235-41. [pmid: 12007064].
Gillissen A, Worth H. New paradigm in asthma management. MMW Fortschr Med. 2010;152(11):33-4. [pmid: 20394153].
Kaufmann-Kolle P, Szecsenyi J, Broge B, Haefeli WE, Schneider A. Does implementation of benchmarking in quality circles improve the quality of care of patients with asthma and reduce drug interaction?. Zeitschrift fur Evidenz Fortbildung und Qualitat im Gesundheitswesen. 2011;105(5):389-395.
Kull I, Johansson GS, Lisspers K, Jagorstrand B, Romberg K, Tilling B, Stallberg B. Efficient care in asthma/COPD primary health care clinics. Lakartidningen. 2008;105(42):2937-40. [pmid: 19025151].
Launois R, Megnigbeto AC, Perez V, Roy M, Camus A, Gailhardou M, Lancon F, Queniart M. A disease management program in France: Lessons from the RESALIS experiment before and after public health interventions. Journal d'Economie Medicale. 2002;20(6):333-352.
Plaza V, Cobos A, Ignacio-Garcia JM, Molina J, Bergonon S, Garcia-Alonso F, Espinosa C. Cost-effectiveness of an intervention based on the Global INitiative for Asthma (GINA) recommendations using a computerized clinical decision support system: a physicians randomized trial. Med Clin (Barc). 2005;124(6):201-6. [pmid: 15737299].
Ruiz Espiricueta JE, Gonzalez Diaz SN, Rodriguez GG, Cruz AA, Canseco Villarreal C, Valdez Ramirez MA. Assessment of an educational course on asthma for primary care physicians. Rev Alerg Mex. 2005;52(2):83-9. [pmid: 16158781].
Schauerte G, Laub O, Hohre H, Schwab S, Unverdorben M, Bredl C, Schober M, Lecheler J. Healthcare program for children with bronchial asthma. Atemwegs- und Lungenkrankheiten. 2009;35(9):379-387.
Scriba PC, Fuchs C. Health services research: Trend-setting promotional initiative. Deutsches Arzteblatt. 2010;107(17):A812-A816.
Segura Mendez NH, Herrera S, Hernandez Martinez E, Torres Salazar A, Espinola Reyna G, del Rivero Hernandez L. Application of the International Guide for the Diagnosis and Treatment of Asthma using first-contact physicians, before and after an educational strategy. Rev Alerg Mex. 2003;50(3):83-5. [pmid: 12940106].
Sladek K. Education program in asthma. Pneumonol Alergol Pol. Suppl 1. 2002;70:87-90. [pmid: 12518647].
Van Rees-Wortelboer MM. The Stimulation Program Health Examination. VII. Evaluation of the part on ‘General Practice and CARA’ Nederlands. Tijdschrift voor Geneeskunde. 1996;140(12):672-675.
Warlies F, Saladin M. The outcome of the train-the-trainer seminars arranged by the “Work Team Patients Education” for instructing adult patients with chronic obstructive pulmonary diseases (asthma and COPD). Atemwegs- und Lungenkrankheiten. 2005;31(10):510-522.

## Does not Address Asthma

Camacho M, Nogales M, Manjon R, Del Granado M, Pio A, Ottmani S. Results of PAL feasibility test in primary health care facilities in four regions of Bolivia. International Journal of Tuberculosis and Lung Disease. 2007;11(11):1246-1252. [pmid: 17958989].
Jans MP, Schellevis FG, Van Hensbergen W, van Eijk JT. Improving general practice care of patients with asthma or chronic obstructive pulmonary disease: evaluation of a quality system. Eff Clin Pract. 2000;3(1):16-24. [pmid: 10788032].
Jiwa M, Hughes J, Sriram D, et al. Piloting and validating an innovation to triage patients presenting with cough to community pharmacies in Western Australia. Quality in Primary Care. 2012;20(2):83-91.
Jones RCM, Copper S. Does implementing COPD guidelines improve patient care and save money in practice?. Asthma in General Practice. 1999;7(1):12-15.
Kuilboer MM, van Wijk MA, Mosseveld M, van der Does E, de Jongste JC, Overbeek SE, Ponsioen B, van der Lei J. Computed critiquing integrated into daily clinical practice affects physicians' behavior--a randomized clinical trial with AsthmaCritic. Methods Inf Med. 2006;45(4):447-54. [pmid: 16964364].
Levac KA. Putting outcomes into practice in physician offices. J Nurs Care Qual. 2002;17(1):51-62. quiz 90. [pmid: 12369748].
Meulepas MA, Jacobs JE, Smeenk FW, Smeele I, Lucas AE, Bottema BJ, Grol RP. Effect of an integrated primary care model on the management of middle-aged and old patients with obstructive lung diseases. Scand J Prim Health Care. 2007;25(3):186-92. [pmid: 17846938].
Newton-Syms FAO, Dawson PH, Cooke J, et al. The influence of an academic representative on prescribing by general practitioners. British Journal of Clinical Pharmacology. 1992;33(1):69-73. [pmid: 1540493].
Ornstein SM, Jenkins RG, MacFarlane L, Glaser A, Snyder K, Gundrum T. Electronic medical records as tools for quality improvement in ambulatory practice: theory and a case study. Top Health Inf Manage. 1998;19(2):35-43. [pmid: 10338712].
Rascati KL, Okano GJ, Burch C. Evaluation of Physician Intervention Letters. Medical Care. 1996;34(8):760-766. [pmid: 8709658].
Roberts DH, Gilmartin GS, Neeman N, et al. Design and measurement of quality improvement indicators in ambulatory pulmonary care: Creating a “culture of quality” in an academic pulmonary division. CHEST. 2009;136(4):1134-1140. [pmid: 19809055].
Stange KC, Goodwin MA, Zyzanski SJ, et al., Dietrich. Sustainability of a practice-individualized preventive service delivery intervention. American Journal of Preventive Medicine. 2003;25(4):296-300. [pmid: 14580630].
Tierney WM, Overhage JM, Murray MD, Harris LE, Zhou XH, Eckert GJ, Smith FE, Nienaber N, McDonald CJ, Wolinsky FD. Can computer-generated evidence-based care suggestions enhance evidence-based management of asthma and chronic obstructive pulmonary disease? A randomized, controlled trial. Health Serv Res. 2005;40(2):477-97. [pmid: 15762903].

## Addressed Inpatient or Emergency Care Only

Benchmarking children's hospitals improves asthma home management. Healthcare Benchmarks Qual Improv. 2009;16(10):109-13. [pmid: 19769322].
Chandler T. Reducing re-admission for asthma: impact of a nurse-led service. Paediatr Nurs. 2007;19(10):19-21. [pmid: 18196853].
Davies B, Edwards N, Ploeg J, Virani T. Insights about the process and impact of implementing nursing guidelines on delivery of care in hospitals and community settings. BMC Health Serv Res. 2008;8:29. [pmid: 18241349].
Doherty SR, Jones PD. Use of an ‘evidence-based implementation’ strategy to implement evidence-based care of asthma into rural district hospital emergency departments. Rural and remote health. 2006;(1):529. [pmid: 16569189].
Hadjianastassiou VG, Karadaglis D, Gavalas M. A comparison between different formats of educational feedback to junior doctors: A prospective pilot intervention study. Journal of the Royal College of Surgeons of Edinburgh. 2001;46(6):354-357. [pmid: 11768577].
Higuchi KS, Davies BL, Edwards N, Ploeg J, Virani T. Implementation of clinical guidelines for adults with asthma and diabetes: a three-year follow-up evaluation of nursing care. J Clin Nurs. 2011;20(9-10):1329-38. [pmid: 21492279].
Kwok R, Dinh M, Dinh D, Chu M. Improving adherence to asthma clinical guidelines and discharge documentation from emergency departments: implementation of a dynamic and integrated electronic decision support system. Emerg Med Australas. 2009;21(1):31-7. [pmid: 19254310].
Mackey D, Myles M, Spooner CH, Lari H, Tyler L, Blitz S, Senthilselvan A, Rowe BH. Changing the process of care and practice in acute asthma in the emergency department: experience with an asthma care map in a regional hospital. CJEM. 2007;9(5):353-65. [pmid: 17935651].
Mason N, Roberts N, Yard N, Partridge MR. Nebulisers or spacers for the administration of bronchodilators to those with asthma attending emergency departments?. Respir Med. 2008;102(7):993-8. [pmid: 18396026].
Masters G, Hall SE, Phillips M, Boldy D. Outcomes measurement for asthma following acute presentation to an emergency department. Aust Health Rev. 2001;24(3):53-60. [pmid: 11668926].
Specialized asthma unit improves care, cuts costs. Health Care Cost Reengineering Rep. 1998;3(7):97-101. [pmid: 10182020].
Wazeka A, Valacer DJ, Cooper M, Caplan DW, DiMaio M. Impact of a pediatric asthma clinical pathway on hospital cost and length of stay. Pediatr Pulmonol. 2001;32(3):211-6. [pmid: 11536450].
Webb LZ, Kuykendall DH, Zeiger RS, Berquist SL, Lischio D, Wilson T, Freedman C. The impact of status asthmaticus practice guidelines on patient outcome and physician behavior. QRB Qual Rev Bull. 1992;18(12):471-6. [pmid: 1287531].
Wright SW, Trott A, Lindsell CJ, Smith C, Gibler WB. Evidence-based emergency medicine. Creating a system to facilitate translation of evidence into standardized clinical practice: a preliminary report. Ann Emerg Med. 2008;51(1):80-6. 86.e1. 8. [pmid: 17719134].

## Does not Target Health Care Providers

Baker D, Middleton E, Campbell S. The impact of chronic disease management in primary care on inequality in asthma severity. J Public Health Med. 2003;25(3):258-60. [pmid: 14575205].
Blenkinsopp A, Holmes J, Mitra G, Pringle M. Joining up self-care: Evaluation of a PCT-wide programme of support for self-care. Primary Health Care Research and Development. 2009;10(2):83-97.
Bunting BA, Cranor CW. The Asheville Project: Long-term clinical, humanistic, and economic outcomes of a community-based medication therapy management program for asthma. Journal of the American Pharmacists Association. 2006;46(2):133-147. [pmid: 16602223].
Cabana MD, Chaffin DC, Jarlsberg LG, Thyne SM, Clark NM. Selective provision of asthma self-management tools to families. Pediatrics. 2008;121(4):e900-e905. [pmid: 18381518].
Chamnan P, Boonlert K, Pasi W, Yodsiri S, Pong-on S, Khansa B, Yongkulwanitchanan P. Implementation of a 12-week disease management program improved clinical outcomes and quality of life in adults with asthma in a rural district hospital: pre- and post-intervention study. Asian Pac J Allergy Immunol. 2010;28(1):15-21. [pmid: 20527511].
Delaronde S, Peruccio DL, Bauer BJ. Improving asthma treatment in a managed care population. American Journal of Managed Care. 2005;11(6):361-368. [pmid: 15974555].
Dickinson J, Hutton S, Atkin A. Implementing the British Thoracic Society's guidelines: The effect of a nurse-run asthma clinic on prescribed treatment in an English general practice. Respiratory Medicine. 1998;92(2):264-267. [pmid: 9616523].
D'Urzo AD, Tamari I, Bouchard J, Jhirad R, Jugovic P. Limitations of a spirometry interpretation algorithm. Canadian Family Physician. 2011;57(10):1153-1156. [pmid: 21998232].
Hartmann CW, Sciamanna CN, Blanch DC, Mui S, Lawless H, Manocchia M, Rosen RK, Pietropaoli A. A website to improve asthma care by suggesting patient questions for physicians: Qualitative analysis of user experiences. Journal of Medical Internet Research. 2007;9(1):1-12.
Higgins JC, Kiser WR, McClenathan S, Tynan NL. Influence of an interventional program on resource use and cost in pediatric asthma. Am J Manag Care. 1998;4(10):1465-9. [pmid: 10338738].
Lind A, Kaplan L, Berg GD. Evaluation of an asthma disease management program in a medicaid population. Disease Management and Health Outcomes. 2006;14(3):151-161.
Lougheed MD, Moosa D, Finlayson S, Hopman WM, Quinn M, Szpiro K, Reisman J. Impact of a provincial asthma guidelines continuing medical education project: The Ontario Asthma Plan of Action's Provider Education in Asthma Care Project. Canadian Respiratory Journal. 2007;14(2):111-117. [pmid: 17372639].
Morell F, Genover T, Reyes L, Benaque E, Roger A, Ferrer J. Monitoring of asthma outpatients after adapting treatment to meet international guidelines. Arch Bronconeumol. 2007;43(1):29-35. [pmid: 17257561].
Pinnock H, Adlem L, Gaskin S, Harris J, Snellgrove C, Sheikh A. Accessibility, clinical effectiveness, and practice costs of providing a telephone option for routine asthma reviews: phase IV controlled implementation study. Br J Gen Pract. 2007;57(542):714-22. [pmid: 17761059].
Rimington LD, Pearson MG. Asthma management in primary care: does increasing patient medication improve symptoms?. Clin Respir J. 2008;2(2):92-7. [pmid: 20298313].
Ruoff G. Effects of flow sheet implementation on physician performance in the management of asthmatic patients. Fam Med. 2002;34(7):514-7. [pmid: 12144005].
Schauerte G, Fendel T, Schwab S, Bredl C. Children with bronchial asthma: effects of an integrated health-care programme. Pneumologie. 2010;64(2):73-80. [pmid: 20143280].
Windt R, Glaeske G. Effects of a German asthma disease management program using sickness fund claims data. Journal of Asthma. 2010;47(6):674-679. [pmid: 20632918].

## Intervention does not Address Adherence or Behavior of Health Care Providers

Abramson MJ, Schattner RL, Sulaiman ND, Birch KE, Simpson PP, Del Colle EA, Aroni RA, Wolfe R, Thien FCK. Do spirometry and regular follow-up improve health outcomes in general practice patients with asthma or COPD? A cluster randomised controlled trial. Medical Journal of Australia. 2010;193(2):104-109. [pmid: 20642418].
Adler RN, McBride J. Tools and strategies for improving asthma management. Fam Pract Manag. 2010;17(1):16-21. [pmid: 20092231].
Advocate's disease management program reduces readmissions for CHF and asthma. Performance improvement advisor. 2003;7(3):44-47. [pmid: 12741043].
Andersen M, Kragstrup J, Sondergaard J. How conducting a clinical trial affects physicians' guideline adherence and drug preferences. JAMA. 2006;295(23):2759-64. [pmid: 16788131].
Andrews T, Banks JR. Achieving and Maintaining asthma control in an urban pediatric disease management program: The breathmobile program. Pediatrics. 2008;122(SUPPL. 4):S209-S210.
Anthonisen NR. Database epidemiology. Canadian Respiratory Journal. 2009;16(6):181-182. [pmid: 20011724].
Barbanel D, Eldridge S, Griffiths C. Can a self-management programme delivered by a community pharmacist improve asthma control? A randomised trial. Thorax. 2003;58(10):851-854. [pmid: 14514935].
Barnes NC, Douglas G, Higgins B. Intermittent use of inhaled corticosteroids for the treatment of mild asthma is not recommended. Prim Care Respir J. 2009;18(4):341-2. author reply 342. [pmid: 19940962].
Bunting BA, Cranor CW. The Asheville Project: Long-term clinical, humanistic, and economic outcomes of a community-based medication therapy management program for asthma. Journal of the American Pharmacists Association. 2006;46(2):133-147. [pmid: 16602223].
Cabana MD, Chaffin DC, Jarlsberg LG, Thyne SM, Clark NM. Selective provision of asthma self-management tools to families. Pediatrics. 2008;121(4):e900-e905. [pmid: 18381518].
Campbell J, Campbell S, Woodward G. Getting evidence into practice using an asthma desktop tool. Aust Fam Physician. 2006;35(1-2):32-3. [pmid: 16489383].
Capen CL, Sherman JM. Fatal asthma in children: a nurse managed model for prevention. Journal of pediatric nursing. 1998;13(6):367-375. [pmid: 9879173].
Chandler T. Reducing re-admission for asthma: impact of a nurse-led service. Paediatr Nurs. 2007;19(10):19-21. [pmid: 18196853].
Clark NM, Gong M, Schork MA, Kaciroti N, Evans D, Roloff D, Hurwitz M, Maiman LA, Mellins RB. Long-term effects of asthma education for physicians on patient satisfaction and use of health services. Eur Respir J. 2000;16(1):15-21. [pmid: 10933079].
Cloutier MM, Hall CB, Rowe T. Easy Breathing: An asthma management program for inner city children. Am J Resp Crit Care Med. 2000;161.
Cloutier MM, Wakefield DB, Tsimikas J, Hall CB, Tennen H, Brazil K. Organizational Attributes of Practices Successful at a Disease Management Program. Journal of Pediatrics. 2009;154(2):290-295. [pmid: 18835488].
Cloutier MM, Wakefield DB, Sangeloty-Higgins P, Delaronde S, Hall CB. Asthma guideline use by pediatricians in private practices and asthma morbidity. Pediatrics. 2006;118(5):1880-1887. [pmid: 17079558].
Cloutier MM, Wakefield DB, Sangeloty-Higgins P, Delaronde S, Hall CB. Asthma guideline use by pediatricians in private practices and asthma morbidity. Pediatrics. 2006;118(5):1880-7. [pmid: 17079558].
Cockcroft DW, Swystun VA. Asthma control versus asthma severity. Journal of Allergy and Clinical Immunology. 1996;98(6 I):1016-1018. [pmid: 8977499].
Coleman CI, Reddy P, Laster-Bradley NM, Dorval S, Munagala B, White CM. Prescriber and pharmacist responses to intervention letters for Connecticut Medicaid beneficiaries with asthma. American Journal of Health-System Pharmacy. 2003;60(11):1142-1144. [pmid: 12816025].
Collins TM, Mott DA, Bigelow WE, Zimmerman DR. A controlled letter intervention to change prescribing behavior: Results of a dual-targeted approach. Health Services Research. 1997;32(4):471-489. [pmid: 9327814].
Crockett A, Leonard A. Local asthma guidelines can help reduce hospital admissions. Asthma Journal. 2001;6(1):31-34.
Dales RE, Vandemheen KL, Clinch J, Aaron SD. Spirometry in the primary care setting: Influence on clinical diagnosis and management of airflow obstruction. CHEST. 2005;128(4):2443-2447. [pmid: 16236907].
Dean M. Implementing the 1998 Canadian asthma guidelines. Canadian family physician M?decin de famille canadien. 2000;46:761-762. 768. 770.
Del Colle E, Green J, Adikari A, Schattner R, Simpson P, Wolfe R, Sulaiman N, Abramson M, Thien F. Regular spirometry with medical review is not associated with improvement in lung function in general practice. Respirology. 2010;15:A9.
Delaronde S, Peruccio DL, Bauer BJ. Improving asthma treatment in a managed care population. American Journal of Managed Care. 2005;11(6):361-368. [pmid: 15974555].
Emmerton L, Shaw J, Kheir N. Asthma management by New Zealand pharmacists: A pharmaceutical care demonstration project. Journal of Clinical Pharmacy and Therapeutics. 2003;28(5):395-402. [pmid: 14632964].
English RG, Fairall LR, Bateman ED. Keeping allergy on the agenda: integrated guidelines for respiratory disease in developing countries. Allergy. 2007;62(3):224-9. [pmid: 17298338].
Feifer RA, Verbrugge RR, Khalid M, et al. Improvements in asthma pharmacotherapy and self-management: an example of a population-based disease management program. Disease Management & Health Outcomes. 2004;12(2):93-102.
Gallagher C. Initiating a pediatric office-based quality improvement program. J Healthc Qual. 2001;23(2):4-9. quiz 9-10, 52. [pmid: 11257800].
Goyder EC, Blank L, Ellis E, Furber A, Peters J, Sartain K, Massey C. Reducing inequalities in access to health care: Developing a toolkit through action research. Quality and Safety in Health Care. 2005;14(5):336-339. [pmid: 16195566].
Grainger-Rousseau TJ, Mc Elnay JC. A model for community pharmacist involvement with general practitioners in the management of asthma patients. Journal of Applied Therapeutics. 1996;1(2):145-161.
Grainger-Rousseau TJ, Miralles MA, Hepler CD, Segal R, Doty RE, Ben-Joseph R. Therapeutic outcomes monitoring: application of pharmaceutical care guidelines to community pharmacy. J Am Pharm Assoc (Wash). 1997;NS37(6):647-61. [pmid: 9425794].
Grant R, Bowen SK, Neidell M, Prinz T, Redlener IE. Health care savings attributable to integrating guidelines-based asthma care in the pediatric medical home. J Health Care Poor Underserved. 2010;21(2 Suppl):82-92. [pmid: 20453378].
Guarnaccia S, Lombardi A, Gaffurini A, Chiarini M, Domenighini S, D'Agata E, Schumacher RF, Spiazzi R, Notarangelo LD. Application and implementation of the GINA asthma guidelines by specialist and primary care physicians: a longitudinal follow-up study on 264 children. Prim Care Respir J. 2007;16(6):357-62. [pmid: 18038103].
Hayes E, Djaferis M, Gattasso S, Hosmer T, Williamson K. Documenting to improve pediatric asthma outcomes: practical tools for nurse practitioners. Advance for nurse practitioners. 2004;12(9):51-53. 55. 56. [pmid: 15473449].
Heale J, Davis D, Norman G, Woodward C, Neufeld V, Dodd P. A randomized controlled trial assessing the impact of problem-based versus didactic teaching methods in CME. Proceedings of the . Annual Conference on Research in Medical Education. Conference on Research in Medical Education. 1988;27:72-77.
Higuchi KS, Davies BL, Edwards N, Ploeg J, Virani T. Implementation of clinical guidelines for adults with asthma and diabetes: a three-year follow-up evaluation of nursing care. J Clin Nurs. 2011;20(9-10):1329-38. [pmid: 21492279].
Holt EW, Tan J, Hosgood HD. The impact of spirometry on pediatric asthma diagnosis and treatment. J Asthma. 2006;43(7):489-93. [pmid: 16939987].
Ingemansson M, Jonsson M, Hedlin G. Improving quality of care for children with asthma by learning with an interactive approach: A prospective randomized controlled study in 14 Swedish primary health care centers Allergy. Asthma and Clinical Immunology. 2010;6:9.
Jans MP, Schellevis FG, Van Hensbergen W, van Eijk JT. Improving general practice care of patients with asthma or chronic obstructive pulmonary disease: evaluation of a quality system. Eff Clin Pract. 2000;3(1):16-24. [pmid: 10788032].
Jiwa M, Hughes J, Sriram D, et al. Piloting and validating an innovation to triage patients presenting with cough to community pharmacies in Western Australia. Quality in Primary Care. 2012;20(2):83-91.
Kasiar J, Bonsignore CL, Dennis BH. Assessment of inhaled steroids for asthma patients overusing inhaled albuterol. Hospital Pharmacy. 1998;33(12):1507-1511.
Lack of self-efficacy keeps inner-city primary care providers from following national asthma management guidelines. AHRQ Research Activities. 2009;(345):15-15.
Lagerlov P, Veninga CCM, Muskova M, et al. Asthma management in five European countries: Doctors' knowledge, attitudes and prescribing behaviour. European Respiratory Journal. 2000;15(1):25-29. [pmid: 10678616].
Laurence CO, Beilby J, Campbell S, Campbell J, Ponte L, Woodward G. Process for improving the integration of care across the primary and acute care settings in rural South Australia: asthma as a case study. Aust J Rural Health. 2004;12(6):264-8. [pmid: 15615580].
Le TT, Rait MA, Jarlsberg LG, Eid NS, Cabana MD. A randomized controlled trial to evaluate the effectiveness of a distance asthma learning program for pediatricians. J Asthma. 2010;47(3):245-50. [pmid: 20394510].
Levac KA. Putting outcomes into practice in physician offices. J Nurs Care Qual. 2002;17(1):51-62. quiz 90. [pmid: 12369748].
Lind A, Kaplan L, Berg GD. Evaluation of an asthma disease management program in a medicaid population. Disease Management and Health Outcomes. 2006;14(3):151-161.
Loymans R, ter Riet G, Sterk PJ. Assessing primary care physicians' beliefs and attitudes of asthma exacerbation treatment and follow-up. Open Respiratory Medicine Journal. 2011;5(1):10. [pmid: 21503264].
Ma J, Stafford RS. US physician adherence to standards in asthma pharmacotherapy varies by patient and physician characteristics. J Allergy Clin Immunol. 2003;112(3):633-5. [pmid: 13679830].
Magzamen S, Van Sickle D, Rose LD, Cronk C. Environmental pediatrics. Pediatric Annals. 2011;40(3):144-151. [pmid: 21417205].
Majak P, Bak-Walczak E, Stelmach I, Jerzynska J, Krakowiak J, Stelmach W. An increasing trend of the delay in asthma diagnosis after the discontinuation of a population-based intervention. J Asthma. 2011;48(4):414-8. [pmid: 21504354].
Maslennikova GY, Shmarova LM, Lapidus JA, Oganov RG. Asthma education in Russia: Effectiveness of a training programme for primary-care doctors. Asthma Journal. 2001;6(3):134-138.
McCowan C. The facilitator effect: Results from a four-year follow-up of children with asthma. British Journal of General Practice. 1997;47(416):156-160. [pmid: 9167319].
McIvor A, Hodder R. Canadian Adult Asthma Update 2008 key messages: a focus on translating knowledge into action in primary care. Can Respir J. 2008;15(3):121-2. [pmid: 18478650].
McLean W, Gillis J, Waller R. The BC Community Pharmacy Asthma Study: A study of clinical, economic and holistic outcomes influenced by an asthma care protocol provided by specially trained community pharmacists in British Columbia. Can Respir J. 2003;10(4):195-202. [pmid: 12851665].
Meadows M. Breathing better: action plans keep asthma in check. FDA Consumer. 2003;37(2):20-27.
Mihaltan F. Asthma--between “control” and “severity”]. Pneumologia. 2008;57(4):192-3. [pmid: 19186680].
Morrow R, Fletcher J, Mulvihill M, Park H. The asthma dialogues: a model of interactive education for skills. J Contin Educ Health Prof. 2007;27(1):49-58. [pmid: 17385732].
Murphy KR, Hopp RJ, Kittelson EB, Hansen G, Windle ML, Walburn JN. Life-threatening asthma and anaphylaxis in schools: A treatment model for school-based programs Annals of Allergy. Asthma and Immunology. 2006;96(3):398-405.
Naish J, Eldridge S, Moser K, Sturdy P. Did the London Initiative Zone investment programme affect general practice structure and performance in East London? A time series analysis of cervical screening coverage and asthma prescribing. Public Health. 2002;116(6):361-7. [pmid: 12407476].
Najada A, Abu-Hasan M, Weinberger M. Outcome of asthma in children and adolescents at a specialty-based care program. Ann Allergy Asthma Immunol. 2001;87(4):335-43. [pmid: 11686427].
Neville RG, Hoskins G, McCowan C, Smith B. Pragmatic ‘real world’ study of the effect of audit of asthma on clinical outcome. Primary Care Respiratory Journal. 2004;13(4):198-204.
Newcomb P. Results of an asthma disease management program in an urban pediatric community clinic. J Spec Pediatr Nurs. 2006;11(3):178-88. [pmid: 16774528].
Newton-Syms FAO, Dawson PH, Cooke J, et al. The influence of an academic representative on prescribing by general practitioners. British Journal of Clinical Pharmacology. 1992;33(1):69-73. [pmid: 1540493].
Ogundele M. Challenge of introducing evidence based medicine into clinical practice: An example of local initiatives in paediatrics. Clinical Governance: An International Journal. 2011;16(3):231-249.
O'Laughlen MC, Hollen P, Ting S. An intervention to change clinician behavior: Conceptual framework for the multicolored simplified asthma guideline reminder (MSAGR). J Am Acad Nurse Pract. 2009;21(8):417-22. [pmid: 19689437].
Partridge MR. Introduction to the Global Initiative for Asthma and the new guidelines. West Indian Med J. Suppl 7. 2003;52:6-9. [pmid: 15042755].
Pastor-Sanchez R, Gomez-Escolar CA, De Toledo Saavedra FA, De Cano Martin NF, Martinez AD. Medafar: A coordination strategy study. Pharmacy World and Science. 2009;31(4):505.
Pilotto LS, Smith BJ, Heard AR, McElroy HJ, Weekley J, Bennett P. Trial of nurse-run asthma clinics based in general practice versus usual medical care. Respirology (Carlton, Vic.). 2004;(3):356-62.
Plaza V, Cobos A, Ignacio-Garcia JM, Molina J, Bergonon S, Garcia-Alonso F, Espinosa C. Cost-effectiveness of an intervention based on the Global INitiative for Asthma (GINA) recommendations using a computerized clinical decision support system: a physicians randomized trial. Med Clin (Barc). 2005;124(6):201-6. [pmid: 15737299].
Rascati KL, Okano GJ, Burch C. Evaluation of Physician Intervention Letters. Medical Care. 1996;34(8):760-766. [pmid: 8709658].
Reed CE. Inhaled corticosteroids: why do physicians and patients fail to comply with guidelines for managing asthma?. Mayo Clin Proc. 2004;79(4):453-5. [pmid: 15065608].
Rimington LD, Pearson MG. Asthma management in primary care: does increasing patient medication improve symptoms?. Clin Respir J. 2008;2(2):92-7. [pmid: 20298313].
Ruiz Espiricueta JE, Gonzalez Diaz SN, Rodriguez GG, Cruz AA, Canseco Villarreal C, Valdez Ramirez MA. Assessment of an educational course on asthma for primary care physicians. Rev Alerg Mex. 2005;52(2):83-9. [pmid: 16158781].
Ruoff G. Effects of flow sheet implementation on physician performance in the management of asthmatic patients. Fam Med. 2002;34(7):514-7. [pmid: 12144005].
Saini B, Filipovska J, Bosnic-Anticevich S, Taylor S, Krass I, Armour C. An evaluation of a community pharmacy-based rural asthma management service. Aust J Rural Health. 2008;16(2):100-8. [pmid: 18318852].
Schaffner W, Ray WA, Federspiel CF, Miller WO. Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. Journal of the American Medical Association. 1983;250(13):1728-1732. [pmid: 6350633].
Schatz M, Gibbons C, Nelle C, Harden K, Zeiger RS. Impact of a care manager on the outcomes of higher risk asthmatic patients: A randomized controlled trial. Journal of Asthma. 2006;43(3):225-229. [pmid: 16754526].
Schneider A, Biessecker K, Quinzler R, Kaufmann-Kolle P, Meyer FJ, Wensing M, Szecsenyi J. Asthma patients with low perceived burden of illness: A challenge for guideline adherence. Journal of Evaluation in Clinical Practice. 2006.
Self TH, Kelso TM, Abou-Shala N, Rumbak MJ. Clinical pharmacist initiated programs for improving outcomes in adult. African American asthmatics. 1992.
Simpson MD, Burton DL, Burton MA, Gissing PM, Bowman SL. Pharmaceutical Care: Impact on Asthma Medication Use. Journal of Pharmacy Practice and Research. 2004;34(1):26-29.
Sin DD, Bell NR, Man SF. Effects of increased primary care access on process of care and health outcomes among patients with asthma who frequent emergency departments. Am J Med. 2004;117(7):479-83. [pmid: 15464704].
Splett PL, Erickson CD, Belseth SB, Jensen C. Evaluation and sustainability of the healthy learners asthma initiative. J Sch Health. 2006;76(6):276-82. [pmid: 16918855].
Tennen H, Cloutier MM, Wakefield DB, et al. The buffering effect of hope on clinician's behavior: A test in pediatric primary care. Journal of Social and Clinical Psychology. 2009;28(5):554-576. [pmid: 20161067].
Ting S. Multicolored simplified asthma guideline reminder (MSAGR) for better adherence to national/global asthma guidelines. Ann Allergy Asthma Immunol. 2002;88(3):326-30. [pmid: 11926628].
Tschopp JM, Frey JG, Pernet R, Burrus C, Jordan B, Morin A, Garrone S, Imhof K, Besse F, Marty S, Uldry C, Assal JP. Bronchial asthma and self-management education: implementation of Guidelines by an interdisciplinary programme in health network. Swiss Med Wkly. 2002;132(7-8):92-7. [pmid: 11971203].
Walter EB, Hellkamp AS, Goldberg KC, Montgomery D, Patterson B, Dolor RJ. Improving influenza vaccine coverage among asthmatics: a practice-based research network study. Journal of Clinical Outcomes Management. 2008;15(5):229-234.
Wanich NH, Kaplan MS. Management of asthma based on exhaled nitric oxide in addition to guideline-based treatment for inner-city adolescents and young adults: A randomised controlled trial. Pediatrics. 2009;124(SUPPL. 2):S147.
Weinberger MM. What is the problem with asthma care for children?. Arch Pediatr Adolesc Med. 2011;165(5):473-5. [pmid: 21536964].
Weiss KB, Lozano P, Finkelstein JA. A randomized controlled clinical trial to improve asthma care for children through provider education and health systems change: A description of the Pediatric Asthma Care Patient Outcomes Research Team (PAC-PORT II) Study Design. Health Serv Outcomes Res Methodology.
White PT, Pharoah CA, Anderson HR, Freeling P. Randomized controlled trial of small group education on the outcome of chronic asthma in general practice. Journal of the Royal College of General Practitioners. 1989;39(322):182-186. [pmid: 2560000].
White P, Atherton A, Hewett G, Howells K. Using information from asthma patients: A trial of information feedback in primary care. British Medical Journal. 1995;311(7012):1065-1069. [pmid: 7580666].
Williams D, Portnoy JM, Meyerson K. Strategies for improving asthma outcomes: a case-based review of successes and pitfalls. J Manag Care Pharm. 2010;16(1 Suppl C):S3-14. quiz S16-7. [pmid: 20146547].
Wright J, Warren E, Reeves J, Bibby J, Harrison S, Dowswell G, Russell I, Russell D. Effectiveness of multifaceted implementation of guidelines in primary care. J Health Serv Res Policy. 2003;8(3):142-8. [pmid: 12869339].
Wright SW, Trott A, Lindsell CJ, Smith C, Gibler WB. Evidence-based emergency medicine. Creating a system to facilitate translation of evidence into standardized clinical practice: a preliminary report. Ann Emerg Med. 2008;51(1):80-6. 86.e1. 8. [pmid: 17719134].
Wroth TH, Boals JC. 4th Application of quality-improvement methods in a community practice: the Sandhills Pediatrics Asthma Initiative. N C Med J. 2005;66(3):218-20. [pmid: 16130947].
Yawn BP, Enright PL, Lemanske RF Jr, Israel E, Pace W, Wollan P, Boushey H. Spirometry can be done in family physicians' offices and alters clinical decisions in management of asthma and COPD. Chest. 2007;132(4):1162-8. [pmid: 17550939].
Zeiger RS, Heller S, Mellon MH. Facilitated referral to asthma specialist reduces relapses in asthma emergency department visits. J Allergy Clin Immunol. 1991;87:1161-1168.

## No Outcomes of Interest

Andersen M, Kragstrup J, Sorensen J. How participation in a clinical trial affects doctors' choice of treatment. Ugeskr Laeger. 2006;168(46):3987-91. [pmid: 17125649].
Anhoj J, Nielsen L. Quantitative and qualitative usage data of an Internet-based asthma monitoring tool. J Med Internet Res. 2004;6(3):e23. [pmid: 15471749].
Blais R, Laurier C, Pare M. Effect of feedback letters to physicians and pharmacists on the appropriate use of medication in the treatment of asthma. J Asthma. 2008;45(3):227-31. [pmid: 18415831].
Blenkinsopp A, Holmes J, Mitra G, Pringle M. Joining up self-care: Evaluation of a PCT-wide programme of support for self-care. Primary Health Care Research and Development. 2009;10(2):83-97.
Boulet LP, Dorval E, Labrecque M, Turgeon M, Montague T, Thivierge RL. Towards Excellence in Asthma Management: final report of an eight-year program aimed at reducing care gaps in asthma management in Quebec. Can Respir J. 2008;15(6):302-10. [pmid: 18818784].
Bratton SL, Cabana MD, Brown RW, White DF, Wang Y, Lang SW, Clark NM. Asthma educational seminar targeting Medicaid providers. Respir Care. 2006;51(1):49-55. [pmid: 16381618].
Brimkulov N, Ottmani SE, Pio A, Chubakov T, Sultanova A, Davletalieva N, Kalieva A, Rittman J, Erhola M, Cholurova R, Blanc L. Feasibility test results of the practical approach to lung health in Bishkek, Kyrgyzstan. International Journal of Tuberculosis and Lung Disease. 2009;13(4):533-539. [pmid: 19335962].
Carlton BG, Lucas DO, Ellis EF, Conboy-Ellis K, Shoheiber O, Stempel DA. The status of asthma control and asthma prescribing practices in the United States: results of a large prospective asthma control survey of primary care practices. J Asthma. 2005;42(7):529-35. [pmid: 16169784].
De Vries TW, Van Den Berg PB, Duiverman EJ, De Jong-van Den Berg LTW. Effect of a minimal pharmacy Intervention on adherence to asthma medication guidelines for children. Pharmaceutisch Weekblad. 2010;145(50):195-197.
Doran T, Fullwood C, Gravelle H, Reeves D, Kontopantelis E, Hiroeh U, Roland M. Pay-for-performance programs in family practices in the United Kingdom. New England Journal of Medicine. 2006;355(4):375-384. [pmid: 16870916].
Fang X, Li S, Gao L, Zhao N, Wang X, Bai C. Quality of care for copd and asthma in China: Clinicians' adherence to guidelines and the effects of a short term training course. Respirology. 2011;16:252-253.
Fifield J, McQuillan J, Martin-Peele M, Nazarov V, Apter AJ, Babor T, Burleson J, Cushman R, Hepworth J, Jackson E, Reisine S, Sheehan J, Twiggs J. Improving pediatric asthma control among minority children participating in medicaid: providing practice redesign support to deliver a chronic care model. J Asthma. 2010;47(7):718-27. [pmid: 20812783].
Gallagher C. Initiating a pediatric office-based quality improvement program. J Healthc Qual. 2001;23(2):4-9. quiz 9-10, 52. [pmid: 11257800].
Grainger-Rousseau TJ, Mc Elnay JC. A model for community pharmacist involvement with general practitioners in the management of asthma patients. Journal of Applied Therapeutics. 1996;1(2):145-161.
Grant R, Bowen SK, Neidell M, Prinz T, Redlener IE. Health care savings attributable to integrating guidelines-based asthma care in the pediatric medical home. J Health Care Poor Underserved. 2010;21(2 Suppl):82-92. [pmid: 20453378].
Harrison S, Dowswell G, Wright J, Russell I. General practitioners' uptake of clinical practice guidelines: a qualitative study. J Health Serv Res Policy. 2003;8(3):149-53. [pmid: 12869340].
Hartmann CW, Sciamanna CN, Blanch DC, Mui S, Lawless H, Manocchia M, Rosen RK, Pietropaoli A. A website to improve asthma care by suggesting patient questions for physicians: Qualitative analysis of user experiences. Journal of Medical Internet Research. 2007;9(1):1-12.
Hartmann CW, Sciamanna CN, Blanch DC, Mui S, Lawless H, Manocchia M, Rosen RK, Pietropaoli A. A website to improve asthma care by suggesting patient questions for physicians: qualitative analysis of user experiences. J Med Internet Res. 2007;9(1):e3. [pmid: 17478412].
Hendricson WD, Wood PR, Hidalgo HA, Kromer ME, Parcel GS, Ramirez AG. Implementation of a physician education intervention. The Childhood Asthma Project. Arch Pediatr Adolesc Med. 1994;148(6):595-601. [pmid: 8193683].
Herrick DE, Lowe CR, Micalizzi JG, Kerby GS. The impact of an evidence-based continuing education course on participant self-efficacy and asthma educator-certified (AE-C) accreditation. Journal of Allergy and Clinical Immunology. 2011;127(2):AB67.
Hoskins G, Neville RG, McCowan C, Smith B, Clark RA, Ricketts IW. Scottish Asthma Management Initiative. Health Bull (Edinb). 2000;58(6):478-88. [pmid: 12813780].
Howard R, Avery A, Cantrill J. How pharmacists working on the PINCER trial helped reduce hazardous prescribing. International Journal of Pharmacy Practice. 2010;18:5-6.
Jans MP, Schellevis FG, L. E. Coq EM, Bezemer PD, Van Eijk JTM. Health outcomes of asthma and COPD patients: The evaluation of a project to implement guidelines in general practice. International Journal for Quality in Health Care. 2001;13(1):17-25. [pmid: 11330439].
Kasiar J, Bonsignore CL, Dennis BH. Assessment of inhaled steroids for asthma patients overusing inhaled albuterol. Hospital Pharmacy. 1998;33(12):1507-1511.
Kryj-Radziszewska E, Windak A, Margas G, Wizner B, Grodzicki T. The influence of guidelines of asthma management in adults in reference to family physicians knowledge in the field of treatment. Przegl Lek. 2008;65(4):166-71. [pmid: 18724541].
Kuilboer MM, Van Wijk MAM, Mosseveld M, Van Der Does E, De Jongste JC, Overbeek SE, Ponsioen B, Van Der Lei J. Computed critiquing integrated into daily clinical practice affects physicians' behavior: A randomized clinical trial with asthma critic. Methods of Information in Medicine. 2006;45(4):447-454. [pmid: 16964364].
Labelle M, Beaulieu M, Renzi P, Rahme E, Thivierge RL. Integrating clinical practice guidelines into daily practice: impact of an interactive workshop on drafting of a written action plan for asthma patients. J Contin Educ Health Prof. 2004;24(1):39-49. [pmid: 15069911].
Lee E, McNally DL, Zuckerman IH. Evaluation of a physician-focused educational intervention on medicaid children with asthma. Ann Pharmacother. 2004;38(6):961-6. [pmid: 15122003].
Lomotan EA, Hoeksema LJ, Edmonds DE, Ramirez-Garnica G, Shiffman RN, Horwitz LI. Evaluating the use of a computerized clinical decision support system for asthma by pediatric pulmonologists. Int. J. Med. Informatics. 2012;81(3):157-65.
Lougheed MD, Moosa D, Finlayson S, Hopman WM, Quinn M, Szpiro K, Reisman J. Impact of a provincial asthma guidelines continuing medical education project: The Ontario Asthma Plan of Action's Provider Education in Asthma Care Project. Canadian Respiratory Journal. 2007;14(2):111-117. [pmid: 17372639].
Lougheed MD, Moosa D, Finlayson S, Hopman WM, Quinn M, Szpiro K, Reisman J. Impacts of a provincial asthma guidelines continuing medical education project: The Ontario Asthma Plan of Action's Provider Education in Asthma Care Project. Can Respir J. 2007;14(2):111-7. [pmid: 17372639].
Lundborg CS, Tomson G, Wahlstrom R, Oke T, Diwan VK. GPs' knowledge and attitudes regarding treatment of UTI and asthma in Sweden: A randomised controlled educational trial on guideline implementation. European Journal of Public Health. 2000;10(4):241-246.
Martens JD, van der Weijden T, Winkens RA, Kester AD, Geerts PJ, Evers SM, Severens JL. Feasibility and acceptability of a computerised system with automated reminders for prescribing behaviour in primary care. Int J Med Inform. 2008;77(3):199-207. [pmid: 17631412].
Mash B, Rhode H, Pather M, et al. Evaluation of the asthma guideline implementation project in the Western Cape, South Africa. Current Allergy and Clinical Immunology. 2010;23(4):154-161.
Modell M, Iliffe S, Austin A, Leaning MS. From guidelines to decision support in the management of asthma. Stud Health Technol Inform. 1995;16:105-13. [pmid: 10163705].
Moonie SA, Strunk RC, Crocker S, Curtis V, Schechtman K, Castro M. Community Asthma Program improves appropriate prescribing in moderate to severe asthma. J Asthma. 2005;42(4):281-9. [pmid: 16032937].
Murphy KR, Hopp RJ, Kittelson EB, Hansen G, Windle ML, Walburn JN. Life-threatening asthma and anaphylaxis in schools: A treatment model for school-based programs Annals of Allergy. Asthma and Immunology. 2006;96(3):398-405.
O'Laughlen MC, Hollen P, Ting S. An intervention to change clinician behavior: Conceptual framework for the multicolored simplified asthma guideline reminder (MSAGR). J Am Acad Nurse Pract. 2009;21(8):417-22. [pmid: 19689437].
Pinnock H, Hoskins G, Smith B, Weller T, Price D. A pilot study to assess the feasibility and acceptability of undertaking acute asthma professional development in three different UK primary care settings. Primary Care Respiratory Journal. 2003;12(1):7-11.
Roberts NJ, Evans G, Blenkhorn P, Partridge MR. Development of an electronic pictorial asthma action plan and its use in primary care. Patient Educ Couns. 2010;80(1):141-6. [pmid: 19879092].
Schaffner W, Ray WA, Federspiel CF, Miller WO. Improving antibiotic prescribing in office practice. A controlled trial of three educational methods. Journal of the American Medical Association. 1983;250(13):1728-1732. [pmid: 6350633].
Shegog R, Bartholomew LK, Sockrider MM, Czyzewski DI, Pilney S, Mullen PD, Abramson SL. Computer-based decision support for pediatric asthma management: Description and feasibility of the Stop Asthma Clinical System. Health Informatics Journal. 2006;12(4):259-273. [pmid: 17092998].
Steiner RM, Walsworth DT. Using quality experts from manufacturing to transform primary care. J Contin Educ Health Prof. 2010;30(2):95-105. [pmid: 20564711].
Sullivan SD, Lee TA, Blough DK, Finkelstein JA, Lozano P, Inui TS, Fuhlbrigge AL, Carey VJ, Wagner E, Weiss KB. A multisite randomized trial of the effects of physician education and organizational change in chronic asthma care: cost-effectiveness analysis of the Pediatric Asthma Care Patient Outcomes Research Team II (PAC-PORT II). Arch Pediatr Adolesc Med. 2005;159(5):428-34. [pmid: 15867115].
Tai SS, Nazareth I, Donegan C, Haines A. Evaluation of general practice computer templates. Lessons from a pilot randomised controlled trial. Methods Inf Med. 1999;38(3):177-81. [pmid: 10522120].
Thomas KW, Dayton CS, Peterson MW. Evaluation of internet-based clinical decision support systems. Journal of Medical Internet Research. 1999;1(2):5-13.
Thomas KW, Dayton CS, Peterson MW. Evaluation of internet-based clinical decision support systems. J Med Internet Res. 1999;1(2):E6. [pmid: 11720915].
Ting S. Multicolored simplified asthma guideline reminder (MSAGR) for better adherence to national/global asthma guidelines. Ann Allergy Asthma Immunol. 2002;88(3):326-30. [pmid: 11926628].
To T, McLimont S, Wang C, Cicutto L. How much do health care providers value a community-based asthma care program?-survey to collect their opinions on the utilities of and barriers to its uptake. BMC Health Services Research. 2009;9.
Tomson Y, Hasselstram J, Tomson G, Ã…berg H. Asthma education for Swedish primary care physicians - A study on the effects of ‘academic detailing’ on practice and patient knowledge. European Journal of Clinical Pharmacology. 1997;53(3-4):191-196. [pmid: 9476030].
Treweek S. The potential of electronic medical record systems to support quality improvement work and research in Norwegian general practice. BMC Health Services Research. 2003;3:1-9. [pmid: 12523939].
Tuomisto LE, Kaila M, Erhola M. Asthma Programme in Finland: Comparison of adult asthma referral letters in 1994 and 2001. Respiratory Medicine. 2007;101(3):595-600. [pmid: 16890421].
Twiggs JE, Fifield J, Jackson E, Cushman R, Apter A. Treating asthma by the guidelines: Developing a medication management information system for use in primary care. Disease Management. 2004;7(3):244-260. [pmid: 15669584].
Van Sickle D, Singh RB. A video-simulation study of the management of asthma exacerbations by physicians in India. Clin Respir J. 2008;2(2):98-105. [pmid: 20298314].
Veninga CC, Lagerlov P, Wahlstrom R, Muskova M, Denig P, Berkhof J, Kochen MM, Haaijer-Ruskamp FM. Evaluating an educational intervention to improve the treatment of asthma in four European countries. Drug Education Project Group. Am J Respir Crit Care Med. 99. 160(4):1254-62. [pmid: 10508816].
Wazeka A, Valacer DJ, Cooper M, et al. Impact of a pediatric asthma clinical pathway on hospital cost and length of stay. Pediatr Pulmonol. 2001;32(3):211-6. [pmid: 11536450].
White P, Atherton A, Hewett G, et al. Using information from asthma patients: A trial of information feedback in primary care. British Medical Journal. 1995;311(7012):1065-1069. [pmid: 7580666].
White M, Michaud G, Pachev, et al. Randomized trial of problem-based versus didactic seminars for disseminating evidence-based guidelines on asthma management to primary care physicians. J Contin Educ Health Prof. 2004;24(4):237-43. [pmid: 15709563].
Witt K, Knudsen E, Ditlevsen S, et al. Academic detailing has no effect on prescribing of asthma medication in Danish general practice: a 3-year randomized controlled trial with 12-monthly follow-ups. Fam Pract. 2004;21(3):248-53. [pmid: 15128684].
Yeh KW, Chao SY, Chiang LC, et al. Increasing asthma care knowledge and competence of public health nurses after a national asthma education program in Taiwan. Asian Pacific Journal of Allergy and Immunology. 2006;24(4):183-189. [pmid: 17348240].

## Other

Adler RN, McBride J. Tools and strategies for improving asthma management. Fam Pract Manag. 2010;17(1):16-21. [pmid: 20092231].
Baddar S, Worthing EA, Al-Rawas OA, Osman Y, Al-Riyami BM. Compliance of physicians with documentation of an asthma management protocol. Respir Care. 2006;51(12):1432-40. [pmid: 17134524].
Baldacci S, Maio S, Simoni M, et al. The ARGA study with general practitioners: Impact of medical education on asthma/rhinitis management. Respir. Med. 2012;106(6):777-85. [pmid: 22436656].
Borkgren-Okonek M, Gronkiewicz C, Diamond EJ. Underutilization of disease-specific electronic medical record templates limits adherence to evidence-based guidelines in outpatient asthma management. CHEST. 2010;138(4).
Boulet LP, Dorval E, Labrecque M, Turgeon M, Montague T, Thivierge RL. Towards Excellence in Asthma Management: final report of an eight-year program aimed at reducing care gaps in asthma management in Quebec. Can Respir J. 2008;15(6):302-10. [pmid: 18818784].
Brimkulov N, Ottmani SE, Pio A, Chubakov T, Sultanova A, Davletalieva N, Kalieva A, Rittman J, Erhola M, Cholurova R, Blanc L. Feasibility test results of the practical approach to lung health in Bishkek, Kyrgyzstan. International Journal of Tuberculosis and Lung Disease. 2009;13(4):533-539. [pmid: 19335962].
Cho SH. How to organize cost-effective care for asthma patients. Respirology. 2009;14:A104.
Dales RE, Vandemheen KL, Clinch J, Aaron SD. Spirometry in the primary care setting: Influence on clinical diagnosis and management of airflow obstruction. CHEST. 2005;128(4):2443-2447. [pmid: 16236907].
Davies B, Edwards N, Ploeg J, Virani T. Insights about the process and impact of implementing nursing guidelines on delivery of care in hospitals and community settings. BMC Health Serv Res. 2008;8:29. [pmid: 18241349].
Eccles M, McColl E, Steen N, Liaw ST. Computerised evidence-based guidelines may not improve asthma or angina management in primary care. Evidence-Based Healthcare. 2003;7(2):81-82.
Emmerton L, Shaw J, Kheir N. Asthma management by New Zealand pharmacists: A pharmaceutical care demonstration project. Journal of Clinical Pharmacy and Therapeutics. 2003;28(5):395-402. [pmid: 14632964].
Fang X, Li S, Gao L, Zhao N, Wang X, Bai C. Quality of care for copd and asthma in China: Clinicians' adherence to guidelines and the effects of a short term training course. Respirology. 2011;16:252-253.
Global initiative for asthma: Global strategy for asthma management and prevention. Global Initiative for Asthma. 2002.
Howard R, Avery A, Cantrill J. How pharmacists working on the PINCER trial helped reduce hazardous prescribing. International Journal of Pharmacy Practice. 2010;18:5-6.
Jones EM, Portnoy JM. Modification of provider behavior to achieve improved asthma outcomes. Curr Allergy Asthma Rep. 2003;3(6):484-90. [pmid: 14531969].
Kallenbach A, Ludwig-Beymer P, Welsh C, Norris J, Giloth B. Process improvement for asthma. An integrated approach. J Nurs Care Qual. 2003;18(4):245-56. quiz 257-8. [pmid: 14556581].
Lagerlov P, Loeb M, Andrew M, Hjortdahl P. Improving doctors' prescribing behaviour through reflection on guidelines and prescription feedback: a randomised controlled study. Qual Health Care. 2000;9(3):159-65. [pmid: 10980076].
Lasley MV. Adherence to follow-up recommendations in asthma. Pediatrics. 2008;122(SUPPL. 4):S211-S212.
Lukacs SL, France EK, Baron AE, Crane LA. Effectiveness of an asthma management program for pediatric members of a large health maintenance organization. Arch Pediatr Adolesc Med. 2002;156(9):872-6. [pmid: 12197793].
Lundborg CS, WahlstrÃ¶m R, Oke T, Tomson G, Diwan VK. Influencing prescribing for urinary tract infection and asthma in primary care in Sweden: A randomized controlled trial of an interactive educational intervention. Journal of Clinical Epidemiology. 1999;52(8):801-812. [pmid: 10465325].
Majak P, Bak-Walczak E, Stelmach I, Jerzynska J, Krakowiak J, Stelmach W. An increasing trend of the delay in asthma diagnosis after the discontinuation of a population-based intervention. J Asthma. 2011;48(4):414-8. [pmid: 21504354].
Martens JD, van der Aa A, Panis B, van der Weijden T, Winkens RA, Severens JL. Design and evaluation of a computer reminder system to improve prescribing behaviour of GPs. Stud Health Technol Inform. 2006;124:617-23. [pmid: 17108585].
McDermott MF, Walter J, Catrambone C, Weiss KB. The Chicago Emergency Department Asthma Collaborative. CHEST. 1999;116(4 SUPPL. 1):196S-197S. [pmid: 10532486].
Roberts NJ, Boyd K, Briggs A, Caress AL, Partridge MR. Is it cost-effective to replace nurses with lay asthma educators in primary care?. Thorax. 2010;65:A8.
Roberts NJ, Evans G, Blenkhorn P, Partridge MR. Development of an electronic pictorial asthma action plan and its use in primary care. Patient Educ Couns. 2010;80(1):141-6. [pmid: 19879092].
Schauerte G, Fendel T, Schwab S, Bredl C. Children with bronchial asthma: effects of an integrated health-care programme. Pneumologie. 2010;64(2):73-80. [pmid: 20143280].
Smith JR, Noble MJ, Musgrave SD, Murdoch J, Price G, Martin A, Windley J, Holland R, Harrison BDW, Price D, Howe A, Harvey I, Wilson AM. The at-risk registers in severe asthma (ARRISA) study: A cluster-randomised controlled trial in primary care. Thorax. 2010;65:A62.
Steiner RM, Walsworth DT. Using quality experts from manufacturing to transform primary care. J Contin Educ Health Prof. 2010;30(2):95-105. [pmid: 20564711].
Verstappen WH, van der Weijden T, Sijbrandij J, Smeele I, Hermsen J, Grimshaw J, Grol RP. Effect of a practice-based strategy on test ordering performance of primary care physicians: a randomized trial. JAMA. 2003;289(18):2407-12. [pmid: 12746365].
Yawn BP, Enright PL, Lemanske RF Jr, Israel E, Pace W, Wollan P, Boushey H. Spirometry can be done in family physicians' offices and alters clinical decisions in management of asthma and COPD. Chest. 2007;132(4):1162-8. [pmid: 17550939].