# Screening and Data Abstraction Forms

Title/Abstract Review

This image is a screen shot of the title/abstract screen form used by the systematic review team to screen articles for applicability and categorization.

Article Review

This image is a screen shot of the article screen form used by the systematic review team to screen articles for applicability and categorization.

Study Characteristics

This image is a screenshot of the study characteristics data abstraction form used by the systematic review team to record and organize data.

Healthcare Provider and Patient Characteristics (Arm D data fields are identical to A, B, and C)

This image is a screenshot of the healthcare provider and practice characteristics data abstraction form used by the systematic review team to record and organize data.

Patient Characteristics

This image is a screenshot of the patient characteristics data abstraction form used by the systematic review team to record and organize data.

Intervention Characteristics

This image is a screenshot of the intervention characteristics data abstraction form used by the systematic review team to record and organize data.

Outcomes – Baseline and End of Treatment

This image is a screenshot of the outcomes data abstraction form used by the systematic review team to record and organize data for baseline and end of treatment measures.

Outcomes – Within Group Differences

This image is a screenshot of the outcomes data abstraction form used by the systematic review team to record and organize data for within group differences.

Outcomes – Mean Difference Between Groups

This image is a screenshot of the outcomes data abstraction form used by the systematic review team to record and organize data for differences between groups.

Risk of Bias

This image is a screenshot of the risk of bias form used by the systematic review team to assess study bias.