# Detailed Search Strategies

Search date –July 2012

Pubmed – 1160

(asthma[mh] OR asthma[tiab])

AND

(guideline[tiab] OR guidelines[tiab] OR practice guidelines as topic[mh] OR consensus conference[tiab] OR consensus statement[tiab] OR consensus statements[tiab] OR recommendation[tiab] OR recommendations[tiab]OR critical pathways[mh] OR critical pathways[tiab] OR critical pathway[tiab] OR clinical pathways[tiab] OR clinical pathway[tiab] OR primary health care/standards[mh])

AND

(guideline adherence[mh] OR adherence[tiab] OR nurse's practice patterns[mh] OR Physician's Practice Patterns[mh] OR practice pattern[tiab] OR practice patterns[tiab] OR behavior[tiab] OR behaviour[tiab] OR Professional practice[mh] OR “outcome assessment (health care)”[mh] OR quality assurance[mh])

AND

(Physicians[mh] or physicians[tiab] OR physician[tiab] OR general practitioner[tiab] OR general practitioners[tiab] OR GPs[tiab] OR hospitalists[tiab] OR Primary health care[mh] OR Nurses[mh] OR nurses[tiab] OR nurse[tiab] OR physical therapy[tiab] or Physical therapy[mh] OR physical therapist[tiab] OR physical therapists[tiab] OR physiotherapist[tiab] OR physiotherapists[tiab] OR Respiratory therapy[mh] OR respiratory therapist[tiab] OR respiratory therapists[tiab] OR Pharmacists[mh] OR pharmacist[tiab] OR pharmacists[tiab] OR health professional[tiab] OR health professionals[tiab] OR health care provider[tiab] OR health care providers[tiab] OR healthcare provider[tiab] OR healthcare providers[tiab] OR pediatricians[tiab] OR pediatrician[tiab] OR paediatrician[tiab] OR paediatricians[tiab] OR specialist[tiab] OR specialists[tiab] OR pulmonologist[tiab] OR pulmonologists[tiab] OR doctor[tiab] OR doctors[tiab] OR allergist[tiab] OR allergists[tiab] OR internist[tiab] OR internists[tiab])

ERIC – 5

CINAHL =377

PsycINFO =80

(TX asthma ) AND (TX guideline OR TX guidelines OR TX consensus conference OR TX consensus statement OR TX consensus statements OR TX recommendation OR TX recommendations OR TX critical pathways OR TX critical pathway OR TX clinical pathways OR TX clinical pathway OR TX primary health care) AND (TX adherence OR TX practice pattern OR TX practice patterns OR TX behavior OR TX behaviour OR TX Professional practice OR TX quality assurance OR TX outcome assessment) AND (TX Physicians OR TX physician OR TX general practitioner OR TX general practitioners OR TX hospitalists OR TX Primary health care OR TX Nurses OR TX nurse OR TX physical therapy OR TX physical therapist OR TX physical therapists OR TX physiotherapist OR TX physiotherapists OR TX respiratory therapist OR TX respiratory therapists OR TX Pharmacists OR TX pharmacist OR TX health professional OR TX health professionals OR TX health care provider OR TX health care providers OR TX healthcare provider OR TX healthcare providers OR TX pediatricians OR TX pediatrician OR TX paediatrician OR TX paediatricians OR TX specialist OR TX specialists OR TX pulmonologist OR TX pulmonologists OR TX doctor OR TX doctors OR TX allergist OR TX allergists OR TX internist OR TX internists)

EMBASE: 538

‘asthma’/exp OR asthma:ab,ti

guideline:ab,ti OR guidelines:ab,ti OR ‘practice guideline’/exp OR ‘practice guideline’:ab,ti OR ‘consensus conference’:ab,ti OR ‘consensus statement’:ab,ti OR ‘consensus statements’:ab,ti OR recommendation:ab,ti OR recommendations:ab,ti OR ‘critical pathways’:ab,ti OR ‘critical pathway’:ab,ti OR ‘clinical pathways’:ab,ti OR ‘clinical pathway’:ab,ti OR ‘primary health care’:ab,ti

adherence:ab,ti OR ‘practice pattern’:ab,ti OR ‘practice patterns’:ab,ti OR behavior:ab,ti OR behaviour:ab,ti OR ‘professional practice’:ab,ti OR ‘quality assurance’:ab,ti OR ‘outcome assessment’/exp OR ‘outcome assessment’:ab,ti

‘physician’/exp OR physicians:ab,ti OR physician:ab,ti OR ‘general practitioner’:ab,ti OR ‘general practitioners’:ab,ti OR hospitalists:ab,ti OR ‘primary health care’/exp OR ‘primary health care’:ab,ti OR nurses:ab,ti OR nurse:ab,ti OR ‘physical therapy’:ab,ti OR ‘physical therapist’:ab,ti OR ‘physical therapists’:ab,ti OR physiotherapist:ab,ti OR physiotherapists:ab,ti OR ‘respiratory therapist’:ab,ti OR ‘respiratory therapists’:ab,ti OR pharmacists:ab,ti OR pharmacist:ab,ti OR ‘health professional’:ab,ti OR ‘health professionals’:ab,ti OR ‘health care provider’:ab,ti OR ‘health care providers’:ab,ti OR ‘healthcare provider’:ab,ti OR ‘healthcare providers’:ab,ti OR pediatricians:ab,ti OR pediatrician:ab,ti OR paediatrician:ab,ti OR paediatricians:ab,ti OR specialist:ab,ti OR specialists:ab,ti OR pulmonologist:ab,ti OR pulmonologists:ab,ti OR doctor:ab,ti OR doctors:ab,ti OR allergist:ab,ti OR allergists:ab,ti OR internist:ab,ti OR internists:ab,ti

Cochrane =92

asthma:ti,ab,kw OR MeSH descriptor Asthma explode all trees

guideline:ti,ab,kw OR guidelines:ti,ab,kw OR “practice guideline”:ti,ab,kw OR “consensus conference”:ti,ab,kw OR “consensus statement”:ti,ab,kw OR “consensus statements”:ti,ab,kw OR recommendation:ti,ab,kw OR recommendations:ti,ab,kw OR MeSH descriptor Critical Pathways explode all trees OR “critical pathways”:ti,ab,kw OR “critical pathway”:ti,ab,kw OR “clinical pathways”:ti,ab,kw OR “clinical pathway”:ti,ab,kw OR “primary health care”:ti,ab,kw

MeSH descriptor Guideline Adherence explode all trees OR adherence:ti,ab,kw OR “practice pattern”:ti,ab,kw OR “practice patterns”:ti,ab,kw OR behavior:ti,ab,kw OR behaviour:ti,ab,kw OR “professional practice”:ti,ab,kw OR “quality assurance”:ti,ab,kw OR MeSH descriptor Outcome Assessment (Health Care) explode trees 2 and 3 OR “outcome assessment”:ti,ab,kw

physicians:ti,ab,kw OR physician:ti,ab,kw OR “general practitioner”:ti,ab,kw OR “general practitioners”:ti,ab,kw OR hospitalists:ti,ab,kw OR MeSH descriptor Primary Health Care explode all trees OR “primary health care”:ti,ab,kw OR nurses:ti,ab,kw OR nurse:ti,ab,kw OR “physical therapy”:ti,ab,kw OR “physical therapist”:ti,ab,kw OR “physical therapists”:ti,ab,kw OR physiotherapist:ti,ab,kw OR physiotherapists:ti,ab,kw OR “respiratory therapist”:ti,ab,kw OR “respiratory therapists”:ti,ab,kw OR pharmacists:ti,ab,kw OR pharmacist:ti,ab,kw OR “health professional”:ti,ab,kw OR “health professionals”:ti,ab,kw OR “health care provider”:ti,ab,kw OR “health care providers”:ti,ab,kw OR “healthcare provider”:ti,ab,kw OR “healthcare providers”:ti,ab,kw OR pediatricians:ti,ab,kw OR pediatrician:ti,ab,kw OR paediatrician:ti,ab,kw OR paediatricians:ti,ab,kw OR specialist:ti,ab,kw OR specialists:ti,ab,kw OR pulmonologist:ti,ab,kw OR pulmonologists:ti,ab,kw OR doctor:ti,ab,kw OR doctors:ti,ab,kw OR allergist:ti,ab,kw OR allergists:ti,ab,kw OR internist:ti,ab,kw OR internists:ti,ab,kw

Research and Development Resource Base in Continuing Medical Education (RDRB/CME)

Asthma =60

Keywords: (“asthma”)

AND

Keywords: (“guideline”) OR (“guidelines”)

AND

Keywords: (“adherence”) OR (“pattern”) OR (“patterns”)

AND

Keywords: (“physicians”) OR (“physician”) OR (“practitioner”)