# Acronyms and Abbreviations

A/P: Asian/Pacific Islander
AAP: Asthma action plan
BQC: benchmarking quality circle feedback intervention
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CLIQ: Clinical Inquiry
CME: Continuing medical education
CON: Control
COPD: Chronic obstructive pulmonary disease
CPGs: clinical practice guidelines
DM: Diabetes mellitus
ED: emergency department
EMR: Electronic Medical Records
ENT: Ear nose throat
EPOC: Cochrane Effective Practice and Organisation of Care
EPR-3: Expert Panel Report 3
ERIC: Educational Resources Information Center
FEV: Forced Expiratory Volume
FVC: Forced Vital Capacity
GPs: General practitoner
HCSD: Health Care Services Division
HMO: Health maintenance organization
ICS: Inhaled Corticosteroids
INT: Intervention
MD: Medical Doctor
MSAGR: Multicolored, Simplified, Asthma Guideline Reminder
NAEPP: National Asthma Education and Prevention Program
NHLBI: National Heart, Lung, and Blood Institute
NYCHP: New York Children's Health Project
PACE: Practitioner Asthma Communication and Education
PCAPP: Primary Care Asthma Pilot Project
PDSA: Plan-do-study-act
PEFR: Peak Expiratory Flow Rate
PFR: Peak Flow Rate
PFT: Pulmonary Function Test
PLE: Peer Leader Education
PPO-FFS: Preferred provider organization – Fee for service
QC: quality circles
QOL: Quality of life
RCT: Randomized controlled trial
RDRB/CME: Research and Development Resource Base in Continuing Medical Education
SBHC: South Bronx Health Center
SOE: Strength of evidence
SP: Suburban practice
TOM: Therapeutic outcomes monitoring
TQC: traditional quality circle
UP: Urban practice
UTI: Urinary Tract Infection
WAAP: Written asthma action plan