# Results

In this section we present findings for each Key Question, beginning with an overview of the content of the literature addressing interventions for feeding and nutrition in individuals with cerebral palsy (CP) meeting our criteria, including the range of study designs used, approaches assessed and participants included. The detailed analysis of the literature provides further discussion and analysis.

Studies also are described in summary tables in the relevant section of text. For further information on quality scores for each study, see Appendix E.

## Results of Literature Searches and Description of Included Studies

### Article Selection

We conducted a broad search to identify any titles or abstracts that might include relevant data for the review. Of the entire group of 1,055 titles and abstracts, we reviewed the full text of 553 because they either appeared to meet criteria or did not provide enough information in the abstract to determine definitively that they should be excluded (Figure 2). Of the 546 full text articles reviewed, 15 articles (comprising 13 unique studies) met our inclusion criteria. This figure includes 12 unique primary research studies (reported in 14 publications) described in this comparative effectiveness review and one systematic review meeting our inclusion criteria. Reasons for article exclusion are listed in Appendix F. As indicated in Figure 2, we were unable to obtain the full text of eight studies. Seven of these appeared from their abstracts to be narrative reviews, and one report, which may contain primary data, focuses on upper limb movement in CP. Thus, we do not feel that any of these papers would change our conclusions.

Figure 2 Disposition of studies identified for this review

CER = comparative effectiveness review; KQ = Key Question; n = number

^a^ Numbers do not tally as studies could be excluded for multiple reasons.

^b^ This number includes one study (Gisel 1994^60^) not explicitly referenced in the Snider review; the Snider review cites a later Gisel paper61 reporting on the same population.

^c^ This figure includes 12 unique primary research studies (reported in 14 publications) described in the current CER and one systematic review meeting our screening criteria.

This disposition of studies (Figure 2) outlines the flow of articles identified for the review. We located a total of 1055 citations. Of these, 553 required full text review. Of the 553 full text articles reviewed, we retained 15 papers (comprising 13 unique studies). A prior systematic review summarized in the current review also included 22 studies. Thus, we excluded 516 of the 553 studies evaluated. Papers could be excluded for multiple reasons, and a number were excluded because they were not relevant to the key questions or outcomes of interest (n=394), reported on an ineligible study population (n=396), described a systematic review that was not relevant to the key questions or did not meet quality criteria (n=106), did not include effectiveness data (n=419), or were not original research (n=96).

Table 6 summarizes characteristics of the primary literature meeting our criteria and not addressed in prior systematic reviews summarized here. The majority of studies were case series.

Table 6 Overview of primary literature addressing feeding and nutrition interventions in CP

Characteristic | RCTs | Prospective Cohort Studies | Prospective Case Series | Retrospective Case Series | Total Literature
Total number of studies: | 1 | 1 | 8 | 2 | 12
Intervention Category
Behavioral | 0 | 0 | 1 | 0 | 1
Surgical | 1 | 1 | 7 | 2 | 11
Duration of Followup
<1 month | 1 | 0 | 0 | 0 | 1
>1 to ≤3 months | 0 | 0 | 0 | 0 | 0
>3 to ≤6 months | 0 | 0 | 3 | 0 | 3
>6 to ≤12 months | 0 | 1 | 3 | 0 | 4
>12 months | 0 | 0 | 2 | 2 | 4
Study Population
United States | 0 | 0 | 0 | 2 | 2
Europe | 0 | 1 | 3 | 0 | 4
Other | 1 | 0 | 5 | 0 | 6
Total number of participants with CP | 14 | 40 | 201 | 76 | 331

CP = cerebral palsy; RCTs = randomized controlled trials

## Key Question 1a Compared with other nonsurgical interventions or no intervention, how effective are behavioral interventions, including positioning, oral appliances, oral stimulation, sensorimotor facilitation, and caregiver training, for improving nutritional state/growth, health outcomes and health care/resource utilization, and quality of life in individuals with cerebral palsy and feeding difficulties?

### Key Points

- One recent, good quality,34 systematic review was available. The primary literature updating the review consisted of one case series.66
- The systematic review assessed interventions including sensorimotor approaches, positioning, oral appliances, altering food consistency, and feeding interventions and largely addressed the outcomes of feeding efficiency and safety; overall, the review concluded that the evidence base was generally of poor quality that limited conclusions about effectiveness for all of the interventions. Strength of evidence (confidence in the estimate of effect) for these interventions across outcomes therefore ranged from insufficient to low.
- The small, short-term case series of a caregiver intervention66 reported some pre- to post-intervention improvements in oral-motor behaviors (increase in number of children able to perform some self-feeding from 0 to 6), caregiver stress (18 indicated feeling very stressed pre-intervention to 2 post), and number of chest infections (15 pre-intervention vs. 6 post), but it does not change the conclusions laid out in the prior review.

### Overview of the Literature

We identified two studies addressing behavioral interventions for feeding in CP: one good quality systematic review34 and one case series.66 The good quality systematic review, published in 2011, included 21 studies of behavioral interventions including sensorimotor interventions, positioning, food consistency, feeding devices, and oral appliances.34 The primary literature consisted of one home-based prospective case series assessing a caregiver training program implemented in Bangladesh and providing data on 22 child-caregiver pairs.66 Outcomes examined included measures of growth and feeding skills, caregiver stress, and time spent feeding at 6 months after training.

### Detailed Analysis

#### Summary of Relevant Prior Systematic Reviews

The good quality systematic review,34 conducted by Snider and colleagues, focused on whether regular application of feeding interventions improves feeding efficiency and safety and results in enhanced weight gain in children with CP. We assessed the review as good quality as it reported search procedures, assessed and reported quality of studies, and appropriately synthesized results. The review investigators searched 12 electronic databases including MEDLINE, PsycINFO, CINAHL, ERIC, and HealthStar. After analysis, 21 studies (two case reports, four case series, one single-subject ABA design, six experimental, six quasi-experimental, one prospective matched pairs, and one RCT) were included in the review. Most (13 of 21) studies would have met inclusion criteria for our review as well; those that did not were either case reports, published prior to 1980, or did not address interventions of interest. Included studies were assessed as oral sensorimotor facilitation (“techniques specific to the enhancement of oral-motor control aim[ing] to decrease or increase tone and inhibit abnormal reflexes that interfere with safe feeding”34), food consistency, positioning, oral appliances, or adaptive equipment. Some studies assessed more than one intervention (e.g., electric feeder + positioning,67 oral device + motor-sensory therapy68 or positioning,69 feeding skills + positioning,70 oral-motor exercises + attention and parent training,71 and oral-motor skills + thermal stimulation + dietary modification72), with results presented in the aggregate. Methodological quality was assessed using the Physiotherapy Evidence Database rating scale (PEDro). A PEDro score of 9–10 points is considered to be of excellent quality, a score of 6–8 points is good, 4–5 points is fair and a score below 4 points is of poor quality. A total of 414 participants aged 1.6 to 17 years were included in the reviewed studies. Severity, type of CP, nutrition status and feeding skills varied among participants. We summarize key findings of the studies included in the review below:

##### Sensorimotor Interventions

Six studies of sensorimotor interventions were included.61,71-75 All were small, with the largest study including 35 children.61 This study was of good quality (PEDro score of 6) and found no effect of the sensorimotor treatment on a range of outcomes, including eating time, clearing time, textures consumed, or weight gain. The remaining studies all were smaller and of poorer quality and results were mixed. Two studies by the same group as that above appear to provide data on overlapping patients and provided data separately for children with and without a history of aspiration.74,75 The papers were rated as fair quality, and reported improved eating efficiency and safety of the sensorimotor intervention when eating pureed food for aspirating children, but no effect among those who did not aspirate. They reported no change in weight or skinfold measures. In a case series of eight children with spastic diplegia, sensorimotor treatment provided four times per day was associated with increased efficiency of chewing and swallowing skills, caloric consumption, and gains in height and weight.71 Treatment was provided for up to six weeks, with outcomes measured over the course of a year. A case series with six severe cases of CP reported improved efficiency and speed of swallowing when using a thermal modality.72 When individuals continued receiving thermal stimulation, frequency of aspiration and recurrence of upper respiratory tract infections were reduced. Overall, evidence was low for improved feeding efficiency and safety outcomes as to the effectiveness of a sensorimotor treatment when compared with no intervention at all as the one good RCT found no effect, and those studies that did report positive effects were of poorer quality.

##### Positioning

Four studies of positioning70,76-78 were included in the Snider review, none of which was a comparative study; thus all studies had a high risk of bias. The largest included 24 participants evaluated before and after use of a thoracic-lumbar-sacral orthosis kept within a nonrigid frame.78 Participants demonstrated increased tolerance of varied textures at meals, shorter feeding times, improved mouth opening, less food leakage and a decrease in tongue protrusion, but the study did not include a comparison group. In one study with five participants, videofluoroscopy was used to visualize the effectiveness of feeding in a 30 percent reclined position.77 In this position, participants who had received food puree mixed with barium powder had decreased aspiration. Two participants showed a decrease in oral leakage and ability to consume purees improved. Another case series using videofluoroscopy reported that the best reclining position depended on the phase of feeding in which problems occurred.76 Given the poor quality of the studies and lack of comparative data, Snider concluded that there may be limited evidence that positioning is effective in reducing episodes of aspiration and decreasing mealtime but there is insufficient evidence to draw conclusions.

##### Altering Food Consistency

The one study on altering food consistency79 in the Snider review would not have met criteria for inclusion in our review on the basis that the study provided no pre-post data and did not include an untreated or differently treated comparison group.

##### Oral Appliances

Eight studies of oral appliances were included in the Snider review.68,69,80-85 A series of studies with overlapping participants assessed the effectiveness of Innsbruck Sensorimotor Activator and Regulator (ISMAR) therapy, which is the use of the ISMAR appliance to stabilize the jaw and promote improved swallowing and lip control.69,83,84 One RCT in which 20 participants were randomized either to 12 months of ISMAR, or 6 months of standard rehabilitation followed by 12 months of ISMAR. Oral-motor skills improved during the stabilization (initial) period in each group, but not in the control period during which standard rehabilitation took place. No significant improvements in weight or feeding skills (our primary outcomes) could be attributed to the treatment; rather these physical changes occurred equally in the two groups and were thus associated with maturation. Two papers69,84 report on participants randomized to immediate versus delayed treatment, followed by cessation of use by one group while the other continued use. The goal was to determine the degree to which improvements continued in the group that ceased use of the ISMAR device. At this point in time, no significant differences were observed, suggesting that maturation accounted for improvements in the second year.

Two other studies without comparison groups examined the use of the ISMAR and other oral appliances and effects on oral sensorimotor functions. A small study with seven subjects reported improvements in lip seal, nasal breathing, transport of saliva and speech articulation.68 A study with 71 subjects reported no improvements in drooling, tongue position, coordination of tongue movement, lip position, or mouth posture.81 Two case series reported positive results with lip control and closure, deglutition skills, and chewing skills after using an oral appliance; followup occurred after the 18^th^85 or sixth month68 of using a device. A case study showed that following one year of ISMAR therapy improvements in feeding skills, swallow, and efficiency eating different textures were observed.82 A change in facial expression and improvements in ambulation and upper extremity functions were noted. Harms noted in the studies include worsening of isolated oral functions (leading to discontinuation of the device in 5 participants)81 and discomfort associated with the device.85 Overall, although individual studies report improvements in typically short term outcomes associated with oral appliances, there is limited evidence to suggest that they are associated with the health outcomes of interest in our review.

##### Feeding Devices

Two studies analyzed effectiveness of an electric feeder in 20 participants (17 with CP) using a pre-post design.67,86 Neither demonstrated positive effects in outcomes of interest for our review and improvements in components of oral-motor behaviors were not observed at followup. Electric feeding devices were not included in our review. Table 7 outlines key findings as summarized in the review's evidence table.34

Table 7 Key findings summarized in Snider et al.34 systematic review^*^

| Author, Year Study Design | Intervention | CP Type/Severity Participants Age Range | Key Findings
Oral sensorimotor facilitation | *Helfrich-Miller et al., 1986^72^ Case series | Dietary modification, oral program during feeding, thermal stimulation | Severe CP n=6 10–13 years | - Improvements in swallowing efficiency and speed; - Reductions in aspirations and incidence of upper respiratory tract infections for those remaining on thermal stimulations program
Oral sensorimotor facilitation | Ganz 1987^73^ Single-subject ABA design | Neuromotor and sensory facilitation | Severe CP n=1 8 years | - Decreased tongue thrust and positive changes in tongue and jaw movements; - Poorer elevation of tongue with jaw separation for liquids and solids
Oral sensorimotor facilitation | *Gisel et al., 1995^74^ Prospective cohort study comparing outcomes in aspirators and nonaspirators^a^ | Tailored sensorimotor treatment with emphasis on tongue lateralization, lip control, chewing | Moderate to severe motor impairment n=27 2–10 years | - Limited change in eating efficiency in non aspirators; improvements with purees in aspirating group but declines with solids; - Rank in weight- and skin fold-or-age measurements maintained; - Eating efficiency may be related to severity of eating impairment
Oral sensorimotor facilitation | *Gisel et al., 1996^75^ Prospective cohort study comparing outcomes in aspirators and nonaspirators^a^ | Tailored sensorimotor treatment with emphasis on tongue lateralization, lip control, chewing | Moderate to severe motor impairment n=27 2–10 years | - Significant improvements in spoon feeding, chewing (lateralization of the tongue), and swallowing; - No significant changes in rotary chewing or drinking skills; - No catch-up growth reported
Oral sensorimotor facilitation | *Gisel et al., 1996^61^ RCT | Tailored sensorimotor treatment with emphasis on tongue lateralization, lip control, chewing | Moderate to severe motor impairment n=35 4.3–13.3 years | - Eating time of standard food textures did not decrease significantly; - No significant changes in clearing time or ability to advance to more solid foods between groups; - No differences between groups regarding weight gain
Oral sensorimotor facilitation | *Clawson et al., 2007^71^ Case series | Beckman oral-motor exercise, parent training | Spastic diplegia n=8 1.6–4.7 years | - Chewing and swallowing improved; - Number of calories increased (less need for supplementation); - Height and weight gain; - Improvements in caregiver ability to feed
Food consistency | Croft et al., 1992^79^ Prospective cohort study | Mashed vs. nonmashed food | Hemiplegia, athetoid, spastic quadriplegia plus athetoid n=67 3–18 years | - Children without speech took significantly longer to eat nonmashed than mashed food; - Children with CP more likely to cough or choke while eating more solid foods
Positioning | Banerdt et al., 1978^70^ Case report | Self-feeding skills program, positioning | Spastic CP n=1 2.5 years | - Number of independent responses from the child increased throughout treatment. New self feeding behaviors at 5 months followup
Positioning | Morton et al., 1993^76^ Case series | Feeding assessment with videofluoroscopy, positioning recommendations | Majority CP with malnourishment n=14 4–16 years | - Children with difficulties mainly in oral phase fed best in the reclined position; - Children with difficulties mainly in pharyngeal phase fed best in the erect position; - Parents found seating recommendations helpful; - No changes in weight gain reported
Positioning | *Larnert et al., 1995^77^ Case series | Positioning | Tetraplegia with dystonia (aspiration, recurrent pneumonia) n=5 3–10 years | - Aspiration decreased for all participants in reclined position with neck flexed; - Oral leak diminished in 2 children; - Retention of puree improved in 1 child
Positioning | *Vekerdy et al., 2007^78^ Case series | Thoracic-lumbar-sacral orthosis | CP, nonambulatory n=24 1.7–11.2 years | - Improvement in meal textures tolerated; - Decreases in feeding time; - Improvements in mouth opening, food leakage, tongue protrusion
Oral appliance | Haberfellner et al.,1977^80^ Case series | Oral appliance (oral shield, vestibular pads) | Mixed forms of spasticity, athetosis, and /or ataxia n=9 6–12 years | - Sensibility, lip seal, saliva transport, and nasal breathing improved; - Speech articulation improved
Oral appliance | *Fischer-Brandies et al.,1987^81^ Case series | Oral appliance (upper palate plates), physical therapy | CP, majority spastic diplegia, majority severe dysfunction n=71 4–14 years | - Improvements in spontaneous tongue position and coordination of tongue movement, food intake, speech development and drooling in at least half of participants; - Treatment discontinued in 5 children due to lack of improvement; - Unclear if positive effects due to physical therapy or appliance
Oral appliance | Gisel et al., 1999^82^ Case report | ISMAR | Moderate spastic quadriplegia n=1 2 years, 10 months | - Improved functional feeding skills and visible aspects of the swallow; - Improved eating efficiency of three standard textures; - Catch-up of weight during treatment phase, improvements in ambulation and upper extremity function; - Child became able to self-feed
Oral appliance | *Gisel, et al., 2000^b,69^ RCT | ISMAR | Tetraparesis with moderate motor impairment n=20 4–13 years | - Improvement in sitting postural control and upper extremity control; - Improvements in jaw stabilization and oral-motor control; - Improvement in oral posture but not tongue position in half of participants
Oral appliance | *Gisel et al., 2001^b,83^ RCT | ISMAR | Tetraparesis with moderate motor impairment n=17 6–15 years | - ISMAR tolerated without complications; - No significant differences in 7 domains of functional feeding or weight gain 18–24 month followup; - Maturation equally effective as ISMAR therapy after the first year of use
Oral appliance | *Haberfellner et al., 2001^b,84^ RCT | ISMAR | Tetraparesis with moderate motor impairment n=20 4.2–13.1 years | - Improvements in oral-motor and chewing skills
Oral appliance | *Johnson et al., 2004^85^ Case series | ISMAR | CP, majority with moderate to sever dysphagia n=18 4–13 years | - Clinically important and statistically significant changes in chewing, cup drinking, straw drinking, and swallowing at various points of study
Oral appliance | *Gerek et al., 2005^68^ Case series | Castillo-Morales device | CP, majority with moderate to severe dysphagia n=7 8–17 years | - Changes noted in deglutition skills with higher consistency in food intake, decreased risk of aspiration, better saliva control; Parental satisfaction with treatment results
Adapted equipment | Pinnington et al., 1999^c,86^ ABA within-subjects design | Electric feeder (Handy 1 Robotic Aid to Eating) | Majority CP, moderate-very severe motor disorder n=16 7–17 years | - Food intake and weight gain maintained using feeder; - Eating efficiency reduced; energy and protein intake unchanged using feeder
Adapted equipment | Pinnington et al., 2000^c,67^ ABA within-subjects design | Electric feeder (Handy 1 Robotic Aid to Eating) | Majority CP, moderate-very severe motor disorder n=16 7–17 years | - Improvements in oral-motor behaviors using feeder but not always sustained; - Children with more limited speech appeared to have greater benefit

CP = cerebral palsy; ISMAR = Innsbruck Sensorimotor Activator and Regulator; n = number; RCT = randomized controlled trial

* Study meets inclusion criteria for current comparative effectiveness review.

a Same study population.

b Same study population.

c Same study population.

#### Summary of Primary Research

In updating the Snider review described above, we identified one case series addressing caregiver training.66 The study was conducted in child-caregiver pairs who received in-home training and support in Dhaka, Bangladesh (Table 8). All of the children had moderate to severe CP, assessed as levels III to IV on the Gross Motor Function Classification System (GMFCS). Thirty-seven pairs were enrolled in the study, but only 22 completed it. Pairs received advice and completed a baseline assessment during an initial home session and then participated in four to six sessions focused on improving dietary intake and ease and efficiency of feeding, including introduction of a high calorie diet, adaptation of food consistency, use of appropriate utensils and provision of appropriate postural and physical support. The intervention was delivered over 2.5 months and evaluated 4 to 6 months after completion.

Table 8 Key outcomes of studies assessing behavioral interventions

Author, Year Country Groups, Number of Participants (Enrollment/Final) | Age (mean years ± SD) CP Severity, n (%) | Key Outcomes
Adams et al., 2011^66^ Bangladesh G1: Caregiver training (4 to 6 sessions over 2.5 months), 37/22 | Age: 3.11 ± 2.3 Severity (GMFCS): Level III: 3 (14) Level IV: 3 (14) Level V: 16 (72) (moderate to severe) | - Significant improvement in chest health (frequency of illness) (p=0.005), nutritional status (mean weight-for-age z-scores and mid-upper-arm circumference) (p=0.02 and 0.001), and fluid intake during meals (p<0.01) at 4 to 6 months after end of intervention.; - Significant improvement in child observed fussiness, food refusal and general mood (p<0.01) and feeding skills (p<0.05) at 4 to 6 months after end of intervention.; - Significant decrease in caregiver self-reported stress (p<0.001) and perceived reduction in mealtime length (p=0.005).

CP = cerebral palsy; G = group; GMFCS = Gross Motor Function Classification System; SD = standard deviation

Children had significantly fewer episodes of chest-related illness after 3 months (15 vs. 6, p=0.005), had improved mean weight-for-age z-scores (−4.83 vs. −4.07, p=0.02), mean mid-upper-arm circumference (14.75 cm vs. 15.46 cm, p=0.02 and 0.001), and fluid intake during meals (173.7 ml vs. 300.2 ml, p<0.01) 4 to 6 months after the end of intervention. Observed child feeding skills and affect also improved, with a significant decrease in child fussiness and food refusal and improvement in general mood and child feeding skills (p<0.05). At baseline, nine children always refused food, no children were involved in self-feeding, and six were observed munching or chewing. At 4 to 6 months after the caregiver training, only one child was observed refusing food and six and eight children were involved in self-feeding and demonstrated munching or chewing, respectively. The authors also reported a significant improvement in caregiver self-reported stress and reduction in mealtime length (p=0.005).

Similarly, a study with a parent training component71 reviewed by Snider et al.34 reported an increase in parents' feeding effectiveness, but as noted, these studies are of high risk of bias (typically pre-post design) and report high attrition.

## Key Question 1b Is the effectiveness of behavioral interventions modified by age, race, severity, functional status (e.g. GMFCS level), or initial nutritional status?

No studies were designed or powered to directly assess this question. Of note, the studies focused on children with moderate or severe CP and provided little detail that might allow for stratification by severity or functional status. One study reported in the Snider review provides data separately for children with and without a history of aspiration.74,75 The study, reported in two publications rated as fair quality on the PEDro scale, reported improved eating efficiency and safety when eating pureed food for aspirating children after sensorimotor intervention, but no effect among those who did not aspirate.

## Key Question 2a Compared with other nonsurgical interventions or no intervention, how effective are nutritional interventions (food thickeners, caloric supplementation with formulas, vitamin supplementation, and altering food consistency (e.g. pureeing)), for improving nutritional state/ growth, health outcomes and health care/resource utilization, and quality of life in individuals with cerebral palsy and feeding difficulties?

No studies met criteria to address this question although pureed food was used in conjunction with positioning and sensorimotor interventions described in the review by Snider and colleagues.34

## Key Question 2b Is the effectiveness of nutritional interventions modified by age, race, severity, functional status (e.g. GMFCS level), or initial nutritional status?

No studies met criteria to address this question.

## Key Question 3a What is the comparative effectiveness of tube feeding compared with oral feeding or to nutritional and behavioral interventions in individuals with cerebral palsy who present with feeding difficulties, including malnourishment, failure to thrive, aspiration and excessive caregiver burden?

### Key Points

- The primary literature included six case series (described in eight publications) focused on assessing clinical outcomes after gastrostomy,87-94 one fair quality cohort study on the potential for overfeeding with gastrostomy that also included effectiveness data,95 one prospective case series assessing the potential for overfeeding using a low energy feed following gastrostomy,41 and one case series regarding the potential for gastrostomy to result in gastroesophageal reflux (GER).96 These latter three studies were considered harms studies.
- Case series included <60 participants each and reported improvements in weight gain, most measures of caregiver satisfaction, and hospitalizations due to chest infections.
- Harms included reflux, tube migration or blockage, stoma ulcers, gastric leakage, peritonitis, pneumonia, and gastrointestinal complications.
- The prospective cohort focused on potential overfeeding compared orally fed and gastrostomy-fed children and reported no significant differences between tube-fed and orally fed groups in normalized weight and skinfold z-scores, energy expenditure, resting metabolic rate, fat mass index, or fat-free mass index, but both groups had higher body fat content than a reference population of age- and sex-matched typically developing children.
- The case series assessing a low energy feed reported weight gain without a corresponding increase in fat mass.
- The strength of the evidence was low for measures of growth and harms of gastrotomy and insufficient for all other outcomes (respiratory outcomes including reflux, quality of life, long term morbidity and mortality).

### Overview of the Literature

The fair quality cohort study included 40 children with spastic quadriplegic CP from a tertiary feeding clinic. Children either had gastrostomy (n=22) or were able to eat orally (n=18) and were evaluated using growth measures and energy expenditure.95 Case series,41,87-94,96 were conducted in the United Kingdom, Canada, Brazil, Australia, and the United States and assessed gastrostomy with and without fundoplication in young children. Outcomes evaluated included measures of growth, quality of life, respiratory events, episodes of GER, and harms. Across studies, followup typically occurred 6 to 12 months after surgery, with one study following patients for up to 41 months91 and another for a median of 55 days.96

### Detailed Analysis

#### Effectiveness Data

Effectiveness data for gastrostomy come from one prospective cohort study,95 four prospective,87-89,92-94 and two retrospective case series90,91 (Table 9). The prospective cohort study was intended to assess potential harms of treatment and is therefore discussed in detail in that section, below. The one multicenter, prospective case series provides the most detailed outcomes data available.92-94 This study includes data collected systematically prior to the intervention, establishes primary outcomes a priori, controls for age and sex in reporting results, and uses standards for typically developing children as a comparison in z-score analyses. The study (reported in three publications92-94) included 57 children (age range: 5 months–17 years, median: 4 years) with CP and severe motor difficulties (75% with spastic quadriplegia, 93% unable to feed independently, 77% with global developmental delay) undergoing gastrostomy (percutaneous endoscopic gastrostomy [PEG] in 53 children and open gastrostomy in 4). Eighteen children with significant reflux (determined by a reflux index > 10% as proposed by Sullivan 1999^97^) had fundoplication performed at the same time as gastrostomy. The majority of children (n=53/57) had severe CP, assessed to be equivalent to level V GMFCS, with 95 percent unable to walk independently. All had substantial oral-motor impairment and feeding difficulty. None of the children had experienced adequate (not defined) weight gain for at least 12 months prior to surgery. Some had experienced no weight gain at all. Outcome measures included changes in body weight and skinfold measurement; dietary intake; general health (measured by infections requiring hospitalization or antibiotics); harms, including respiratory morbidity; and quality of life for caregivers (measured using the validated Short-Form 36, version II [SF-36]98). Although there was no active comparison group in this study, standards for typically developing children were used as a reference.

Table 9 Summary of key outcomes of studies of surgical interventions reporting effectiveness data

Author, Year Country Groups, Number of Participants, N Enrollment/N Final | Age CP Severity/Type, N (%) | Key Outcomes
Arrowsmith et al., 2010^87^ Australia G1: Gastrostomy, 21/21 | Age: 8 years, 5 months (median) Severity (GMFCS): Level V: 21 (100) | - Median gastrostomy feeding time=19.4 months, range=7.7-29.9 months; median followup=20.6 months, range 11.3-34.4 months; - Significant increase in weight, height, body fat at followup (p<0.05) with mean body weight increase of approximately 50%; - Significant increase in weight standard deviation (-4.8 at baseline, -3.0 at followup, p<0.05)
Mahant et al., 2009^89^ Canada G1: Gastrostomy or gastrojejunostomy tube feeding, 50/43 | Age: 591 days (median, range: 20–5663 days) Severity (among those with static neurologic disorder, GMFCS): Level V: 29 (69) Level IV: 6 (14) Level III: 5 (11) | - 42/50 participants had static neurological disorder; study assessed parent-reported child QOL and anthropometric changes; - Improvements from baseline to 6 months (including activities, parental time, feeding) but not sustained; - Improvement in medications sustained at 12 months; - No impact on pain, mental health, health perceptions, parental impact on emotions and respite care; - Overall significant increase in weight for age (baseline z-score -2.8 vs. -1.8 at followup, p<0.01) but not height (baseline -2.1 vs. -2.0 at followup); - At 12 months 87% of parents felt that tube insertion improved the health of their child; - 3 deaths
Sullivan et al., 2004, 2005, 2006^92-94^ United Kingdom G1:Gastrostomy (PEG=53, laparoscopic gastrostomy=2, open gastrostomy=2), 57/46 | Age: 4.32 years (median) Type: Spastic quadriplegic: 43 Mixed CP: 6 Hemiplegic:3 Undiagnosed: 3 Ataxia: 1 Extrapyramidal disorder: 1 | - Significant positive change in median z-scores for weight (-3 at baseline vs. -1.6 followup), head circumference (0.15 at baseline vs. 0.52 at followup), lower leg length (-1.21 at baseline vs. -0.44), arm circumference (-0,14 at baseline vs. 0.58 at followup), and skin fold measurements (-1.71 at baseline vs. -0.59 at followup) after 12 months, p values ranging from <0.0001 to 0.004; - Hospitalizations due to infection dropped from 26% at baseline to 7% at 12 months post-gastrostomy, p=0.021; number of infections requiring antibiotics did not change; - Significant decrease in both hospitalizations(mean # at baseline=0.5, at followup=0.09, p=0.04) and antibiotics for chest infections (mean # at baseline=1.8, at followup=0.0, p=0.07) after tube placement; no difference in hospitalization or antibiotics for chest infection in patients who had fundoplication; - 4/57 participants died, 1 prior to insertion of g-tube; - Significant improvement on caregiver-rated measures of social function (mean change 13.51, 95%CI 1.55 to 25.48; p=0.028), mental health (9.88, 95%CI 2.03 to 17.72; p=0.015), energy (9.94, 95%CI 2.29 to 17.58; p=0.012), general health perception (6.35, 95%CI 0.15 to 12.56; p=0.045), and mental component summary (7.06, 95%CI 0.90 to 13.22; p=0.026); no change in pain.; - At baseline, caregivers had lower QOL due to physical problems, emotional problems, social functioning, mental health, and energy compared with the general public. At the end of 12 months, these had normalized except for emotional problems; - Post gastrostomy, caregivers reported decreased feeding times and decreased overall concern about nutritional status and increased ease of medication administration
Brant et al., 1999^88^ Brazil G1: PEG, 16/16 | Age: 6.5 years (mean) Type: Tetraparesis: 16 | - Weight z-scores increased significantly from baseline in all participants; height and skinfold did not change significantly (data only reported graphically); - Harms included leakage, granulation tissue, ostomy infection, pneumonia, pneumoperitoneum; - 3 participants died
Rempel et al., 1988^90^ United States G1: Gastrostomy with and without fundoplication, 57/57 | Age: 10.7 (range: 9 months–23 years) Severity: No useful motor activity/dependent for all needs: 49 Moderate to severe involvement/dependent for most needs: 8 | - Over 70% of participants symptomatic for GER; 32 had Nissen fundoplication plus gastrostomy; - Most participants gained weight; roughly half attained appropriate height for weight standards, 21% were overweight, 33% were underweight; - 8/57 died after gastrostomy; 5 deaths occurred within 1 year of placement
Shapiro et al., 1986^91^ United States G1: Gastrostomy, 19/19 | Age: 60.4 months Severity: All were profoundly handicapped, 17/19 had oral-motor dysfunction | - Significant improvement in weight (3 participants >10^th^ percentile weight for length ratio preoperatively vs. 11 postoperatively, p<0.10) more than length; growth improved in most overall with children moving on average 1.5 standard deviations closer to 50^th^ percentile for children of similar ages; - 2 children required subsequent fundoplication

CP = cerebral palsy; G = group; GER = gastroesophageal reflux; GMFCS = Gross Motor Function Classification System; PEG = percutaneous endoscopic gastrostomy; QOL = quality of life

Participants improved on all measures of growth. Median weight z-scores (relative to standards for typically developing children of the same age and sex) increased from −3 at baseline to −1.6 at 12 months post-gastrostomy, and the proportion of children more than 2 standard deviations below the mean decreased from 2/3 to under half at 12 months. Linear growth (lower leg length, median baseline z-score −1.31 vs. −0.44 at followup) and head circumference (median baseline z-score among those with 12 month data available 0.15 vs. 0.52 at followup) measures improved significantly at followup as did arm circumference (median baseline z-score −0.14 vs. 0.58 at followup) and skinfold z-scores (median baseline z-score −1.71 vs. −0.59 at followup). Thus, improvements were observed and were statistically significant for every measure of growth (p values ranging from <0.0001 to 0.004).

Energy intake as measured by 3-day dietary records maintained by caregivers increased, and the proportion of children experiencing at least one infection requiring hospitalization decreased from 26 to 7 percent (p=0.021). A separate analysis of chest infections showed a significant decrease in the mean number of infections requiring antibiotics from baseline to 12 month followup (mean at baseline=1.8 [SD=2.7], mean at followup=0.9 [SD=1.7], p=0.07) and in hospitalizations for chest infection (mean at baseline=0.5 [SD=1.0], mean at followup=0.09 [SD=0.4], p=0.04).94

An Australian prospective case series including 21 children with quadriplegic CP (median age=8 years 5 months, all GMFCS level V) similarly reported significant increases in weight (median baseline weight in kg=15.4, followup=23.3, p<0.05) and height (median baseline height in cm=105.4, followup=118.3, p<0.05) after a median 19.4 months of gastrostomy tube feeding.87 Standard deviation scores for weight, but not height, also increased significantly (p<0.05). Body fat percentage increased from a median 10.7 percent at baseline to 16.3 percent at followup (p<0.05). Another prospective case series conducted in Brazil included 16 children (mean age 6.5 years) with CP and dysphagia or recurrent aspiration undergoing PEG tube placement; the study also included 4 children with swallowing dysfunction but not CP.88 Children were followed for a mean of 5.9 months (range: 2–10 months). Weight, but not height or skinfold, z-scores significantly increased from baseline across all participants (data presented graphically only).

A retrospective case series conducted in the United States assessed growth in gastrostomy-fed children with CP between the ages of 9 months and 23 years (mean=10.7 years). At the time of data collection, most participants had severe motor dysfunction, and over 70 percent had signs of GER.90 No data are provided on the proportion that had GER prior to surgery and it is not possible to assess whether surgery ameliorated or created cases of GER. Fifty-six percent (n=32) of participants had Nissen fundoplication as well as gastrostomy, suggesting that at least half had substantial reflux prior to surgery; two of these later required jejunostomy after failed fundoplication. Baseline and followup data were available for 35 participants; among these, roughly 70 percent remained below the 5^th^ percentile for height and weight post-gastrostomy. Roughly half (46%) attained appropriate weight for height standards, 21 percent were overweight, and 33 percent were underweight. In subgroup analyses, at least 50 percent of children with gastrostomy before age 2; those with gastrostomy for more than 2 years; and those with fundoplications reached appropriate weight for height. Caution should be used, however, in interpreting these data as reference standards in the literature are often for typically developing children and not an appropriate comparison for individuals with CP. Caregivers generally reported satisfaction with gastrostomy and noted increased ease of feeding and improvements in child affect.

An additional retrospective case series evaluated outcomes for 19 children with CP (mean age: 60.4 months) and reported increases in growth overall (baseline mean weight/length z-scores: −2.71, followup: −1.18).91 Two studies assessed quality of life. One, the Sullivan case series, assessed quality of life (QOL) of caregivers using the SF-36 and interviews with caregivers of these 57 children.93 Participants completed the questionnaire prior to their child's gastrostomy and at 6 and 12 months post-placement; roughly 35 individuals completed the 12-month followup. Baseline scores on all measures were lower than those for the population norm at baseline. By 12 months, scores had improved on all measures and improved significantly (p values <0.01) on the domains of Role limitations—emotional (baseline: 68.06 ± 31.05, followup: 73.54 ± 27.27), Energy/vitality (baseline: 41.59 ± 23.58, followup: 51.56 ± 22.46), and on the Mental Component summary (baseline: 40.10 ± 15.60, followup: 46.37 ± 11.84). Caregivers reported declines in feeding time from baseline (median: 2.5 hours/day) to 12 month followup (1 hour/day) and greater ease in medication administration. Caregiver concern/worry over their child's nutritional state also lessened post-gastrostomy, with 15 percent indicating concern at 12-month followup compared with 78 percent at baseline. While SF-36 scores improved overall, not all participants reported positive changes; scores on social functioning declined post-gastrostomy for one in four caregivers, and scores for 13 of 39 respondents were lower for the Energy/vitality domain.

The other study assessing QOL was also prospective, but focused on parental perception of the child's quality of life. In this series, 50 children underwent gastrostomy, 42 of whom had static neurologic disorders, presumably CP (overall median age: 591 days).89 Investigators used a 10 cm visual analog scale (VAS) to assess parental perception of the child's life and health, an unvalidated questionnaire adapted from the CHQ-PF50 to assess QOL, and collected anthropometric data at baseline and 12 months post-gastrostomy. The study also documented harms. Most parents (98%) expected QOL to improve for their children prior to gastrostomy; however, parent-rated VAS QOL scores did not differ between baseline and followup. Ratings on questions related to global health, impact on activities, and impact on feeding improved at 6 months, but improvements were not sustained at the final, 12-month followup. Ratings on questions related to impact on parental time and medications improved significantly at 12 months (p≤0.05), and ratings on bodily pain, mental health, health perceptions, and parental impact on emotions and respite care did not change. Weight for age z-scores increased significantly at 12 months (p<0.01) though height did not change significantly. Triceps skinfold measurements were increased or maintained.

#### Harms Data

Three studies were focused specifically on potential harms of gastrostomy; two were related to the potential to overfeed,41,95 and one on the potential to induce GER post-gastrostomy96 (Table 10).

Table 10 Summary of surgical papers focused on harms

Author, Year Country Groups, N Enrollment/N Final | Age (Median Years) CP Severity/Type, N | Key Outcomes
Thompson et al., 2011^96^ United Kingdom G1: Neurologically impaired with feeding difficulty treated with PEG, 10/10 | Age: 4.9 Severity: NR | - 9/10 participants had CP; 183 total GER events recorded pre-PEG (median =17.50); 355 events recorded post-PEG (median=39.50); - GER episodes measured with combined intraluminal pH and multiple intraluminal impedance monitoring pre- and post-gastrostomy; - Significant increase in both acidic and nonacidic reflux events post-PEG, with majority nonacidic; - Percent of the events reaching highest impedance channel was 56% pre-PEG and 82% post-PEG
Vernon-Roberts et al. 2010^41^ United Kingdom G1: Gastrostomy tube with or without fundoplication+low energy, high fiber enteral feed, 14/8 | Age: 2 Severity (GMFCS): Level V: 13 Level IV:1 | - Significant increases in weight 6^th^ month study period (p=0.012) without a change in fat mass; - Increase in muscle mass without increase fat stores; - No significant change in micronutrient status or fiber intake; - 50% decrease in chest infections requiring antibiotics; - 3 deaths during study period from respiratory infections related to CP
Sullivan et al., 2006^95^ United Kingdom G1: Gastrostomy tube, 22/14 G2: Orally fed, 18/11 | Age: G1: 9.0 (range: 1.3–14.6 ) G2: 8.0 (range: 1.3–18.9 ) Severity (GMFCS): G1: Level V: 19 Level IV: 2 G2: Level V:11 Level IV: 4 Level I: 1 | - Gastrostomy-fed children had greater fat mass and less fat-free mass than orally fed children with CP (differences not significant); - Both groups had higher fat content and lower lean muscle mass than reference population of normally developing children; - Number with GER not reported

CP = cerebral palsy; G = group; GER = gastroesophageal reflux; GMFCS = Gross Motor Function Classification System; N = number; NR = not reported; PEG = percutaneous endoscopic gastrostomy

A fair quality prospective cohort study included 40 consecutive children (median age: 8 years 6 months, range: 1–18 years) at a tertiary feeding clinic for children with neurological impairment in the United Kingdom.95 Given the reduced energy requirements of quadriplegic children with CP, it is conceivable that they might be overfed, which would be indicated by an imbalance in body composition (i.e., excessive fat mass to fat-free mass) and this was the focus of this study. Investigators also used a reference population of normally developing children for comparison. Twenty-two children were gastrostomy fed (approximately 2/3 also underwent preoperative nasogastric tube feeding prior to gastrostomy), and 18 were fed orally. Investigators took anthropometric (weight, skinfold, height), body composition, and energy expenditure measurements at baseline and after 12 months (median duration of tube feeding: 12 months, range: 4–60 months). As expected, children in the orally fed group had lower (less severe) GMFCS scores, lower weight, higher fat-free mass index, and lower skinfold thickness (p=0.01) z-scores than the gastrostomy group at baseline. Children in the gastrostomy group had lower energy expenditure (p=0.04) and resting metabolic rates and higher fat mass index (p=0.02) than the orally fed group at baseline.

At followup, the gastrostomy group had greater fat mass than the orally fed group, and had lower fat-free mass, but the differences were not statistically significant. Compared with data from the reference population, both CP groups had higher body fat content and lower fat-free content, with the gastrostomy group having greater fat mass relative to the reference population than the orally fed participants. The investigators note that results may be confounded by preoperative nasogastric tube feeding in the gastrostomy group and ongoing nutritional therapy (caloric supplementation and/or enteral feeds) in the orally fed participants, and the degree to which gastrostomy may be associated with poor outcomes from overfeeding remains unclear.95

One case series similarly addressing the potential for overfeeding assessed the use of a low-energy feed on weight, body fat, and other anthropometric measures (assessed using a doubly labeled water method); micronutrient status; and general health in 14 gastrostomy-fed children (median age=2 years).41 Participants had severe disability: all had spastic quadriplegic CP, a GMFCS level of V (n=13) or IV (n=1), and weight between 8 and 30kg at baseline (median=12.1 kg). All participants were solely tube-fed, and seven of 14 had undergone fundoplication in addition to gastrostomy. Six month followup data were available for eight of the 14 participants; three participants died of respiratory infections in the study period.

Participants' weight, mid-upper arm circumference, and lower leg length increased significantly over the 6-month feeding period. Fat mass and body fat percentage increased, but not significantly (fat mass at baseline=3.1 kg, at followup=5.0; body fat percentage at baseline=28.3, at followup=32.5). Fat mass was not significantly different from that of a reference group of children without disability, though these data should be interpreted with caution given the limited comparability of the two groups. Micronutrient levels were largely within normal limits both prior to and after gastrostomy feeding, with levels of zinc, coper, vitamin B1 and chromium elevated beyond recommended ranges at followup. Fiber intake remained below recommended levels, and bowel movement frequency was generally unchanged over the study period. Chest infections requiring antibiotics decreased in half of participants at followup; 25 percent had no chest infections pre- or post-gastrostomy.

In one case series, investigators used impedance monitoring to assess episodes of GER pre- and post-PEG in children with CP (n=9) and Down syndrome (n=1) and normal reflux indices.96 The intent of the study was to assess the degree to which tube feeding increased rates of GER. Participants' median age was 4.9 years (range: 0.5–16.8 years), and six were taking gastric pH/motility medications. The number of reflux events increased significantly post-PEG (183 at baseline to 355 post-PEG, p=0.047), with the percentage of events reaching the pharyngeal space increasing from 56 percent pre-procedure to 82 percent. The number of nonacidic events at followup was 182, while 173 were acidic. The proportion of reflux events that were acidic dropped from 85 percent prior to PEG to 51 percent after PEG. Weight increased over time (median weight gain: 2.53 kg, range: 0.8–7.24 kg), but the study was not designed to clearly ascertain the degree to which weight gain was associated with the PEG, and no comparisons were made to any reference group.

Table 11 outlines harms included in other surgical studies. In the Sullivan case series,92-94 four of 57 children died during the study period, which the investigators note is comparable with death rates reported in other studies of tube-fed children. Importantly, given the observed decreases in hospitalizations and no change in antibiotic use, gastrostomy did not appear to increase respiratory morbidity.94 No child in this study developed reflux that could not be managed medically. Three children died during the course of the quality of life study93; the authors note that deaths were due to the children's underlying condition rather than the gastrostomy. In the Brazilian case series,88 three participants died of causes thought to be unrelated to gastrostomy. In one retrospective case series, 23 percent of all participants had major complications including gastrointestinal bleeding (n=5), peritonitis (n=3), bowel obstruction (n=3), tube migration (n=2), wound dehiscence (n=1). Rates of harms did not differ among subgroups. Eight children died after gastrostomy, with 5 deaths occurring within 1 year of placement.90

Table 11 Harms reported in case series assessing effectiveness of feeding interventions in CP

Author, Year Study Design Number of Participants | Harm/Adverse Event | N (%)
Mahant et al., 2009^89^ Prospective case series n=50 | Peritonitis | 01 (2)
Mahant et al., 2009^89^ Prospective case series n=50 | Gastroesophageal reflux disease | 04 (8)
Mahant et al., 2009^89^ Prospective case series n=50 | Deaths^a^ | 03 (6)
Mahant et al., 2009^89^ Prospective case series n=50 | Tube removal during study | 04 (8)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Serious post-surgical complications (gastric leakage, peritonitis, skin erythema, excoriation and ulceration) | 01 (2)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Minor site infection | 27/46 (59)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Granulation tissue | 20/48 (42)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Leakage | 14/46( 30)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Tube blockages | 9/47 (19)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Tube migration | 03/46 (7)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Child pulled tube out | 02/46 (4)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Peritonitis | 01/46 (2)
Sullivan et al., 2004, 2005, 2006^92-94^ Prospective case series n=57 | Deaths (1 occurred prior to gastrostomy placement) | 04/57 (7)
Brant et al., 1999^88^ Prospective case series n=20 (16 with CP) | Deaths^a^ | 03 (15)
Brant et al., 1999^88^ Prospective case series n=20 (16 with CP) | Granulation^b^ | 7 (35)
Brant et al., 1999^88^ Prospective case series n=20 (16 with CP) | Ostomy infection | 07 (35)
Brant et al., 1999^88^ Prospective case series n=20 (16 with CP) | Pneumoperitoneum | 1 (5)
Brant et al., 1999^88^ Prospective case series n=20 (16 with CP) | Pneumonia | 03 (15)
Rempel et al., 1988^90^ Retrospective case series n=57 | Deaths^a^ | 8 (14)
Rempel et al., 1988^90^ Retrospective case series n=57 | Gastrointestinal bleeding and ulceration | 5 (9)
Rempel et al., 1988^90^ Retrospective case series n=57 | Peritonitis | 3 (5)
Rempel et al., 1988^90^ Retrospective case series n=57 | Bowel obstruction | 3 (5)
Rempel et al., 1988^90^ Retrospective case series n=57 | Tube migration | 2 (4)
Rempel et al., 1988^90^ Retrospective case series n=57 | Wound dehiscence | 1 (2)

CP = cerebral palsy; N = number; PEG = percutaneous endoscopic gastrostomy

a Deaths thought to be unrelated to study treatment; in Rempel et al.90 5/8 deaths occurred within 1 year of surgery.

b Study reports both 7/20 and 10/20 participants with granulation--not clear which number is accurate.

Overall, rates of peritonitis were low, ranging from 2 to 5 percent, one study reported minor site infections at 59 percent and leakage at 30 percent. Deaths ranged from 6 to 15 percent, but were considered not to be related to gastrostomy in all studies. Mortality is high among individuals with CP, and it is impossible to know whether the observed deaths were causally related to treatment or to the course of the condition.

## Key Question 3b Among individuals with cerebral palsy and feeding difficulties with significant reflux, what is the effectiveness of g-tube placement with fundoplication versus oral feeding for reducing reflux and for improving nutritional state/ growth, health outcomes and health care/resource utilization, and quality of life?

### Key Points

- One fair quality RCT,99 and one case series100 addressed surgical interventions in individuals with CP and reflux.
- Reflux in participants undergoing either Nissen fundoplication or vertical gastric plication improved; the mean number of episodes decreased from 11.28 at baseline to 2.9 at followup in the Nissen group versus 6.35 at baseline and 4.40 at followup in the vertical plication group.
- In a case series, children undergoing gastrostomy plus Nissen fundoplication showed improvements in reflux symptoms and weight gain but not episodes of pneumonia; 30 percent of participants had recurrent reflux post-surgery.
- Harms included valve migration, gastrointestinal bleeding, peritonitis, pneumonia, and gastrointestinal symptoms.

### Overview of the Literature

One RCT99 and one case series100 addressed surgical intervention in individuals with CP and reflux. A good quality, Cochrane review attempted to study efficacy of fundoplication versus post-operative medication to control GER in CP but identified no studies meeting inclusion criteria.63 The review is therefore not summarized further.

The fair quality RCT, conducted in Brazil, randomized 14 children (age range: 4–147 months) to either fundoplication or gastric plication and evaluated changes in episodes of GER.99 Followup lasted for an average of 5.2 months. One case series,100 conducted in China, included 20 children (ages ranging from 3.9 to 14.4 years at surgery) and assessed gastrostomy with Nissen fundoplication; nine participants underwent an open procedure while the rest were laparoscopic. Outcomes evaluated included measures of growth, episodes of GER, and harms over a median of 3.5 years of followup.100

### Detailed Analysis

#### Effectiveness Data

No studies directly compared the use of g-tube with fundoplication to oral feeding. One fair quality RCT compared Nissen fundoplication (in which the upper part of the stomach is wrapped around the lower esophagus to create a one-way valve) with vertical gastric plication (in which the esophagus is lengthened) at two hospitals in Brazil.99 GERD was established in the participants based on esophageal pH. Both groups had clinically significant improvement in reflux symptoms. The Nissen fundoplication group had a statistically significant decrease in the total number of reflux episodes (p=0.012), percentage of pH (p=0.002), and composite of pH parameters (p<0.001), whereas the vertical gastric plication group had a significant decrease in pH parameters (p=0.041) and percentage (p=0.042). There was no difference between the groups in the length of the procedure or hospitalization.

In one prospective case series, reflux and pH monitoring were reported to be improved after gastrostomy plus Nissen fundoplication, regardless of laparoscopic versus open approach (baseline median reflux index=5.7% vs. 0.15%, p=0.009).100 Within one year after surgery, 30 percent of the patients had a relapse in reflux symptoms but were responsive to medical intervention. Table 12 summarizes key outcomes of these studies.

Table 12 Summary of key outcomes of studies of surgical interventions in individuals with CP and significant reflux

Author, Year Country Groups, Number of Participants (Enrollment/Final) | Age CP Type | Key Outcomes
Durante et al., 2007^99^ Brazil G1: Nissen fundoplication, 7/7 G2: Vertical gastric plication, 7/7 | Age: 67.8 months (overall mean, range: 4–147 months) Type: G1: Diplegic spastic: 2 Tetraplegic spastic: 5 G2: Diplegic spastic: 2 Tetraplegic spastic: 5 | - 2 children in G1 also underwent gastrostomy and 2 underwent gastrostomy and tracheostomy; 2 in G2 underwent gastrostomy.; - Significant reduction in parameters related to GERD in both groups (p≤0.006).; - 42.8% of G1 and 57.1% of G2 participants asymptomatic throughout followup period.; - All esophageal pH measurements except number of reflux episodes >5 minutes improved significantly in G1; total # of reflux episodes, number episodes >5 minutes, and longer reflux episodes did not improve significantly in G2.; - Length of stay and duration and surgery were not significantly different between groups.
Cheung et al., 2006^100^ China G1: Nissen fundoplication plus gastrostomy, 20/20 | Age: 8.5 ± 3.5 (mean years ± SD) Type: Mixed: 5 Spastic: 13 Hypotonic: 1 Dystonic: 1 | - Participants were residents at rehabilitation center for individuals with severe neurological impairment and undergone nasogastric feeding for minimum 12 months prior to surgery; all had GER for at least 3 months and were taking antireflux medications; 9 had open surgery, 11 laparoscopic.; - Median reflux index decreased significantly post-surgery (p=0.009) and median longest reflux, median # of reflux episodes >5 minutes improved; weight increased from mean 17.4 kg at baseline to 22.8 kg at median followup of 3.5 years.; - 6/20 (30%) of participants had recurrent reflux post-surgery.; - Improvements in vomiting and gastrointestinal bleeding indices sustained at 4 years post-surgery; pneumonia index not significantly affected.

CP = cerebral palsy; G = group; GER = gastroesophageal reflux; GERD = gastroesophageal reflux disease; SD = standard deviation; UTI = urinary tract infection

#### Harms Data

The RCT comparing Nissen fundoplication with vertical gastric plication reported a rate of major complications (valve migration, hernia) of 14.3 percent in both the Nissen and vertical plication groups. Other harms reported are listed in Table 13; two participants died during the study (one in each group, considered unrelated to surgery).99 In the case series early complications (within one week of fundoplication) included pneumothorax, stoma ulcers, and cellulitis, all in patients undergoing laparoscopic fundoplication. Late complications (i.e., more than one week post-fundoplication) included bloating, diarrhea (dumping syndrome), and intestinal obstruction; these events were all reported in individuals undergoing open fundoplication.100

Table 13 Harms reported in primary research studies of surgical interventions in individuals with CP and significant reflux

Study Study Design Number of Participants | Harm/Adverse Event | N (%)
Durante et al., 2007^99^ RCT n=14 | Valve migration | 1 (14)
Durante et al., 2007^99^ RCT n=14 | Paraesophageal hernia | 1 (14)
Durante et al., 2007^99^ RCT n=14 | Aspiration of contrast into tracheobronchial tree | 2 (29)
Durante et al., 2007^99^ RCT n=14 | Urinary tract infection | 1 (14)
Durante et al., 2007^99^ RCT n=14 | Pneumonia | 2 (29)
Durante et al., 2007^99^ RCT n=14 | Deaths^a^ | 2 (29)
Cheung et al., 2006^100^ Prospective case series n=20 | Recurrent gastroesophageal reflux postoperatively | 6 (30)
Cheung et al., 2006^100^ Prospective case series n=20 | Pneumothorax | 1 (5)
Cheung et al., 2006^100^ Prospective case series n=20 | Stoma ulcers | 6 (30)
Cheung et al., 2006^100^ Prospective case series n=20 | Air bloating and diarrhea | 1 (5)
Cheung et al., 2006^100^ Prospective case series n=20 | Intestinal obstruction | 1 (5)
Cheung et al., 2006^100^ Prospective case series n=20 | Deaths^a^ | 4 (20)

CP = cerebral palsy; N = number; RCT = randomized controlled trial

a Deaths thought to be unrelated to study treatment.

## Key Question 3c Among individuals who develop reflux following gastrostomy, what is the comparative effectiveness of j-tube versus fundoplication for reducing reflux in the short term and achieving improvements in nutritional state/ growth, health outcomes and health care/resource utilization, and quality of life?

We did not identify any studies addressing this Key Question.

## Key Question 3d Is the effectiveness of tube feeding modified by tube placement, age, race, severity, functional status (e.g. GMFCS level), initial nutritional status, or continuous v bolus feeding?

Sub-analyses were conducted in two case series88,90 to assess the degree to which age and type of procedure modified outcomes. In the first, children were divided into age bands of <2, 2 to 4, 5 to 7, 8 to 11 and 12 to 18. No age group included more than five children. Weight increased in all groups except ages 5 to 7, although this group had significant increases in triceps skinfold measurement. The very small size of each group, however, precludes any conclusion about age as a modifier. The other, retrospective case series of 57 individuals90 reported that the highest proportion of individuals reaching weight for height were in the groups that had surgery before age 2, had had their gastrostomy for at least 2 years or had fundoplication. The group of children who had their gastrostomies earliest in life also had the smallest proportion remaining at less than the 5^th^ percentile of weight for height. Because this is a retrospective study, however, it is likely that the groups represent patient populations that presented with differing levels of severity or indication; thus the comparisons are likely confounded by indication. One study assessed outcomes by the presence of fundoplication.94 This analysis suggested that use of antibiotics and respiratory hospitalizations did not differ by whether the child had a fundoplication. The decision about whether or not to use fundoplication, was made clinically and not for research purposes.

One series evaluating the g-tube with fundoplication found no difference in outcomes associated with laparoscopic versus open approach.100 The intent of the study was not to compare the two approaches; rather, the clinical team changed their approach during the course of the study.

## Grey Literature

### Regulatory Information

The manufacturer of the VitalStim device, DJO, noted that no controlled studies have been conducted on the use of VitalStim specifically to treat dysphagia and provided a summary of evidence related to neuromuscular electrical stimulation in general. None of the studies included in the summary appeared to include individuals with CP. We did not identify effectiveness or safety information in other resources including the U.S. Food and Drug Administration web site.

### Conference Abstracts

We located conference abstracts from 2009–2012 from the annual meetings of the American Academy of Cerebral Palsy and Developmental Medicine and the American Academy of Physical Medicine and Rehabilitation. Abstracts from 2012 for the American Academy of Physical Medicine and Rehabilitation meeting were not available as the annual meeting had not taken place at the time of this review's conduct.

We did not identify any poster or presentation abstracts of relevance to the current review among those available. Some presentations assessed elements that may modify growth (e.g., GMFCS status) or used registries to evaluate prevalence of feeding problems, but we did not identify any abstracts assessing interventions for feeding or nutritional status.