# References

1 Bax M, Goldstein M, Rosenbaum P, et al. Proposed definition and classification of cerebral palsy, April 2005. Dev Med Child Neurol. Aug. 2005;47(8):571-6. [pmid: 16108461].
2 Rosenbaum P, Paneth N, Leviton A, et al. A report: the definition and classification of cerebral palsy April 2006. Dev Med Child Neurol. Suppl. Feb. 2007;109:8-14. [pmid: 17370477].
3 Economic costs of birth defects and cerebral palsy--United States, 1992. MMWR Morb Mortal Wkly Rep. Sep. 22. 1995;44(37):694-9. [pmid: 7666849].
4 Aday LA. Health insurance and utilization of medical care for chronically ill children with special needs. Health of our nation's children, United States, 1988. Adv Data. Aug. 18. 1992;(215):1-8. [pmid: 10126842].
5 Arneson CL, Durkin MS, Benedict RE, et al. Prevalence of cerebral palsy: Autism and Developmental Disabilities Monitoring Network, three sites, United States, 2004. Disability and Health Journal. 2009;2:45-8. [pmid: 21122742].
6 Bhasin TK, Brocksen S, Avchen RN, et al. Prevalence of four developmental disabilities among children aged 8 years--Metropolitan Atlanta Developmental Disabilities Surveillance Program, 1996 and 2000. MMWR Surveill Summ. Jan. 27. 2006;55(1):1-9. [pmid: 16437058].
7 Boyle CA, Boulet S, Schieve LA, et al. Trends in the prevalence of developmental disabilities in US children, 1997-2008. Pediatrics. Jun. 2011;127(6):1034-42. [pmid: 21606152].
8 Boyle CA, Yeargin-Allsopp M, Doernberg NS, et al. Prevalence of selected developmental disabilities in children 3-10 years of age: the Metropolitan Atlanta Developmental Disabilities Surveillance Program, 1991. MMWR CDC Surveill Summ. Apr. 19. 1996;45(2):1-14. [pmid: 8602136].
9 Newacheck PW, McManus MA, Gephart J. Health insurance coverage of adolescents: a current profile and assessment of trends. Pediatrics. Oct. 1992;90(4):589-96. [pmid: 1408514].
10 Winter S, Autry A, Boyle C, et al. Trends in the prevalence of cerebral palsy in a population-based study. Pediatrics. Dec. 2002;110(6):1220-5. [pmid: 12456922].
11 Yeargin-Allsopp M, Van Naarden Braun K, Doernberg NS, et al. Prevalence of cerebral palsy in 8-year-old children in three areas of the United States in 2002: a multisite collaboration. Pediatrics. Mar. 2008;121(3):547-54. [pmid: 18310204].
12 Binks JA, Barden WS, Burke TA, et al. What do we really know about the transition to adult-centered health care? A focus on cerebral palsy and spina bifida. Arch Phys Med Rehabil. Aug. 2007;88(8):1064-73. [pmid: 17678671].
13 Cooley WC. Providing a primary care medical home for children and youth with cerebral palsy. Pediatrics. Oct. 2004;114(4):1106-13. [pmid: 15466117].
14 Crichton JU, Mackinnon M, White CP. The life-expectancy of persons with cerebral palsy. Dev Med Child Neurol. Jul. 1995;37(7):567-76. [pmid: 7615144].
15 Donkervoort M, Roebroeck M, Wiegerink D, et al. Determinants of functioning of adolescents and young adults with cerebral palsy. Disabil Rehabil. Mar. 30. 2007;29(6):453-63. [pmid: 17364800].
16 Murphy KP, Molnar GE, Lankasky K. Medical and functional status of adults with cerebral palsy. Dev Med Child Neurol. Dec. 1995;37(12):1075-84. [pmid: 8566465].
17 Rapp CE Jr., Torres MM. The adult with cerebral palsy. Arch Fam Med. May. 2000;9(5):466-72. [pmid: 10810953].
18 Economic costs associated with mental retardation, cerebral palsy, hearing loss, and vision impairment--United States, 2003. MMWR Morb Mortal Wkly Rep. Jan. 30. 2004;53(3):57-9. [pmid: 14749614].
19 Jones MW, Morgan E, Shelton JE, et al. Cerebral palsy: introduction and diagnosis (part I). J Pediatr Health Care. May-Jun. 2007;21(3):146-52. [pmid: 17478303].
20 Pakula AT, Van Naarden Braun K, Yeargin-Allsopp M. Cerebral palsy: classification and epidemiology. Phys Med Rehabil Clin N Am. Aug. 2009;20(3):425-52. [pmid: 19643346].
21 Palisano R, Rosenbaum P, Walter S, et al. Development and reliability of a system to classify gross motor function in children with cerebral palsy. Dev Med Child Neurol. Apr. 1997;39(4):214-23. [pmid: 9183258].
22 Sullivan PB, Lambert B, Rose M, et al. Prevalence and severity of feeding and nutritional problems in children with neurological impairment: Oxford Feeding Study. Dev Med Child Neurol. Oct. 2000;42(10):674-80. [pmid: 11085295].
23 Murphy CC, Yeargin-Allsopp M, Decoufle P, et al. Prevalence of cerebral palsy among ten-year-old children in metropolitan Atlanta, 1985 through 1987. J Pediatr. Nov. 1993;123(5):S13-20. [pmid: 8229472].
24 Odding E, Roebroeck ME, Stam HJ. The epidemiology of cerebral palsy: incidence, impairments and risk factors. Disabil Rehabil. Feb. 28. 2006;28(4):183-91. [pmid: 16467053].
25 Fennell EB, Dikel TN. Cognitive and neuropsychological functioning in children with cerebral palsy. J Child Neurol. Jan. 2001;16(1):58-63. [pmid: 11225958].
26 Heinen F, Desloovere K, Schroeder AS, et al. The updated European Consensus 2009 on the use of Botulinum toxin for children with cerebral palsy. Eur J Paediatr Neurol. Jan. 2010;14(1):45-66. [pmid: 19914110].
27 Evans PM, Evans SJ, Alberman E. Cerebral palsy: why we must plan for survival. Arch Dis Child. Dec. 1990;65(12):1329-33. [pmid: 2148667].
28 Reid SM, Carlin JB, Reddihough DS. Survival of individuals with cerebral palsy born in Victoria, Australia, between 1970 and 2004. Dev Med Child Neurol. Apr. 2012;54(4):353-60. [pmid: 22329739].
29 Maudsley G, Hutton JL, Pharoah PO. Cause of death in cerebral palsy: a descriptive study. Arch Dis Child. Nov. 1999;81(5):390-4. [pmid: 10519709].
30 Strauss D, Cable W, Shavelle R. Causes of excess mortality in cerebral palsy. Dev Med Child Neurol. Sep. 1999;41(9):580-5. [pmid: 10503915].
31 Reilly S, Skuse D, Poblete X. Prevalence of feeding problems and oral motor dysfunction in children with cerebral palsy: a community survey. J Pediatr. Dec. 1996;129(6):877-82. [pmid: 8969730].
32 Calis EA, Veugelers R, Sheppard JJ, et al. Dysphagia in children with severe generalized cerebral palsy and intellectual disability. Dev Med Child Neurol. Aug. 2008;50(8):625-30. [pmid: 18754902].
33 Venkateswaran S, Shevell MI. Comorbidities and clinical determinants of outcome in children with spastic quadriplegic cerebral palsy. Dev Med Child Neurol. Mar. 2008;50(3):216-22. [pmid: 18248493].
34 Snider, Majnemer A, Darsaklis V. Feeding Interventions for Children With Cerebral Palsy: A Review of the Evidence. Physical & Occupational Therapy in Pediatrics. 2011;31(1):58-77. [pmid: 20950250].
35 Greer AJ, Gulotta CS, Masler EA, et al. Caregiver stress and outcomes of children with pediatric feeding disorders treated in an intensive interdisciplinary program. J Pediatr Psychol. Jul. 2008;33(6):612-20. [pmid: 18056140].
36 Sleigh G, Brocklehurst P. Gastrostomy feeding in cerebral palsy: a systematic review. Arch Dis Child. Jun. 2004;89(6):534-9. [pmid: 15155398].
37 Vandenplas Y, Rudolph CD, Di Lorenzo C, et al. Pediatric gastroesophageal reflux clinical practice guidelines: joint recommendations of the North American Society for Pediatric Gastroenterology, Hepatology, and Nutrition (NASPGHAN) and the European Society for Pediatric Gastroenterology, Hepatology, and Nutrition (ESPGHAN). J Pediatr Gastroenterol Nutr. Oct. 2009;49(4):498-547. [pmid: 19745761].
38 Delgado MR, Hirtz D, Aisen M, et al. Pharmacologic treatment of spasticity in children and adolescents with cerebral palsy (an evidence-based review): Report of the Quality Standards Subcommittee of the American Academy of Neurology and the Practice Committee of the Child Neurology Society. Neurology. Jan. 2010;74(4):336-43. PMID: 2010-03233-003. [pmid: 20101040].
39 Liptak GS, Murphy NA. Providing a primary care medical home for children and youth with cerebral palsy. Pediatrics. Nov. 2011;128(5):e1321-9. [pmid: 22042817].
40 Hemming K, Hutton JL, Pharoah PO. Long-term survival for a cohort of adults with cerebral palsy. Dev Med Child Neurol. Feb. 2006;48(2):90-5. [pmid: 16417662].
41 Vernon-Roberts A, Wells J, Grant H, et al. Gastrostomy feeding in cerebral palsy: enough and no more. Dev Med Child Neurol. Dec. 2010;52(12):1099-105. [pmid: 20964670].
42 Agency for Healthcare Research and Quality. Research Protocol: Feeding and Nutrition Interventions in Cerebral Palsy. AHRQ. Rockville, MD. 2012. effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=1138&pageaction=displayproduct.
43 Dove D, Reimschisel T, McPheeters M, Jackson K, Glasser A, Curtis P, Gordon C, Stearns S, Mattson K, Church B. Developmental Disabilities Issues Exploration Forum: Cerebral Palsy. Research White Paper. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.) AHRQ Publication No. 11(12)-EHC078-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2011. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
44 Samson-Fang L, Butler C, O'Donnell M. Effects of gastrostomy feeding in children with cerebral palsy: an AACPDM evidence report. Dev Med Child Neurol. Jun. 2003;45(6):415-26. [pmid: 12785443].
45 Mollitt DL, Golladay ES, Seibert JJ. Symptomatic gastroesophageal reflux following gastrostomy in neurologically impaired patients. Pediatrics. Jun. 1985;75(6):1124-6. [pmid: 4000789].
46 Samuel M, Holmes K. Quantitative and qualitative analysis of gastroesophageal reflux after percutaneous endoscopic gastrostomy. J Pediatr Surg. Feb. 2002;37(2):256-61. [pmid: 11819210].
47 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov.
48 Higgins JPT, Altman DG. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.0.1. [updated September 2008]. The Cochrane Collaboration. 2008. Available at www.cochrane-handbook.org.
49 Wells GA, Shea B, O'Connell D, Peterson J, Welch V, et al. Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa Hospital Research Institute. www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
50 Viswanathan M, Ansari MT, Berkman ND, Chang S, Hartling L, McPheeters ML, Santaguida PL, Shamliyan T, Singh K, Tsertsvadze A, Treadwell JR. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Effective Health Care Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. March. 2012. AHRQ Publication No. 12-EHC047-EF. www.effectivehealthcare.ahrq.gov/.
51 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
52 Armijo-Olivo S, Stiles CR, Hagen NA, et al. Assessment of study quality for systematic reviews: a comparison of the Cochrane Collaboration Risk of Bias Tool and the Effective Public Health Practice Project Quality Assessment Tool: methodological research. J Eval Clin Pract. Feb. 2012;18(1):12-8. [pmid: 20698919].
53 Deeks JJ, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
54 Hartling L, Ospina M, Liang Y, et al. Risk of bias versus quality assessment of randomised controlled trials: cross sectional study. Br Med J. 2009;339:b4012. [pmid: 19841007].
55 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. Br Med J. 2011;343:d5928. [pmid: 22008217].
56 Shea BJ, Bouter LM, Peterson J, et al. External validation of a measurement tool to assess systematic reviews (AMSTAR). PLoS One. 2007;2(12):e1350. [pmid: 18159233].
57 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. Oct. 2009;62(10):1013-20. [pmid: 19230606].
58 White CM, Ip S, McPheeters M, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. [posted September 2009]. Rockville, MD. effectivehealthcare.ahrq.gov/healthInfo.cfm?infotype=rr&ProcessID=60.
59 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
60 Gisel EG. Oral-motor skills following sensorimotor intervention in the moderately eating-impaired child with cerebral palsy. Dysphagia. Summer. 1994;9(3):180-92. [pmid: 8082327].
61 Gisel EG. Effect of oral sensorimotor treatment on measures of growth and efficiency of eating in the moderately eating-impaired child with cerebral palsy. Dysphagia. Winter. 1996;11(1):48-58. [pmid: 8556879].
62 Sleigh G, Sullivan PB, Thomas AG. Gastrostomy feeding versus oral feeding alone for children with cerebral palsy. Cochrane Database Syst Rev. 2004;(2):CD003943. [pmid: 15106226].
63 Vernon-Roberts A, Sullivan PB. Fundoplication versus post-operative medication for gastro-oesophageal reflux in children with neurological impairment undergoing gastrostomy. Cochrane Database Syst Rev. 2007;(1):CD006151. [pmid: 17253583].
64 Whittingham, Wee D, Boyd R. Systematic review of the efficacy of parenting interventions for children with cerebral palsy. Child: Care, Health & Development. 2011;37(4):475-83.
65 Wilcox DD, Potvin M, Prelock PA. Oral motor interventions and cerebral palsy: using evidence to inform practice. Early Intervention & School Special Interest Section Quarterly. 2009;16(4):1-4.
66 Adams MS, Khan NZ, Begum SA, et al. Feeding difficulties in children with cerebral palsy: low-cost caregiver training in Dhaka, Bangladesh. Child Care Health Dev. 2011. Nov. 15. [pmid: 22082112].
67 Pinnington L, Hegarty J. Effects of consistent food presentation on oral-motor skill acquisition in children with severe neurological impairment. Dysphagia. Fall. 2000;15(4):213-23. [pmid: 11014884].
68 Gerek M, Çiyiltepe M. Dysphagia management of pediatric patients with cerebral palsy. Br J Dev Disabil. 2005;51 part 1(100):57-72.
69 Gisel EG, Schwartz S, Petryk A, et al. “Whole body” mobility after one year of intraoral appliance therapy in children with cerebral palsy and moderate eating impairment. Dysphagia. Fall. 2000;15(4):226-35. [pmid: 11014886].
70 Banerdt B, Bricker D. Training program for selected self-feeding skills for the motorically impaired. American Association for the Education of the Severely/profoundly Handicapped Review. 1978;3(4):222-9.
71 Clawson EP, Kuchinski KS, Bach R. Use of behavioral interventions and parent education to address feeding difficulties in young children with spastic diplegic cerebral palsy. NeuroRehabilitation. 2007;22(5):397-406. [pmid: 18162702].
72 Helfrich-Miller KR, Rector KL, Straka JA. Dysphagia: its treatment in the profoundly retarded patient with cerebral palsy. Arch Phys Med Rehabil. Aug. 1986;67(8):520-5. [pmid: 3741076].
73 Ganz SF. Decreasing tongue thrusting and tonic bite reflex through neuromotor and sensory facilitation techniques. Physical and Occupational Therapy in Pediatrics. 1987;7(4):57-75.
74 Gisel EG, Applegate-Ferrante T, Benson JE, et al. Effect of oral sensorimotor treatment on measures of growth, eating efficiency and aspiration in the dysphagic child with cerebral palsy. Dev Med Child Neurol. Jun. 1995;37(6):528-43. [pmid: 7789662].
75 Gisel EG, Applegate-Ferrante T, Benson J, et al. Oral-motor skills following sensorimotor therapy in two groups of moderately dysphagic children with cerebral palsy: aspiration vs nonaspiration. Dysphagia. Winter. 1996;11(1):59-71. [pmid: 8556880].
76 Morton RE, Bonas R, Fourie B, et al. Videofluoroscopy in the assessment of feeding disorders of children with neurological problems. Dev Med Child Neurol. May. 1993;35(5):388-95. [pmid: 8495819].
77 Larnert G, Ekberg O. Positioning improves the oral and pharyngeal swallowing function in children with cerebral palsy. Acta Paediatr. Jun. 1995;84(6):689-92. [pmid: 7670257].
78 Vekerdy Z. Management of seating posture of children with cerebral palsy by using thoracic-lumbar-sacral orthosis with non-rigid SIDO frame. Disabil Rehabil. Sep. 30. 2007;29(18):1434-41. [pmid: 17729090].
79 Croft RD. What consistency of food is best for children with cerebral palsy who cannot chew?. Arch Dis Child. Mar. 1992;67(3):269-71. [pmid: 1575546].
80 Haberfellner H, Rossiwall B. Appliances for treatment of oral sensori--motor disorders. Am J Phys Med. Oct. 1977;56(5):241-8. [pmid: 910881].
81 Fischer-Brandies H, Avalle C, Limbrock GJ. Therapy of orofacial dysfunctions in cerebral palsy according to Castillo-Morales: first results of a new treatment concept. Eur J Orthod. May. 1987;9(2):139-43. [pmid: 3472892].
82 Gisel EG, Schwartz S, Haberfellner H. The Innsbruck Sensorimotor Activator and Regulator (ISMAR): construction of an intraoral appliance to facilitate ingestive functions. ASDC J Dent Child. May-Jun. 1999;66(3):180-7. 54. [pmid: 10476356].
83 Gisel EG, Haberfellner H, Schwartz S. Impact of oral appliance therapy: are oral skills and growth maintained one year after termination of therapy?. Dysphagia. Fall. 2001;16(4):296-307. [pmid: 11720405].
84 Haberfellner H, Schwartz S, Gisel EG. Feeding skills and growth after one year of intraoral appliance therapy in moderately dysphagic children with cerebral palsy. Dysphagia. Spring. 2001;16(2):83-96. [pmid: 11305226].
85 Johnson HM, Reid SM, Hazard CJ, et al. Effectiveness of the Innsbruck Sensorimotor Activator and Regulator in improving saliva control in children with cerebral palsy. Dev Med Child Neurol. Jan. 2004;46(1):39-45. [pmid: 14974646].
86 Pinnington L, Hegarty J. Effects of consistent food presentation on efficiency of eating and nutritive value of food consumed by children with severe neurological impairment. Dysphagia. Winter. 1999;14(1):17-26. [pmid: 9828270].
87 Arrowsmith F, Allen J, Gaskin K, et al. The effect of gastrostomy tube feeding on body protein and bone mineralization in children with quadriplegic cerebral palsy. Dev Med Child Neurol. Nov. 2010;52(11):1043-7. [pmid: 20497453].
88 Brant CQ, Stanich P, Ferrari AP Jr. Improvement of children's nutritional status after enteral feeding by PEG: an interim report. Gastrointest Endosc. Aug. 1999;50(2):183-8. [pmid: 10425410].
89 Mahant S, Friedman JN, Connolly B, et al. Tube feeding and quality of life in children with severe neurological impairment. Arch Dis Child. Sep. 2009;94(9):668-73. [pmid: 19465586].
90 Rempel GR, Colwell SO, Nelson RP. Growth in children with cerebral palsy fed via gastrostomy. Pediatrics. Dec. 1988;82(6):857-62. [pmid: 3186375].
91 Shapiro BK, Green P, Krick J, et al. Growth of severely impaired children: neurological versus nutritional factors. Dev Med Child Neurol. Dec. 1986;28(6):729-33. [pmid: 3817311].
92 Sullivan PB, Juszczak E, Bachlet AM, et al. Gastrostomy tube feeding in children with cerebral palsy: a prospective, longitudinal study. Dev Med Child Neurol. Feb. 2005;47(2):77-85. [pmid: 15707230].
93 Sullivan PB, Juszczak E, Bachlet AM, et al. Impact of gastrostomy tube feeding on the quality of life of carers of children with cerebral palsy. Dev Med Child Neurol. Dec. 2004;46(12):796-800. [pmid: 15581151].
94 Sullivan PB, Morrice JS, Vernon-Roberts A, et al. Does gastrostomy tube feeding in children with cerebral palsy increase the risk of respiratory morbidity?. Arch Dis Child. Jun. 2006;91(6):478-82. [pmid: 16446283].
95 Sullivan PB, Alder N, Bachlet AM, et al. Gastrostomy feeding in cerebral palsy: too much of a good thing?. Dev Med Child Neurol. Nov. 2006;48(11):877-82. [pmid: 17044953].
96 Thomson M, Rao P, Rawat D, et al. Percutaneous endoscopic gastrostomy and gastro-oesophageal reflux in neurologically impaired children. World J Gastroenterol. Jan. 14. 2011;17(2):191-6. [pmid: 21245991].
97 Sullivan PB. Gastrostomy feeding in the disabled child: when is an antireflux procedure required?. Arch Dis Child. Dec. 1999;81(6):463-4. [pmid: 10569957].
98 Ware JE Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
99 Durante AP, Schettini ST, Fagundes DJ. Vertical gastric plication versus Nissen fundoplication in the treatment of gastroesophageal reflux in children with cerebral palsy. Sao Paulo Med J. Jan. 4. 2007;125(1):15-21. [pmid: 17505680].
100 Cheung KM, Tse HW, Tse PW, et al. Nissen fundoplication and gastrostomy in severely neurologically impaired children with gastroesophageal reflux. Hong Kong Med J. Aug. 2006;12(4):282-8. [pmid: 16912355].
101 Wockenforth R, Gillespie CS, Jaffray B. Survival of children following Nissen fundoplication. Br J Surg. May. 2011;98(5):680-5. [pmid: 21351077].
102 Smith SW, Camfield C, Camfield P. Living with cerebral palsy and tube feeding: A population-based follow-up study. J Pediatr. Sep. 1999;135(3):307-10. [pmid: 10484794].