# Methods

## Topic Development and Refinement

The topic for this report was nominated in a public process. We drafted the initial Key Questions and analytic framework and refined them with input from key informants with expertise in child health and development, pediatric gastroenterology, occupational therapy, neurodevelopment, and developmental disabilities. After review from the Agency for Healthcare Research and Quality (AHRQ), the questions and framework were posted to a public Web site. The public was invited to comment on these questions.

After reviewing the public commentary, we drafted final Key Questions and submitted them to AHRQ for review. During the topic development phase we identified a recent, rigorously conducted systematic review addressing behavioral feeding interventions.34 We thus structured the part of the review relevant to behavioral interventions as an update to the previous reviews. We developed a protocol for the review that was also posted to the AHRQ Effective Health Care web site.42

We identified technical experts on the topic of feeding and nutrition in cerebral palsy (CP) to provide assistance during the project. Technical Expert Panel (TEP) members represented the clinical and research communities from a range of perspectives and were invited to participate based on our commitment to engaging a range of experts who could help solidify the decisional dilemmas facing individuals and families with CP. They included both researchers and clinicians with expertise in behavioral, medical, surgical, and allied health approaches. We identified TEP members through scanning recent research related to CP, reviewing stakeholders in an AHRQ-funded research exploration forum on CP,43 and through discussions with our AHRQ Task Order Officer (TOO). All candidates were approved by the TOO after disclosure and review of potential conflicts of interest.

The TEP contributed to AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and Key Questions at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Ensure that relevant outcomes and studies were addressed.

### Role of the AHRQ Task Order Officer

The TOO was responsible for overseeing all aspects of this project. The TOO helped to develop a common understanding among all parties involved in the project, resolved questions and ambiguities, and addressed our queries regarding the scope and processes of the project. The TOO reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

### Analytic Framework

The analytic framework (Figure 1) outlines the path of care for individuals with CP and feeding difficulties; numbers in circles on the diagram represent Key Questions. The framework illustrates multiple indications of disrupted nutrition among this population, including signs of malnourishment or failure to thrive, episodes of aspiration or pneumonia, swallowing difficulties, or other clinical concerns for nutritional support. Individuals typically undergo a feeding and nutrition assessment, which could be followed by a behavioral (Key Question 1a) or nutritional (Key Question 2a) feeding intervention or a combination of such approaches, or the placement of a tube for feeding (Key Questions 3a–c). Individuals with reflux may undergo tube placement with fundoplication to help alleviate reflux (Key Question 3b). Individuals without pre-existing reflux who undergo a tube placement may develop reflux following the procedure44-46 and require additional treatment via a jejunostomy tube or fundoplication (Key Question 3c). Possible intermediate or surrogate outcomes resulting from these interventions can include a change in growth status, improved swallowing, or various adverse effects. At this point on the pathway, individuals with CP may undergo another feeding and nutrition assessment followed by an alternative intervention. Patient-centered and health outcomes following intermediate outcomes can include mortality, incidences of hospitalizations, antibiotic use, quality of life, patient and family satisfaction and stress, changes in time spent on feeding activities, physical and mental health of the primary caregiver, pain or comfort, and various adverse effects.

Figure 1 Analytic framework

Note: Numbers in circles represent Key Questions.

The analytic framework (Figure 1) outlines the path of care for individuals with CP and feeding difficulties; numbers in circles on the diagram represent key questions. The framework illustrates multiple indications of disrupted nutrition among this population, including signs of malnourishment or failure to thrive, episodes of aspiration or pneumonia, swallowing difficulties, or other clinical concerns for nutritional support. Individuals typically undergo a feeding and nutrition assessment, which could be followed by a behavioral (Key Question 1a) or nutritional (Key Question 2a) feeding intervention or a combination of such approaches, or the placement of a tube for feeding (Key Questions 3a–c). Individuals with reflux may undergo tube placement with fundoplication to help alleviate reflux (Key Question 3b). Individuals without pre-existing reflux who undergo a tube placement may develop reflux following the procedure and require additional treatment via a jejunostomy tube or fundoplication (Key Question 3c). Possible intermediate or surrogate outcomes resulting from these interventions can include a change in growth status, improved swallowing, or various adverse effects. At this point on the pathway, individuals with CP may undergo another feeding and nutrition assessment followed by an alternative intervention. Patient-centered and health outcomes following intermediate outcomes can include mortality, incidences of hospitalizations, antibiotic use, quality of life, patient and family satisfaction and stress, changes in time spent on feeding activities, physical and mental health of the primary caregiver, pain or comfort, and various adverse effects. Certain factors may influence the pathway at all stages and can include the type and severity of CP, age, race, intellectual and clinical comorbidities, severity of intellectual disability, and caregiver or family needs (Key Questions 1b, 2b, 3d specifically address potential modifiers of treatment effectiveness). Numbers in circles within the diagram indicate the placement of key questions in relation to the treatment process.

Certain factors may influence the pathway at all stages and can include the type and severity of CP, age, race, intellectual and clinical comorbidities, severity of intellectual disability, and caregiver or family needs (Key Questions 1b, 2b, 3d specifically address potential modifiers of treatment effectiveness). Numbers in circles within the diagram indicate the placement of Key Questions in relation to the treatment process.

## Literature Search Strategy

### Search Strategy

#### Databases

A librarian employed search strategies provided in Appendix A to retrieve research on feeding and nutrition interventions in CP. All strategies were peer reviewed by a second librarian. Our primary literature search employed six databases: MEDLINE® via the PubMed interface, PsycINFO (psychology and psychiatry literature), the Educational Resources Information Clearinghouse, OTSeeker, REHABDATA, and the Cumulative Index of Nursing and Allied Health Literature (CINAHL) database; see Appendix A for a description of database content. Our search strategies used a combination of subject heading terms appropriate for each database and key words relevant to CP and nutrition (e.g., cerebral palsy, enteral feeding). We also conducted a secondary search on the broader topic of neurologic impairment and surgical feeding interventions to capture research potentially including individuals with CP. We limited searches to literature published since 1980 to ensure that interventions used currently would be represented.

We also manually searched the reference lists of included studies and of recent narrative and systematic reviews and meta-analyses addressing CP and feeding and nutrition issues. We invited TEP members to provide additional citations.

#### Prior Systematic Reviews

We identified systematic reviews retrieved by the searches for primary literature as well as through a search of the Cochrane Database of Systematic Reviews using the search terms cerebral palsy, feeding, and nutrition. We also searched MEDLINE via PubMed using our MEDLINE strategy for primary research but limited to the review or meta-analysis publication types (Appendix A).

#### Grey Literature and Regulatory Information

To ensure that we captured relevant research that may not yet be published in biomedical journals, we located conference abstracts presented at annual meetings of the American Academy of Cerebral Palsy and Developmental Medicine and the American Academy of Physical Medicine and Rehabilitation (as available) from 2009 to 2012. We selected these associations in consultation with our clinical experts who felt that they would capture relevant presentations.

An expert librarian also searched for information on the VitalStim device as it is approved by the U.S. Food and Drug Administration to promote swallowing in individuals with swallowing difficulties in resources including the websites of the Food and Drug Administration and Health Canada. We also gave manufacturers of the device an opportunity to provide additional information, with a comment period of June 6 to July 19, 2012.

#### Search Terms

Controlled vocabulary terms served as the foundation of our search in each database (e.g., MEDLINE vocabulary terms including cerebral palsy, gastrostomy), complemented by additional keyword phrases (e.g., CP, tube feeding). We also limited searches to items published in English and from 1980 to the present. Our TEP felt that most CP research of relevance to the review topic is published in English.

Our searches were done between March and July 2012. Appendix A provides search terms and the yield from each database. We imported all citations into an electronic database.

### Inclusion and Exclusion Criteria

We developed criteria for inclusion and exclusion in consultation with the TEP (Table 2). Studies needed to include individuals of any age with CP and feeding difficulties and had to include at least two individuals (i.e., single case reports were excluded; multiple baseline studies with only one participant—regardless of the number of data points—were excluded). For studies with populations including individuals with CP and other conditions, we retained the study if we could infer that at least 80 percent of the study participants had CP or if we could isolate data on those participants with CP. Comparators included other nonsurgical approaches for the behavioral interventions (Key Questions 1–3a), oral feeding, intervention or pre-intervention data (Key Question 3b) or jejunostomy tube, fundoplication or pre-intervention data (Key Question 3c). Behavioral studies had to include an active comparator; surgical studies could be pre-post design (case series) in which individuals served as their own comparators.

Table 2 Inclusion and exclusion criteria

Category | Criteria
Study population | Individuals with CP and feeding or nutrition difficulties, at least 80% of population with CP in studies that include mixed populations
Time period | 1980–present
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs]; - Controlled trials, observational studies including prospective and retrospective cohort studies, prospective and retrospective case series providing data from before and after intervention, and systematic reviews; [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Patient populations must include individuals with CP (at least 80% for studies with mixed populations not reporting data separately for individuals with CP) and feeding or nutrition difficulties; - Studies must address one or more of the following:; ○ Nonsurgical interventions; ○ Behavioral interventions (including positioning, oral appliances, oral stimulation, sensorimotor facilitation, and caregiver training); ○ Nutritional interventions (food thickeners, caloric supplementation with formulas, supplementation with vitamins and minerals, and altering food consistency); ○ Tube feeding; ○ Oral feeding; ○ Surgical interventions (G-tube, J-tube, fundoplication); ○ Modifiers of nonsurgical intervention effectiveness (age, race, severity, functional status); ○ Modifiers of tube feeding effectiveness (tube placement, age, race, severity, functional status, initial nutritional status, or continuous vs. bolus feeding); ○ Baseline and outcome data (including harms) related to interventions for feeding difficulties; - Studies must include extractable data on relevant outcomes, including data presented in text or tables (vs. solely in figures); - Studies must provide aggregate data vs. data for each individual participant

CP = cerebral palsy; G-tube = gastrostomy tube; J-tube = jejunostomy tube

We assessed both intermediate/surrogate and patient-centered/health outcomes. We considered intermediate outcomes as those that occur directly as a result of the intervention and that may also have longer term implications for the ultimate, functional outcomes that are the long-term goal of therapies. Outcomes assessed include:

- Intermediate or surrogate outcomes
  ○ Growth status as proxies for nutrition (height including leg length or tibia length, weight, skin fold status, energy expenditure)
  ○ Nutritional status (measures of energy balance, micronutrient scores)
  ○ Improved swallowing (including feeding efficiency score)
  ○ Need for surgical or nutritional intervention
- Patient-centered and health outcomes
  ○ Mortality
  ○ Hospitalizations
  ○ Days of antibiotics for aspiration needed
  ○ Validated measures of quality of life
  ○ Patient and family satisfaction and stress
  ○ Decreased parent/caregiver time spent on feeding-related activities
  ○ Physical and mental health of primary caregiver
  ○ Reflux outcomes (episodes of reflux, duration).

We also assessed the harms of interventions, defined by the AHRQ Effective Health Care program as the totality of adverse consequences of an intervention.47 Harms may include:

- Adverse effects related to surgical procedures (e.g., feeding tube migration or dislodgement, interference with pulmonary toilet)
- Need for further surgery
- Gastrointestinal bleeding or ulceration
- Peritonitis
- Episodes of aspiration or acute respiratory problems
- Pain/comfort
- Other gastrointestinal symptoms (e.g., constipation, retching, dumping, gas-bloat syndrome, secondary GER)
- Reduction in and negative influences on quality of life.

We included studies with any length of followup and in any setting (clinic, home, etc.).

#### Language

We focused the review on studies published in English. In the opinion of our content experts, most research on feeding and nutrition interventions in CP is published in English regardless of the native language of the investigators or country of publication. We reviewed the English abstracts of the non-English literature retrieved by our MEDLINE search to assess whether we had missed any relevant studies and verified that we had not.

### Study Selection

#### Screening of Studies

Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it for full text assessment.

Two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. One reviewer also separately assessed the abstracts of review articles identified by our database searches for relevance to the comparative effectiveness review topic (See form in Appendix B). The group of abstract and full text reviewers included expert clinicians and health services researchers.

### Data Extraction and Data Management

The staff members and clinical experts who conducted this review jointly developed the evidence table, which was used to summarize data from the studies. We modeled the table on that used in a recent systematic review of feeding interventions for CP34 and designed the table to include issues of study design, descriptions of the study populations (for applicability), description of the intervention, and baseline and outcome data on constructs of interest.

One team member initially entered information into the evidence table. Another member of the team also independently reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The full research team met during the article extraction period and discussed issues related to data extraction (e.g., optimal level of detail in the description of the intervention, determining key population characteristic such as GMFCS level to include). In addition to outcomes related to intervention effectiveness, we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

The final evidence table is presented in Appendix C. Studies are presented in the evidence table alphabetically by the last name of the first author within each year. When possible to identify, analyses resulting from the same study were grouped into a single evidence table.

## Quality (Risk of Bias) Assessment of Individual Studies

We assessed quality using separate tools as appropriate by study design. The detailed tools used to assess quality are in Appendix D and include the Cochrane Risk of Bias tool for randomized controlled trials (RCTs),48 the Newcastle-Ottawa scale for cohort studies,49 a tool adapted from AHRQ's Effective Health Care program guidance for case series,50 and the AMSTAR tool for systematic reviews.51 The reliability and other characteristics of the Cochrane Risk of Bias tool, Newcastle scale, and AMSTAR have been previously assessed with positive ratings overall.52-57

Two reviewers independently assessed quality for each study, with final decisions made via discussion to reach consensus or by third party adjudication by a senior methodologist as needed. We describe the individual quality components below and report individual quality assessments for each study in Appendix E.

### Determining Quality Levels

We used targeted sets of questions to assess randomized trials, case series, and cohort studies and systematic reviews. Appendix D includes the individual questions used to assess each study type, and Appendix E lists scores for each question for each study. Three quality levels were possible: good, fair, and poor (Table 3).

- We required that RCTs receive a positive score (i.e., low risk of bias for RCTs) on all of the questions used to assess quality to receive a rating of good. RCTs had to receive at least five positive scores to receive a rating of fair, and studies with ≤ four positive ratings were considered poor quality. We considered a rating of “unclear” as a positive rating as long as the consensus of the investigators assessing quality was that study outcomes were not likely to be biased by the factor.
- We required that cohort studies receive positive scores (stars) on all elements to receive a rating of good, ≤ 2 negative ratings for fair, and > 2 negative scores for a rating of poor quality.
- Case series, or pre-post studies, have inherently high risk of bias. Nonetheless, prospective case series that enroll participants consecutively and control for potentially confounding factors may provide more evidence to support comparative studies. We assessed case series using questions identified in the AHRQ Effective Health Care program's “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”47 but did not assign a quality level for these studies as it would be inappropriate to assess them on the same scale as prospective cohort and RCT designs. Rather, the elements on which they were scored and the results are presented in Appendix E.
- We used the approach recommended in the AHRQ guidance on use of prior reviews in systematic reviews to assess systematic reviews identified through the literature search, with the expectation that we would only consider updating a review that was of good quality.58 Other reviews might be used to provide context or as a source of references but not to provide data for our review. We required that systematic reviews receive no more than two negative scores and receive positive scores on questions related to quality assessment, search of the literature, and appropriate synthesis to receive a rating of good. Reviews had to receive three or fewer negative scores and a positive score on quality assessment for a rating of fair; reviews with four or more negative scores were considered poor quality. We conducted an audit of papers included in good quality reviews to assess the quality of individual studies and determine that our assessments would match those of the review author before accepting their data and summarizing the review.

Table 3 Description of study quality levels for individual studies

Quality Level | Description
Good | Good studies are considered to have the least bias and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to treatments; has a low dropout rate; and uses appropriate means to prevent bias; measure outcomes; analyze and report results.
Fair | Fair studies are susceptible to some bias, but probably not sufficient to invalidate the results. A study may be missing information, making it difficult to assess limitations and potential problems. As the “fair quality” category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | Poor studies are subject to significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

## Data Synthesis

When we identified published, high-quality systematic review addressing a Key Question that was largely up to date and relevant, we intended to cite and summarize these reviews as evidence and not extract data from the primary studies. Of note, only one review met these criteria. We provide a summary of the methods of this review and overall findings in line with guidance in the Using Existing Systematic Reviews to Replace de novo Processes in Conducting Comparative Effectiveness Reviews chapter of the AHRQ Effective Health Care Program Methods Guide.58

For interventions not covered in existing systematic reviews or to update existing reviews, we extracted and synthesized data from primary studies meeting our criteria. We considered the possibility of conducting a meta-analysis, but the small number of the studies, the study designs and the heterogeneity in outcomes made a meta-analysis both inappropriate and unnecessary.

## Strength of the Body of Evidence for Each Key Question

The assessment of the literature is done by considering both the observed effectiveness of interventions and the confidence that we have in the stability of those effects in the face of future research. The degree of confidence that the observed effect of an intervention is unlikely to change is presented as strength of evidence, and it can be regarded as insufficient, low, moderate, or high. Strength of evidence describes the adequacy of the current research, both in terms of quantity and quality, as well as the degree to which the entire body of current research provides a consistent and precise estimate of effect. Interventions that have demonstrated benefit in a small number of studies but have not yet been replicated using the most rigorous study designs will therefore have insufficient or low strength of evidence to describe the body of research. Future research may find that the intervention is either effective or ineffective.

Methods for applying strength of evidence assessments are established in the “Grading the Strength of a Body of Evidence When Comparing Medical Interventions” chapter of the Methods Guide59 and are based on consideration of four domains: risk of bias, consistency in direction of the effect, directness in measuring intended outcomes, and precision of effect (Table 4). Strength of evidence is assessed separately for major intervention-outcome pairs.

Table 4 Domains used to assess strength of evidence^a^

Domain | Explanation
Risk of bias | Degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements:; - Study design (e.g., RCTs or observational studies).; - Aggregate quality of the studies under consideration.; Information for this determination comes from the rating of quality (good/fair/poor) done for individual studies.
Consistency | Degree to which reported effect sizes from included studies appear to have the same direction of effect. This can be assessed through two main elements:; - Effect sizes have the same sign (that is, are on the same side of “no effect”).; - The range of effect sizes is narrow.
Directness | Relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important health or ultimate outcomes. Evidence is indirect if:; - It uses intermediate or surrogate outcomes instead of ultimate health outcomes. In this case, one body of evidence links the intervention to intermediate outcomes and another body of evidence links the intermediate to most important (health or ultimate) outcomes.; - It uses two or more bodies of evidence to compare interventions A and B, e.g., studies of A vs. placebo and B vs. placebo, or studies of A vs. C and B vs. C but not A vs. B.; Indirectness always implies that more than one body of evidence is required to link interventions to the most important health outcomes. Directness may be contingent on the outcomes of interest.
Precision | Precision is the degree of certainty surrounding an effect estimate with respect to a given outcome (i.e., for each outcome separately). If a meta-analysis was performed, this will be the confidence interval around the summary effect size.

RCTs = randomized controlled trials

a Excerpted from Owens et al., 2010^59^

Once we had established the maximum strength of evidence possible based upon these criteria, we assessed the number of studies and range of study designs for a given intervention-outcome pair, and downgraded the rating when the cumulative evidence was not sufficient to justify the higher rating. The possible grades were—

- High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates.
- Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate.
- Insufficient: Evidence is either unavailable or does not permit a conclusion.

### Prior Systematic Reviews

One prior systematic review met all of our criteria and was used in its entirety in our review.34 That review had used a modified Sackett approach to strength of evidence (Table 5).

Table 5 Levels of evidence (adapted from Sackett) used in Snider review34

Level | Description
1a (strong) | Well-designed meta-analysis, or 2 or more “high-quality” RCT's (PEDro score ≥ 6) showing similar findings.
1b (moderate) | 1 RCT of “high-quality” (PEDro score ≥ 6).
2a (limited) | At least 1 “fair-quality” RCT (PEDro score = 4–5).
2b (limited) | At least 1 “poor-quality” RCT (PEDro score < 4) or well-designed nonexperimental study (nonrandomized controlled trial, quasi-experimental studies, cohort studies with multiple baselines, single subject series with multiple baselines, etc.).
3 (consensus) | Agreement by an expert panel or a group of professionals in the field or a number of pre–post studies, all with similar results.
4 (conflict) | Conflicting evidence of 2 or more equally well-designed studies.
5 (no evidence) | No well-designed studies—only case studies/case descriptions, or cohort studies/single-subject series with no multiple baselines.

PEDro = Physiotherapy Evidence Database; RCT = randomized controlled trial

We translated this approach (as described in the Discussion) into equivalent strength of evidence grades.

## Applicability

Finally, it is important to consider the ability of the outcomes observed to apply both to other populations and to other settings (especially for those interventions that take place within a clinical/treatment setting but are hoped to change behavior overall). Our assessment of applicability included determining the population, intervention, comparator, outcomes and setting in each study and developing an overview of these elements for each intervention category.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in the area and individuals representing stakeholder communities were invited to provide external peer review of this report; AHRQ personnel and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment (August 7 to September 3, 2012). We addressed all reviewer comments, revising the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final evidence report on the AHRQ Web site.