# Peer Reviewers

- Kristie Bell, B. App.Sc, B. Hlth.Sc, Ph.D.
  University of Queensland
  Queensland, Australia
- Susan H. Lin, Sc.D., OTR/L
  American Occupational Therapy Association
  Bethesda, MD
- Lemmietta McNeilly, Ph.D., CCC-SLP
  American Speech-Language-Hearing Association
  Rockville, MD
- Robert Palisano, P.T., ScD, FAPTA
  Drexel University
  Philadelphia, PA
- Gina Rempel, M.D., FRCPC, FAAP
  University of Manitoba
  Winnipeg, Manitoba, Canada
- Laurie Snider, Ph.D.
  McGill University
  Montreal, Quebec, Canada
- Peter Sullivan, M.A., M.D., FRCP, FRCPCH, FHEA
  University of Oxford,
  Oxford, United Kingdom
- Wendy Wittenbrook, M.A., R.D., CSP, LD
  Texas Scottish Rite Hospital for Children
  Dallas, TX