# Key Informants

- Susan H. Lin, Sc.D., OTR/L
  American Occupational Therapy Association
  Bethesda, MD
- David Michelson, M.D.
  Loma Linda University
  Loma Linda, CA
- Gina Rempel, M.D., FRCPC, FAAP
  University of Manitoba
  Winnipeg, Manitoba, Canada
- Lisa Samson-Fang, M.D.
  University of Utah
  Salt Lake City, UT
- Laurie Snider, Ph.D.
  McGill University
  Montreal, Quebec, Canada
- Peter Sullivan, M.A., M.D., FRCP, FRCPCH, FHEA
  University of Oxford,
  Oxford, United Kingdom
- Gordon Worley, M.D.
  Duke University
  Durham, NC