# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

Mr. Jeffrey Seroogy and Ms. Katie Worley assisted with managing the review, including handling day-to-day logistics and participating in screening studies.

Dr. Christopher Fonnesbeck provided a statistical review of studies included in the review to determine the potential for meta-analyses.

Dr. Steven R. Couch provided valuable insight into the care of and clinical decision making for individuals with cerebral palsy.

Ms. Rachel Walden and Mr. Zachary Fox, library scientists for the review, created comprehensive searches, and assisted with screening of abstracts and full text studies. We appreciate their thoughtful input across the project's stages.

Ms. Sharana Jones and Mr. Ross Brown provided helpful assistance in locating articles and preparing materials for meetings.

Ms. Shannon Potter assisted with formatting and preparation of the draft report.