# Excluded Studies

Reasons for exclusion

- X-1 Not original research
- X-2 Not published in English
- X-3 Population does not include at least 80% individuals with CP
- X-4 Does not address interventions of interest
- X-5 Does not include effectiveness data
- X-9 Study not obtainable
- X-10 Systematic review not relevant to current CER or not of good quality
- X-11 Conference abstract or other ineligible publication

1 Hamby WB, Schiffer S. Spasmodic torticollis; results after cervical rhizotomy in 80 cases. Clin Neurosurg. 1970;17:28-37. X-3. [pmid: 4941664].
2 Bird JW. Skeletal muscle lysosomes. Front biol. 1975;43(4):75-109. X-1. [pmid: 780148].
3 Rosenthal HM, Cooper JN. Chest pain: coronary or esophageal?. Angiology. Dec. 1977;28(12):832-8. X-1. [pmid: 23713].
4 Walters FJ, Nott MR. The hazards of anaesthesia in the injured patient. Br J Anaesth. Jul. 1977;49(7):707-20. X-1. [pmid: 328031].
5 Cohen S. Motor disorders of the esophagus. N Engl J Med. Jul. 26. 1979;301(4):184-92. X-1. [pmid: 109758].
6 Kosloske AM. Necrotizing enterocolitis in the neonate. Surg Gynecol Obstet. Feb. 1979;148(2):259-69. X-1. [pmid: 369004].
7 Davis R, Barolat-Romana G, Engle H. Chronic cerebellar stimulation for cerebral palsy—five-year study. Acta Neurochir Suppl (Wien). 1980;30:317-32. X-4. [pmid: 6970507].
8 Ellis FH Jr. Surgical management of esophageal motility disturbances. Am J Surg. Jun. 1980;139(6):752-9. X-1, X-3, X-4, X-5. [pmid: 6770700].
9 Love RJ, Hagerman EL, Taimi EG. Speech performance, dysphagia and oral reflexes in cerebral palsy. J Speech Hear Disord. Feb. 1980;45(1):59-75. X-3, X-4, X-5. [pmid: 7354631].
10 Pomerantz MA, Salomon J, Dunn R. Permanent gastrostomy as a solution to some nutritional problems in the elderly. J Am Geriatr Soc. Mar. 1980;28(3):104-7. X-3, X-4, X-5. [pmid: 6766486].
11 Van De Heyning PH, Marquet JF, Creten WL. Drooling in children with cerebral palsy. Acta Otorhinolaryngol Belg. 1980;34(6):691-705. X-3, X-4, X-5. [pmid: 7223419].
12 Helping mentally handicapped children to eat. World Ir Nurs. Oct-Nov. 1981;10(10-11):1-2. 11. X-1, X-3, X-4, X-5. [pmid: 6460389].
13 Bachrach W, Boyce HW Jr., Jackson D. Grand rounds in critical care: problems in swallowing and esophageal carcinoma. Heart Lung. May-Jun. 1981;10(3):525-31. X-1, X-2, X-3, X-4, X-5. [pmid: 6908893].
14 Greene HL, Helinek GL, Folk CC, et al. Nasogastric tube feeding at home: a method for adjunctive nutritional support of malnourished patients. Am J Clin Nutr. Jun. 1981;34(6):1131-8. X-3, X-4, X-5. [pmid: 6786077].
15 Hellemans J, Pelemans W, Vantrappen G. Pharyngoesophageal swallowing disorders and the pharyngoesophageal sphincter. Med Clin North Am. Nov. 1981;65(6):1149-71. X-1. [pmid: 6276629].
16 Korabek CA, Reid DH, Ivancic MT. Improving needed food intake of profoundly handicapped children through effective supervision of institutional staff. Appl Res Ment Retard. 1981;2(1):69-88. X-3. [pmid: 7305330].
17 Matino JJ. Feeding jejunostomy in patients with neurologic disorders. Arch Surg. Feb. 1981;116(2):169-71. X-3, X-5. [pmid: 6810842].
18 Nelson EC, Pendleton TB, Edel J. Lip halter: an aid in drool control. Phys Ther. Mar. 1981;61(3):361-2. X-1, X-3, X-4, X-5. [pmid: 7465633].
19 Ottenbacher K, Scoggins A, Wayland J. The effectiveness of oral sensory motor therapy with severely and profoundly developmentally disabled. Occup Ther J Res. 1981;1:147-60. X-4.
20 Wilkinson JD, Dudgeon DL, Sondheimer JM. A comparison of medical and surgical treatment of gastroesophageal reflux in severely retarded children. J Pediatr. 1981;99:202-5. X-3, X-5. [pmid: 7252675].
21 Byrne WJ, Euler AR, Ashcraft E, et al. Gastroesophageal reflux in the severely retarded who vomit: criteria for and results of surgical intervention in twenty-two patients. Surgery. Jan. 1982;91(1):95-8. X-3, X-5. [pmid: 7054912].
22 Jerome C, Smith GP. Gastric vagotomy inhibits drinking after hypertonic saline. Physiol Behav. Feb. 1982;28(2):371-4. X-3, X-4. [pmid: 7079351].
23 Olsen AM. Chevalier Jackson lecture. Esophagology: an update. Ann Otol Rhinol Laryngol. Nov-Dec. 1982;91(6 Pt 1):551-7. X-1. [pmid: 6816124].
24 Raventos JM, Kralemann H, Gray DB. Mortality risks of mentally retarded and mentally ill patients after a feeding gastrostomy. Am J Ment Defic. Mar. 1982;86(5):439-44. X-3, X-5. [pmid: 7124798].
25 Ross LM, editor. Problem solving with rehabilitation engineering. Rehabilitation engineering center tech brief: winter 1982. 1982. X-9.
26 Shaw G, Wright C. A two-handle spoon: an aid for independent eating. Am J Occup Ther. Jan. 1982;36(1):45-6. X-4, X-5. [pmid: 7058867].
27 de Bruijn KM, Blendis LM, Zilm DH, et al. Effect of dietary protein manipulation in subclinical portal-systemic encephalopathy. Gut. Jan. 1983;24(1):53-60. X-3, X-4. [pmid: 6336714].
28 Ferry GD, Selby M, Pietro TJ. Clinical response to short-term nasogastric feeding in infants with gastroesophageal reflux and growth failure. J Pediatr Gastroenterol Nutr. 1983;2(1):57-61. X-3. [pmid: 6411890].
29 Friesen DL, Henderson RD, Hanna W. Ultrastructure of the esophageal muscle in achalasia and diffuse esophageal spasm. Am J Clin Pathol. Mar. 1983;79(3):319-25. X-3, X-4. [pmid: 6829502].
30 Harnsberger JK, Corey JJ, Johnson DG, et al. Long-term follow-up of surgery for gastroesophageal reflux in infants and children. J Pediatr. Apr. 1983;102(4):505-8. X-3, X-4, X-5. [pmid: 6834183].
31 O'Brien M, Tsurumi K. The effect of two body positions on head righting in severely disabled individuals with cerebral palsy. Am J Occup Ther. Oct. 1983;37(10):673-80. X-4. [pmid: 6638143].
32 Ottenbacher K, Hicks J, Roark A, et al. Oral sensorimotor therapy in the developmentally disabled: a multiple baseline study. Am J Occup Ther. Aug. 1983;37(8):541-7. X-3, X-4, X-5. [pmid: 6624851].
33 Ray SA, Bundy AC, Nelson DL. Decreasing drooling through techniques to facilitate mouth closure. Am J Occup Ther. Nov. 1983;37(11):749-53. X-1, X-3, X-4. [pmid: 6650647].
34 Rombeau JL, Twomey PL, McLean GK, et al. Experience with a new gastrostomy-jejunal feeding tube. Surgery. Apr. 1983;93(4):574-8. X-3, X-4, X-5. [pmid: 6403996].
35 Trefler E, Nickey J, Hobson DA. Technology in the education of multiply-handicapped children. Am J Occup Ther. Jun. 1983;37(6):381-7. X-4. [pmid: 6224424].
36 Whishaw IQ, Kolb B. “Stick out your tongue”: tongue protrusion in neocortex and hypothalamic damaged rats. Physiol Behav. Mar. 1983;30(3):471-80. X-3, X-4. [pmid: 6867143].
37 Wiberg J, Nornes H. Effects of carotid endarterectomy on blood flow in the internal carotid artery. Acta Neurochir (Wien). 1983;68(3-4):217-26. X-3, X-4. [pmid: 6880878].
38 Christensen E, Schlichting P, Fauerholdt L, et al. Prognostic value of child-turcotte criteria in medically treated cirrhosis. Hepatology. May-Jun. 1984;4(3):430-5. X-3, X-4. [pmid: 6724511].
39 Hill LD, Asplund CM, Roberts PN. Intraoperative manometry: adjunct to surgery for esophageal motility disorders. Am J Surg. Jan. 1984;147(1):171-4. X-3, X-4, X-5. [pmid: 6691543].
40 Krick J, Van Duyn MA. The relationship between oral-motor involvement and growth: a pilot study in a pediatric population with cerebral palsy. J Am Diet Assoc. May. 1984;84(5):555-9. X-4. [pmid: 6715752].
41 Luessenhop AJ, Rosa L. Cerebral arteriovenous malformations. Indications for and results of surgery, and the role of intravascular techniques. J Neurosurg. Jan. 1984;60(1):14-22. X-1, X-3, X-4. [pmid: 6689706].
42 McGovern B. Janeway gastrostomy in children with cerebral palsy. J Pediatr Surg. Dec. 1984;19(6):800-2. X-4, X-5. [pmid: 6440972].
43 Molteno CD, Cumpsty P. Tactile aversion in infancy. S Afr Med J. May. 12. 1984;65(19):773-4. X-3, X-4. [pmid: 6202015].
44 Rivkin L, Bremner CG, Bremner CH. Pathophysiology of mid-oesophageal and epiphrenic diverticula of the oesophagus. S Afr Med J. Jul. 28. 1984;66(4):127-9. X-3, X-4. [pmid: 6429868].
45 Crysdale WS, Greenberg J, Koheil R, et al. The drooling patient: team evaluation and management. Int J Pediatr Otorhinolaryngol. Aug. 1985;9(3):241-8. X-4. [pmid: 3902695].
46 Hrabovsky EE, Mullett MD. Patterns of pediatric gastroesophageal reflux. Am Surg. Apr. 1985;51(4):212-6. X-3, X-4, X-5. [pmid: 3985487].
47 Jolley SG, Smith EI, Tunell WP. Protective antireflux operation with feeding gastrostomy. Experience with children. Ann Surg. Jun. 1985;201(6):736-40. X-3. [pmid: 4004385].
48 Mollitt DL, Golladay ES, Seibert JJ. Symptomatic gastroesophageal reflux following gastrostomy in neurologically impaired patients. Pediatrics. Jun. 1985;75(6):1124-6. X-3. [pmid: 4000789].
49 O'Neill J, Brown M, Schonhorn R. The impact of deinstitutionalization on activities and skills of severely/profoundly retarded multiply handicapped adults. Appl Res Ment Retard. 1985;6(3):361-71. X-3, X-4, X-5. [pmid: 4037793].
50 Smith HJ. Gastrointestinal hemorrhage in paralyzed and neurologically impaired patients: contribution of reflux esophageal disease. Gastrointest Radiol. 1985;10(1):7-10. X-3, X-4, X-5. [pmid: 3871714].
51 Traube M, McCallum RW. Primary oesophageal motility disorders. Current therapeutic concepts. Drugs. Jul. 1985;30(1):66-77. X-1. [pmid: 2863126].
52 Turner WW Jr. Nutritional considerations in the patient with disabling brain disease. Neurosurgery. May. 1985;16(5):707-13. X-1, X-3, X-4. [pmid: 3923386].
53 Vane DW, Harmel RP Jr., King DR, et al. The effectiveness of Nissen fundoplication in neurologically impaired children with gastroesophageal reflux. Surgery. Oct. 1985;98(4):662-7. X-3, X-4, X-5. [pmid: 2931842].
54 Bouvia v. Glenchur. Issues Law Med. May. 1986;1(6):493-8. X-1, X-3, X-4, X-5. [pmid: 11644051].
55 Bouvia v. County of Riverside. Issues Law Med. May. 1986;1(6):485-91. X-1, X-3, X-4, X-5. [pmid: 11644050].
56 Bouvia v. Superior Court (Glenchur). Wests Calif Report. Apr. 16. 1986;225:297-308. X-1, X-3, X-4, X-5. [pmid: 11648237].
57 Annas GJ. Elizabeth Bouvia: whose space is this anyway?. Hastings Cent Rep. Apr. 1986;16(2):24-5. X-1, X-3, X-4, X-5. [pmid: 3084400].
58 Bayley C. The case of Elizabeth Bouvia: a strain on our ethical reasoning. Health Prog. Jul-Aug. 1986;67(6):40-7. 86. X-1, X-4. [pmid: 10311605].
59 Colbert AP, Doyle KM, Webb WE. DESEMO seats for young children with cerebral palsy. Arch Phys Med Rehabil. Jul. 1986;67(7):484-6. X-3, X-4, X-5. [pmid: 3729697].
60 Cunningham BA, Morris G, Cheney CL, et al. Effects of resistive exercise on skeletal muscle in marrow transplant recipients receiving total parenteral nutrition. JPEN J Parenter Enteral Nutr. Nov-Dec. 1986;10(6):558-63. X-3, X-4. [pmid: 3098997].
61 Hou SM, Seaber AV, Urbaniak JR. Blood-induced arterial segmental spasm. J Reconstr Microsurg. Oct. 1986;3(1):29-32. X-3, X-4. [pmid: 3795193].
62 Kocan MJ, Hickisch SM. A comparison of continuous and intermittent enteral nutrition in NICU patients. J Neurosci Nurs. Dec. 1986;18(6):333-7. X-3, X-4, X-5. [pmid: 2949027].
63 Limbrock J, Wirth C. Mundtherapie für behinderte kinder: vorstellung der konzepte nach Bobath und Castillo-Morales. Orofacial therapy for handicapped children: presentation of the concepts of Bobath and Castillo-Morales. Frühförderung interdisziplinär. 1986;5(4):168-82. X-9.
64 Mills KR, Ward K, Martin F, et al. Peripheral neuropathy and myopathy in chronic alcoholism. Alcohol Alcohol. 1986;21(4):357-62. X-3, X-4. [pmid: 3028439].
65 Mulcahy M. IASSMD: looking back to new delhi. Australia & New Zealand J Dev Disabil. Mar. 1986;12(1):9-12. X-11.
66 Patrick J, Boland M, Stoski D, et al. Rapid correction of wasting in children with cerebral palsy. Dev Med Child Neurol. Dec. 1986;28(6):734-9. X-4. [pmid: 3102303].
67 Petersen P, Ottenbacker K. Use of applied behavioral techniques and an adaptive device to teach lip closure to severly handicapped children. Am J ment Defic. 1986;90(5):535-9. X-4. [pmid: 3953686].
68 Shoemaker M, Lampe RM, Weir MR. Peritonsillitis: abscess or cellulitis?. Pediatr Infect Dis. Jul-Aug. 1986;5(4):435-9. X-3, X-4. [pmid: 3460043].
69 Abarbanel JM, Berginer VM, Osimani A, et al. Neurologic complications after gastric restriction surgery for morbid obesity. Neurology. Feb. 1987;37(2):196-200. X-3, X-4. [pmid: 3027610].
70 Bowes WA J. The disabled newborn - diagnosis, prognosis, and outcome: the fetal view. Issues Law Med. 1987;2(6):435-61. X-1, X-3, X-4, X-5. [pmid: 2957339].
71 Campbell-Taylor I, Fisher RH. The clinical case against tube feeding in palliative care of the elderly. J Am Geriatr Soc. Dec. 1987;35(12):1100-4. X-3. [pmid: 2445806].
72 Chang JH, Coln CD, Strickland AD, et al. Surgical management of gastroesophageal reflux in severely mentally retarded children. J Ment Defic Res. Mar. 1987;31(Pt 1):1-7. X-3. [pmid: 3585986].
73 Cohen SR, Thompson JW. Variants of mobius' syndrome and central neurologic impairment. Lindeman procedure in children. Ann Otol Rhinol Laryngol. Jan-Feb. 1987;96(1 Pt 1):93-100. X-3. [pmid: 3545021].
74 Dedinsky GK, Vane DW, Black T, et al. Complications and reoperation after Nissen fundoplication in childhood. Am J Surg. Feb. 1987;153(2):177-83. X-3, X-5. [pmid: 3812892].
75 Drvaric DM, Roberts JM, Burke SW, et al. Gastroesophageal evaluation in totally involved cerebral palsy patients. J Pediatr Orthop. Mar-Apr. 1987;7(2):187-90. X-4, X-5. [pmid: 3558803].
76 Henderson RD. Esophageal motor disorders. Surg Clin North Am. Jun. 1987;67(3):455-74. X-1, X-3, X-4, X-5. [pmid: 3109043].
77 Henderson RD, Ryder D, Marryatt G. Extended esophageal myotomy and short total fundoplication hernia repair in diffuse esophageal spasm: five-year review in 34 patients. Ann Thorac Surg. Jan. 1987;43(1):25-31. X-3, X-4, X-5. [pmid: 3541814].
78 Hulme JB, Shaver J, Acher S, et al. Effects of adaptive seating devices on the eating and drinking of children with multiple handicaps. Am J Occup Ther. Feb. 1987;41(2):81-9. X-3. [pmid: 3565530].
79 Koheil R, Sochaniwskyj AE, Bablich K, et al. Biofeedback techniques and behaviour modification in the conservative remediation of drooling by children with cerebral palsy. Dev Med Child Neurol. Feb. 1987;29(1):19-26. X-3, X-4, X-5. [pmid: 3556797].
80 McBride MC, Danner SC. Sucking disorders in neurologically impaired infants: assessment and facilitation of breastfeeding. Clin Perinatol. Mar. 1987;14(1):109-30. X-4. [pmid: 3549110].
81 Rothwell BR. Prevention and treatment of the orofacial complications of radiotherapy. J Am Dent Assoc. Mar. 1987;114(3):316-22. X-1, X-3, X-4. [pmid: 2951417].
82 Bowes WA Jr. The disabled newborn - diagnosis, prognosis, and outcome: the fetal view. Issues Law Med. 1987;2(6):435-61. X-1, X-3, X-4, X-5. [pmid: 2957339].
83 Berge TI. Visual analogue scale assessment of postoperative swelling. A study of clinical inflammatory variables subsequent to third-molar surgery. Acta Odontol Scand. Aug. 1988;46(4):233-40. X-3, X-4. [pmid: 3188849].
84 Campbell AL. Tube feeding: parental perspective. Exceptional Parent. 1988;18(3):36-40. X-1, X-4, X-5.
85 Duane P, Peters TJ. Nutritional status in alcoholics with and without chronic skeletal muscle myopathy. Alcohol Alcohol. 1988;23(4):271-7. X-3, X-4. [pmid: 3166626].
86 Endo S, Branson PJ, Alksne JF. Experimental model of symptomatic vasospasm in rabbits. Stroke. Nov. 1988;19(11):1420-5. X-3, X-4. [pmid: 3188126].
87 Fee MA, et al. Nutritional assessment of the young child with cerebral palsy. Infants and Young Children. 1988;1(1):33-40. X-1, X-3, X-4, X-5.
88 Fontaine S, Theron J, Melanson D, et al. Superselective cerebral arterial infusion of BCNU in high-grade glioma: the radiologist's point of view. Can Assoc Radiol J. Sep. 1988;39(3):178-81. X-3, X-4. [pmid: 2971050].
89 Gauderer MW, Stellato TA, Olsen MM, et al. Percutaneous endoscopic gastrostomy in 156 children: indications, technique and complications. Z Kinderchir. Sep. Suppl 1. 1988;43:38-40. X-3, X-5. [pmid: 3151960].
90 Gisel EG, Patrick J. Identification of children with cerebral palsy unable to maintain a normal nutritional state. Lancet. Feb. 6. 1988;1(8580):283-6. X-4, X-5. [pmid: 2893092].
91 Langer JC, Wesson DE, Ein SH, et al. Feeding gastrostomy in neurologically impaired children: is an antireflux procedure necessary?. J Pediatr Gastroenterol Nutr. Nov-Dec. 1988;7(6):837-41. X-3, X-4, X-5. [pmid: 3143818].
92 Llaneza PP, Menendez AM, Roberts R, et al. Percutaneous endoscopic gastrostomy: clinical experience and follow-up. South Med J. Mar. 1988;81(3):321-4. X-3, X-4, X-5. [pmid: 3126551].
93 Ross MN, Haase GM, Reiley TT. The importance of acid reflux patterns in neurologically damaged children detected by four-channel esophageal pH monitoring. J Pediatr Surg. 1988;23:573-6. X-3, X-4, X-5. [pmid: 3418477].
94 Tuggle DW, Tunell WP, Hoelzer DJ, et al. The efficacy of Thal fundoplication in the treatment of gastroesophageal reflux: the influence of central nervous system impairment. J Pediatr Surg. Jul. 1988;23(7):638-40. X-3, X-4, X-5. [pmid: 3204462].
95 Campbell JR, Gilchrist BF, Harrison MW. Pyloroplasty in association with Nissen fundoplication in children with neurologic disorders. J Pediatr Surg. Apr. 1989;24(4):375-7. X-3, X-4, X-5. [pmid: 2732880].
96 Edebol-Tysk K. Evaluation of care-load for individuals with spastic tetraplegia. Dev Med Child Neurol. Dec. 1989;31(6):737-45. X-3, X-4, X-5. [pmid: 2532160].
97 Einset K, Deitz J, Billingsley F, et al. The electric feeder: an efficacy study. OTJR. Jan-Feb. 1989;9(1):38-52. X-4.
98 Fonkalsrud EW, Foglia RP, Ament ME, et al. Operative treatment for the gastroesophageal reflux syndrome in children. J Pediatr Surg. Jun. 1989;24(6):525-9. X-3, X-4, X-5. [pmid: 2738816].
99 Foutch PG, Talbert GA, Gaines JA, et al. The gastrostomy button: a prospective assessment of safety, success, and spectrum of use. Gastrointest Endosc. Jan-Feb. 1989;35(1):41-4. X-3, X-4, X-5. [pmid: 2493407].
100 Grunow JE, al-Hafidh A, Tunell WP. Gastroesophageal reflux following percutaneous endoscopic gastrostomy in children. J Pediatr Surg. Jan. 1989;24(1):42-4. Discussion 4-5. X-3. [pmid: 2723992].
101 Hulme JB, Bain B, Hardin M, et al. The influence of adaptive seating devices on vocalization. J Commun Disord. Apr. 1989;22(2):137-45. X-4. [pmid: 2723144].
102 Jones TN, Moore FA, Moore EE, et al. Gastrointestinal symptoms attributed to jejunostomy feeding after major abdominal trauma—a critical analysis. Crit Care Med. Nov. 1989;17(11):1146-50. X-3, X-4. [pmid: 2507224].
103 Morris SE. Development of oral-motor skills in the neurologically impaired child receiving non-oral feedings. Dysphagia. 1989;3(3):135-54. X-1. [pmid: 2517923].
104 Noronha J, Bundy A, Groll J. The effect of positioning on the hand function of boys with cerebral palsy. Am J Occup Ther. Aug. 1989;43(8):507-12. X-3, X-4, X-5. [pmid: 2774051].
105 Ponsky JL, Gauderer MW. Percutaneous endoscopic gastrostomy: indications, limitations, techniques, and results. World J Surg. Mar-Apr. 1989;13(2):165-70. X-1. [pmid: 2499128].
106 Stringel G, Delgado M, Guertin L, et al. Gastrostomy and Nissen fundoplication in neurologically impaired children. J Pediatr Surg. Oct. 1989;24(10):1044-8. X-3, X-4, X-5. [pmid: 2809949].
107 Turnage RH, Oldham KT, Coran AG, et al. Late results of fundoplication for gastroesophageal reflux in infants and children. Surgery. Apr. 1989;105(4):457-64. X-3, X-5. [pmid: 2928949].
108 Growth and nutrition in children with cerebral palsy. Lancet. May. 26. 1990;335(8700):1253-4. X-1, X-4, X-5. [pmid: 1971327].
109 Ciocon JO. Indications for tube feedings in elderly patients. Dysphagia. 1990;5(1):1-5. X-1, X-3. [pmid: 2118023].
110 Clarkston WK, Smith OJ, Walden JM. Percutaneous endoscopic gastrostomy and early mortality. South Med J. Dec. 1990;83(12):1433-6. X-3. [pmid: 2123563].
111 Craft MJ, Lakin JA, Oppliger RA, et al. Siblings as change agents for promoting the functional status of children with cerebral palsy. Dev Med Child Neurol. Dec. 1990;32(12):1049-57. X-3, X-4. [pmid: 2286303].
112 Cullado MJ, Slezak FA, Porter JA. Repeat percutaneous endoscopic gastrostomy (PEG): an outpatient procedure. Surg Endosc. 1990;4(3):173-4. X-3. [pmid: 2267650].
113 Dawson RC 3rd, Tarr RW, Hecht ST, et al. Treatment of arteriovenous malformations of the brain with combined embolization and stereotactic radiosurgery: results after 1 and 2 years. AJNR Am J Neuroradiol. Sep-Oct. 1990;11(5):857-64. X-3, X-4. [pmid: 2120988].
114 Evans PM, Evans SJ, Alberman E. Cerebral palsy: why we must plan for survival. Arch Dis Child. Dec. 1990;65(12):1329-33. X-4, X-5. [pmid: 2148667].
115 Fung KP, Seagram G, Pasieka J, et al. Investigation and outcome of 121 infants and children requiring Nissen fundoplication for the management of gastroesophageal reflux. Clin Invest Med. Oct. 1990;13(5):237-46. X-3, X-5. [pmid: 2276217].
116 Giordano M, Ford LM, Brauckmann JL, et al. MK801 prevents quinolinic acid-induced behavioral deficits and neurotoxicity in the striatum. Brain Res Bull. Mar. 1990;24(3):313-9. X-3, X-4. [pmid: 2159831].
117 Harper ME, Patrick J, Kramer JK, et al. Erythrocyte membrane lipid alterations in undernourished cerebral palsied children during high intakes of a soy oil-based enteral formula. Lipids. Oct. 1990;25(10):639-45. X-4, X-5. [pmid: 2127821].
118 Iammatteo PA, Trombly C, Luecke L. The effect of mouth closure on drooling and speech. Am J Occup Ther. Aug. 1990;44(8):686-91. X-4. [pmid: 1698021].
119 Lazarus BA, Murphy JB, Culpepper L. Aspiration associated with long-term gastric versus jejunal feeding: a critical analysis of the literature. Arch Phys Med Rehabil. Jan. 1990;71(1):46-53. X-3, X-5. [pmid: 2136992].
120 Limbrock GJ, Hoyer H, Scheying H. Drooling, chewing and swallowing dysfunctions in children with cerebral palsy: treatment according to Castillo-Morales. ASDC J Dent Child. Nov-Dec. 1990;57(6):445-51. X-1, X-4, X-5. [pmid: 2147927].
121 Lu CC, Schulze-Delrieu K. Pyloric deformation from peptic disease. Radiographic evidence for incompetence rather than obstruction. Dig Dis Sci. Dec. 1990;35(12):1459-67. X-3, X-4. [pmid: 2253530].
122 Manninen PH, Lam AM, Nantau WE. Monitoring of somatosensory evoked potentials during temporary arterial occlusion in cerebral aneurysm surgery. J Neurosurg Anesthesiol. Jun. 1990;2(2):97-104. X-4. [pmid: 15815328].
123 McCarran MS, Andrasik F. Behavioral weight-loss for multiply-handicapped adults: assessing caretaker involvement and measures of behavior change. Addict Behav. 1990;15(1):13-20. X-3, X-4, X-5. [pmid: 2138405].
124 Miles M, Frizzell Y. Handling the cerebral palsied child: multi-level skills transfer in Pakistan. Physiotherapy. 1990;76(3):183-6. X-1, X-3, X-4, X-5.
125 Pearl RH, Robie DK, Ein SH, et al. Complications of gastroesophageal antireflux surgery in neurologically impaired versus neurologically normal children. J Pediatr Surg. Nov. 1990;25(11):1169-73. X-3, X-5. [pmid: 2273433].
126 Sanders KD, Cox K, Cannon R, et al. Growth response to enteral feeding by children with cerebral palsy. JPEN J Parenter Enteral Nutr. Jan-Feb. 1990;14(1):23-6. X-4. [pmid: 2109109].
127 Stringel G. Gastrostomy with antireflux properties. J Pediatr Surg. Oct. 1990;25(10):1019-21. X-3, X-4, X-5. [pmid: 2262850].
128 Waxman MJ, Durfee D, Moore M, et al. Nutritional aspects and swallowing function of patients with parkinson's disease. Nutr Clin Pract. Oct. 1990;5(5):196-9. X-3, X-4. [pmid: 2122203].
129 Chez RA. Discussion: methodologic issues in assessment of pregnancy outcomes. Methodological issues in controlled studies on effects of prenatal exposure to drug abuse. 1991:84-92. X-9.
130 Collins BC, Gast DL, Wolery M, et al. Using constant time delay to teach self-feeding to young students with severe/profound handicaps: evidence of limited effectiveness. J Dev Phys Disabil. 1991;3(2):157-79. X-4, X-5.
131 Collins BC, Gast DL, Wolery M, et al. Using constant time delay to teach self-feeding to young students with severe/profound handicaps: evidence of limited effectiveness. J Dev Phys Disabil. Jun. 1991;3(2):157-79. X-4.
132 de Zanche C, Cattapan S, Simionato P, et al. Diagnosi funzionale dei disturbi dell'apprendimento nel cerebropatico grave. / Functional diagnosis of learning disability in severe brain injury. Italian Journal of Intellective Impairment. May. 1991;4(1):111-6. X-11.
133 Fay DE, Poplausky M, Gruber M, et al. Long-term enteral feeding: a retrospective comparison of delivery via percutaneous endoscopic gastrostomy and nasoenteric tubes. Am J Gastroenterol. Nov. 1991;86(11):1604-9. X-3, X-4, X-5. [pmid: 1951237].
134 Flake AW, Shopene C, Ziegler MM. Anti-reflux gastrointestinal surgery in the neurologically handicapped child. Pediatr Surg Int. 1991;6:92-4. X-3.
135 Medina R, Wing SS, Haas A, et al. Activation of the ubiquitin-ATP-dependent proteolytic system in skeletal muscle during fasting and denervation atrophy. Biomed Biochim Acta. 1991;50(4-6):347-56. X-3, X-4. [pmid: 1724903].
136 Murakami K, Segami N, Fujimura K, et al. Correlation between pain and synovitis in patients with internal derangement of the temporomandibular joint. J Oral Maxillofac Surg. Nov. 1991;49(11):1159-61. discussion 62. X-3, X-4, X-5. [pmid: 1941329].
137 Myhr U, von Wendt L. Improvement of functional sitting position for children with cerebral palsy. Dev Med Child Neurol. Mar. 1991;33(3):246-56. X-3, X-4, X-5. [pmid: 1760002].
138 Nagata S, Fujii K, Nomura T, et al. Hemifacial spasm caused by CP angle AVM associated with ruptured aneurysm in the feeding artery—case report. Neurol Med Chir (Tokyo). Jul. 1991;31(7):406-9. X-3. [pmid: 1720219].
139 Pope JE, Curzon ME. The dental status of cerebral palsied children. Pediatr Dent. May-Jun. 1991;13(3):156-62. X-3, X-4, X-5. [pmid: 1831891].
140 Rice H, Seashore JH, Touloukian RJ. Evaluation of Nissen fundoplication in neurologically impaired children. J Pediatr Surg. Jun. 1991;26(6):697-701. X-3, X-5. [pmid: 1941460].
141 Robie DK, Pearl RH. Modified Nissen fundoplication: improved results in high-risk children. J Pediatr Surg. Nov. 1991;26(11):1268-72. X-3, X-4, X-5. [pmid: 1812253].
142 Rosenwasser RH, Jimenez DF, Wending WW, et al. Routine use of etomidate and temporary vessel occlusion during aneurysm surgery. Neurol Res. Dec. 1991;13(4):224-8. X-3, X-4. [pmid: 1687331].
143 Seekri IK, Rescorla FJ, Canal DF, et al. Lesser curvature gastrostomy reduces the incidence of postoperative gastroesophageal reflux. J Pediatr Surg. Aug. 1991;26(8):982-4. discussion 4-5. X-3, X-4. [pmid: 1919993].
144 Stolovitz P, Gisel EG. Circumoral movements in response to three different food textures in children 6 months to 2 years of age. Dysphagia. 1991;6(1):17-25. X-3, X-4. [pmid: 1884634].
145 Thommessen M, Kase BF, Riis G, et al. The impact of feeding problems on growth and energy intake in children with cerebral palsy. Eur J Clin Nutr. Oct. 1991;45(10):479-87. X-4. [pmid: 1782919].
146 Re J (A Minor) (Wardship: Medical Treatment). All Engl Law Rep. Jun. 10. [1992]. 1992;4:614-26. X-1, X-3, X-4, X-5. [pmid: 11648313].
147 Allen KB, Ricketts RR. Surgery for achalasia of the cardia in children: the Dor-Gavriliu procedure. J Pediatr Surg. Nov. 1992;27(11):1418-21. X-3, X-4. [pmid: 1479502].
148 Barabas G, Matthews W, Zumoff P. Care-load for children and young adults with severe cerebral palsy. Dev Med Child Neurol. Nov. 1992;34(11):979-84. X-4. [pmid: 1426688].
149 Cheu HW, Grosfeld JL, Heifetz SA, et al. Persistence of barrett's esophagus in children after antireflux surgery: influence on follow-up care. J Pediatr Surg. Feb. 1992;27(2):260-4. discussion 5-6. X-4, X-5. [pmid: 1564627].
150 Fonkalsrud EW, Ament ME, Vargas J. Gastric antroplasty for the treatment of delayed gastric emptying and gastroesophageal reflux in children. Am J Surg. Oct. 1992;164(4):327-31. X-3, X-4, X-5. [pmid: 1415938].
151 Fried MD, Khoshoo V, Secker DJ, et al. Decrease in gastric emptying time and episodes of regurgitation in children with spastic quadriplegia fed a whey-based formula. J Pediatr. Apr. 1992;120(4 Pt 1):569-72. X-3, X-5. [pmid: 1552396].
152 Gibson SE, Wenig BL, Watkins JL. Complications of percutaneous endoscopic gastrostomy in head and neck cancer patients. Ann Otol Rhinol Laryngol. Jan. 1992;101(1):46-50. X-3, X-4, X-5. [pmid: 1728885].
153 Glassman MS, Dozer AJ, Newman LJ. Gastroesophageal reflux in neurologically impaired children: perioperative evaluation and management. South Med J. Mar. 1992;85(3):289-92. X-1, X-3, X-4, X-5. [pmid: 1546353].
154 Grill HJ, Schwartz GJ, Travers JB. The contribution of gustatory nerve input to oral motor behavior and intake-based preference. I. Effects of chorda tympani or glossopharyngeal nerve section in the rat. Brain Res. Feb. 21. 1992;573(1):95-104. X-3, X-4. [pmid: 1576537].
155 Hall DM. Child health promotion, screening and surveillance. J Child Psychol Psychiatry. May. 1992;33(4):649-57. X-1. [pmid: 1601940].
156 Henderson CT, Trumbore LS, Mobarhan S, et al. Prolonged tube feeding in long-term care: nutritional status and clinical outcomes. J Am Coll Nutr. Jun. 1992;11(3):309-25. X-3, X-4, X-5. [pmid: 1619183].
157 Kadakia SC, Sullivan HO, Starnes E. Percutaneous endoscopic gastrostomy or jejunostomy and the incidence of aspiration in 79 patients. Am J Surg. Aug. 1992;164(2):114-8. X-3, X-5. [pmid: 1636889].
158 Kleinhaus S, Weinberg G, Gregor MB. Necrotizing enterocolitis in infancy. Surg Clin North Am. Feb. 1992;72(1):261-76. X-1. [pmid: 1731387].
159 Korpela R, Seppanen RL, Koivikko M. Technical aids for daily activities: a regional survey of 204 disabled children. Dev Med Child Neurol. Nov. 1992;34(11):985-98. X-4. [pmid: 1426689].
160 Krick J, Murphy PE, Markham JF, et al. A proposed formula for calculating energy needs of children with cerebral palsy. Dev Med Child Neurol. Jun. 1992;34(6):481-7. X-4. [pmid: 1612207].
161 Martinez DA, Ginn-Pease ME, Caniano DA. Sequelae of antireflux surgery in profoundly disabled children. J Pediatr Surg. Feb. 1992;27(2):267-71. discussion 71-3. X-3. [pmid: 1532982].
162 Martinez DA, Ginn-Pease ME, Caniano DA. Recognition of recurrent gastroesophageal reflux following antireflux surgery in the neurologically disabled child: high index of suspicion and definitive evaluation. J Pediatr Surg. Aug. 1992;27(8):983-8. discussion 8-90. X-3. [pmid: 1403562].
163 McGrath SJ, Splaingard ML, Alba HM, et al. Survival and functional outcome of children with severe cerebral palsy following gastrostomy. Arch Phys Med Rehabil. Feb. 1992;73(2):133-7. X-4, X-5. [pmid: 1543407].
164 McPherson KA, Kenny DJ, Koheil R, et al. Ventilation and swallowing interactions of normal children and children with cerebral palsy. Dev Med Child Neurol. Jul. 1992;34(7):577-88. X-3, X-4, X-5. [pmid: 1511793].
165 Park RH, Allison MC, Lang J, et al. Randomised comparison of percutaneous endoscopic gastrostomy and nasogastric tube feeding in patients with persisting neurological dysphagia. BMJ. May. 30. 1992;304(6839):1406-9. X-3. [pmid: 1628013].
166 Park RH, Galloway A, Russell RI, et al. Home sweet HEN—a guide to home enteral nutrition. Br J Clin Pract. Summer. 1992;46(2):105-10. X-1, X-3, X-4. [pmid: 1457296].
167 Persha AJ. Early identification and prevention of mental retardation. ICCW News Bull. Jan-Mar. 1992;40(1):9-12. X-1, X-3, X-4, X-5. [pmid: 12344890].
168 Pollack IF, Pang D, Kocoshis S, et al. Neurogenic dysphagia resulting from Chiari malformations. Neurosurgery. May. 1992;30(5):709-19. X-3, X-4, X-5. [pmid: 1584383].
169 Reilly S, Skuse D. Characteristics and management of feeding problems of young children with cerebral palsy. Dev Med Child Neurol. May. 1992;34(5):379-88. X-9. [pmid: 1592191].
170 Smith CD, Othersen HB Jr., Gogan NJ, et al. Nissen fundoplication in children with profound neurologic disability. High risks and unmet goals. Ann Surg. Jun. 1992;215(6):654-8. discussion 8-9. X-3, X-4, X-5. [pmid: 1632687].
171 Taylor CA, Larson DE, Ballard DJ, et al. Predictors of outcome after percutaneous endoscopic gastrostomy: a community-based study. Mayo Clin Proc. Nov. 1992;67(11):1042-9. X-3, X-5. [pmid: 1434864].
172 Tolia V, Lin CH, Kuhns LR. Gastric emptying using three different formulas in infants with gastroesophageal reflux. J Pediatr Gastroenterol Nutr. Oct. 1992;15(3):297-301. X-3. [pmid: 1432468].
173 Albanese CT, Towbin RB, Ulman I, et al. Percutaneous gastrojejunostomy versus Nissen fundoplication for enteral feeding of the neurologically impaired child with gastroesophageal reflux. J Pediatr. Sep. 1993;123(3):371-5. X-3, X-4, X-5. [pmid: 8355112].
174 Crawford MA. The role of essential fatty acids in neural development: implications for perinatal nutrition. Am J Clin Nutr. May. 1993;57(5 Suppl):703S-9S. discussion 9S-10S. X-3, X-4. [pmid: 7682751].
175 Crombleholme TM, Jacir NN. Simplified “push” technique for percutaneous endoscopic gastrostomy in children. J Pediatr Surg. Oct. 1993;28(10):1393-5. X-3. [pmid: 8263707].
176 DeCou JM, Shorter NA, Karl SR. Feeding Roux-en-Y jejunostomy in the management of severely neurologically impaired children. J Pediatr Surg. Oct. 1993;28(10):1276-9. discussion 9-80. X-3. [pmid: 8263686].
177 Dellert SF, Hyams JS, Treem WR, et al. Feeding resistance and gastroesophageal reflux in infancy. J Pediatr Gastroenterol Nutr. Jul. 1993;17(1):66-71. X-3, X-4, X-5. [pmid: 8350213].
178 Eyman RK, Olmstead CE, Grossman HJ, et al. Mortality and the acquisition of basic skills by children and adults with severe disabilities. Am J Dis Child. Feb. 1993;147(2):216-22. X-3, X-4, X-5. [pmid: 8427251].
179 Fitzgerald GK, Newsome D. Treatment of a large infected thoracic spine wound using high voltage pulsed monophasic current. Phys Ther. 1993;73(6):355-60. X-4. [pmid: 8497510].
180 Guo WY, Wikholm G, Karlsson B, et al. Combined embolization and gamma knife radiosurgery for cerebral arteriovenous malformations. Acta Radiol. Nov. 1993;34(6):600-6. X-3, X-4. [pmid: 8240896].
181 Hamosh A, Scharer G, Van Hove J. Glycine Encephalopathy. 1993. [pmid: 20301531]. X-1, X-3, X-4.
182 Jamieson JR. Pharyngoesophageal swallowing disorders. Curr Opin Gen Surg. 1993:189-94. X-1. [pmid: 7583964].
183 Jevsevar DS, Karlin LI. The relationship between preoperative nutritional status and complications after an operation for scoliosis in patients who have cerebral palsy. J Bone Joint Surg Am. Jun. 1993;75(6):880-4. X-4. [pmid: 8314827].
184 Kasper CE, McNulty AL, Otto AJ, et al. Alterations in skeletal muscle related to impaired physical mobility: an empirical model. Res Nurs Health. Aug. 1993;16(4):265-73. X-3, X-4. [pmid: 8378556].
185 Kratzer DA, Spooner F, Test DW, et al. Extending the application of constant time delay: teaching a requesting skill to students with severe multiple disabilities. Education & Treatment of Children. Aug. 1993;16(3):235-53. X-4.
186 Kruer M, Gregory A, Hayflick SJ. Fatty acid hydroxylase-associated neurodegeneration. 1993. [pmid: 21735565]. X-3, X-4.
187 Lewin JE, Mix CM, Gaebler-Spira D. Self-help and upper extremity changes in 36 children with cerebral palsy subsequent to selective posterior rhizotomy and intensive occupational and physical therapy. Phys Occup Ther Pediatr. 1993;13(3):25-42. X-4.
188 Merrill JR. PEG/PEJ and the incidence of aspiration. Am J Surg. Oct. 1993;166(4):441-2. X-1, X-3, X-4, X-5. [pmid: 8214312].
189 Namavar Y, Barth PG, Baas F. Pontocerebellar Hypoplasia Type 2 and Type 4. 1993. [pmid: 20301773]. X-1, X-3, X-4, X-5.
190 Neumann S. Swallowing therapy with neurologic patients: results of direct and indirect therapy methods in 66 patients suffering from neurological disorders. Dysphagia. 1993;8(2):150-3. X-3, X-4, X-5. [pmid: 8467723].
191 Ramsay M, Gisel EG, Boutry M. Non-organic failure to thrive: growth failure secondary to feeding-skills disorder. Dev Med Child Neurol. Apr. 1993;35(4):285-97. X-3, X-4, X-5. [pmid: 8335143].
192 Rauen KA. Cardiofaciocutaneous Syndrome. 1993. [pmid: 20301365]. X-1, X-3, X-4.
193 Reyes AL, Cash AJ, Green SH. Gastro-esophageal reflux in children with cerebral palsy. Child Care Health Dev. 1993;19:109-18. X-4, X-5. [pmid: 8462129].
194 Rogers BT, Arvedson J, Msall M, et al. Hypoxemia during oral feeding of children with severe cerebral palsy. Dev Med Child Neurol. 1993;35:3-10. X-4, X-5. [pmid: 8449378].
195 Sant SM, Gilvarry J, Shannon R, et al. Percutaneous endoscopic gastrostomy—its application in patients with neurological disease. Ir J Med Sci. Nov. 1993;162(11):450-1. X-3. [pmid: 8113032].
196 Sigafoos J, et al. Short-term conductive education: an evaluation study. British Journal of Special Education. 1993;20(4):148-51. X-3, X-4, X-5.
197 Sommer A. Occurrence of the Sandifer complex in the Brachmann-de Lange syndrome. Am J Med Genet. Nov. 15. 1993;47(7):1026-8. X-3, X-4. [pmid: 8291518].
198 Sparks SE, Krasnewich DM. PMM2-CDG (CDG-Ia). 1993. [pmid: 20301289]. X-1, X-3, X-4.
199 Spitz L, Roth K, Kiely EM, et al. Operation for gastro-oesophageal reflux associated with severe mental retardation. Arch Dis Child. Mar. 1993;68(3):347-51. X-3, X-5. [pmid: 8466236].
200 Stallings VA, Charney EB, Davies JC, et al. Nutritional status and growth of children with diplegic or hemiplegic cerebral palsy. Dev Med Child Neurol. Nov. 1993;35(11):997-1006. X-4. [pmid: 8224567].
201 Stallings VA, Charney EB, Davies JC, et al. Nutrition-related growth failure of children with quadriplegic cerebral palsy. Dev Med Child Neurol. 1993;35:126-38. X-4, X-5. [pmid: 8444326].
202 Wilms G, Goffin J, Plets C, et al. Embolization of arteriovenous malformations of the brain: preliminary experience. J Belge Radiol. Oct. 1993;76(5):299-303. X-3, X-4. [pmid: 8119868].
203 Amundson JA, Sherbondy A, Van Dyke DC, et al. Early identification and treatment necessary to prevent malnutrition in children and adolescents with severe disabilities. J Am Diet Assoc. Aug. 1994;94(8):880-3. X-1, X-3, X-4, X-5. [pmid: 7519203].
204 Bensoussan AL, Yazbeck S, Carceller-Blanchard A. Results and complications of Toupet partial posterior wrap: 10 years' experience. J Pediatr Surg. Sep. 1994;29(9):1215-7. X-3, X-4. [pmid: 7807348].
205 Borgstein ES, Heij HA, Beugelaar JD, et al. Risks and benefits of antireflux operations in neurologically impaired children. Eur J Pediatr. Apr. 1994;153(4):248-51. X-3, X-4, X-5. [pmid: 8194556].
206 Buchholz DW. Dysphagia associated with neurological disorders. Acta Otorhinolaryngol Belg. 1994;48(2):143-55. X-1. [pmid: 8209677].
207 Coben RM, Weintraub A, DiMarino AJ Jr., et al. Gastroesophageal reflux during gastrostomy feeding. Gastroenterology. Jan. 1994;106(1):13-8. X-3, X-4, X-5. [pmid: 8276174].
208 De Assis JL, Marchiori PE, Scaff M. Atrophy of the tongue with persistent articulation disorder in myasthenia gravis: report of 10 patients. Auris Nasus Larynx. 1994;21(4):215-8. X-3, X-4. [pmid: 7779022].
209 Detoledo J, Icovinno J, Haddad H. Swallowing difficulties and early CNS injuries: correlation with the presence of axial skeletal deformities. Brain Inj. Oct. 1994;8(7):607-11. X-4. [pmid: 7804297].
210 Ferrara MS, Dattilo J, Dattilo AM. A cross-disability analysis of programming needs for athletes with disabilities. Palaestra. 1994;11(1):32-42. X-3, X-4, X-5.
211 Ganga UR, Ryan JJ, Schafer LW. Indications, complications, and long-term results of percutaneous endoscopic gastrostomy: a retrospective study. S D J Med. May. 1994;47(5):149-52. X-3. [pmid: 8047869].
212 Georgeson K, Halpin D, Figueroa R, et al. Sequential intestinal lengthening procedures for refractory short bowel syndrome. J Pediatr Surg. Feb. 1994;29(2):316-20. discussion 20-1. X-3, X-4, X-5. [pmid: 8176611].
213 Isaacs JS, Georgeson KE, Cloud HH, et al. Weight gain and triceps skinfolds fat mass after gastrostomy placement in children with developmental disabilities. J Am Diet Assoc. Aug. 1994;94(8):849-54. X-3. [pmid: 7519202].
214 Kazerooni NL, VanCamp J, Hirschl RB, et al. Fundoplication in 160 children under 2 years of age. J Pediatr Surg. May. 1994;29(5):677-81. X-3. [pmid: 8035282].
215 Lewis D, Khoshoo V, Pencharz PB, et al. Impact of nutritional rehabilitation on gastroesophageal reflux in neurologically impaired children. J Pediatr Surg. Feb. 1994;29(2):167-9. discussion 9-70. X-3, X-4. [pmid: 7513758].
216 Lund DP, Mitchell J, Kharasch V, et al. Congenital diaphragmatic hernia: the hidden morbidity. J Pediatr Surg. Feb. 1994;29(2):258-62. discussion 62-4. X-3, X-4, X-5. [pmid: 8176602].
217 Marin OE, Glassman MS, Schoen BT, et al. Safety and efficacy of percutaneous endoscopic gastrostomy in children. Am J Gastroenterol. Mar. 1994;89(3):357-61. X-3. [pmid: 8122644].
218 Massaro AR, Young WL, Kader A, et al. Characterization of arteriovenous malformation feeding vessels by carbon dioxide reactivity. AJNR Am J Neuroradiol. Jan. 1994;15(1):55-61. X-3, X-4. [pmid: 7908161].
219 Maxson RT, Harp S, Jackson RJ, et al. Delayed gastric emptying in neurologically impaired children with gastroesophageal reflux: the role of pyloroplasty. J Pediatr Surg. Jun. 1994;29(6):726-9. X-3, X-5. [pmid: 8078006].
220 Naureckas SM, Christoffel KK. Nasogastric or gastrostomy feedings in children with neurologic disabilities. Clin Pediatr (Phila). Jun. 1994;33(6):353-9. X-3. [pmid: 8200170].
221 Panos MZ, Reilly H, Moran A, et al. Percutaneous endoscopic gastrostomy in a general hospital: prospective evaluation of indications, outcome, and randomised comparison of two tube designs. Gut. Nov. 1994;35(11):1551-6. X-3, X-4, X-5. [pmid: 7828971].
222 Pelegano JP, Nowysz S, Goepferd S. Temporomandibular joint contracture in spastic quadriplegia: effect on oral-motor skills. Dev Med Child Neurol. Jun. 1994;36(6):487-94. X-4. [pmid: 8005359].
223 Quinn F. Cerebral palsy. Nurs Stand. 1994;9(10):41-8. X-1, X-4, X-5. [pmid: 7833242].
224 Rogers B, Arvedson J, Buck G, et al. Characteristics of dysphagia in children with cerebral palsy. Dysphagia. Winter. 1994;9(1):69-73. X-4. [pmid: 8131428].
225 Rogers BT, Stratton P, Msall M, et al. Long-term morbidity and management strategies of tracheal aspiration in adults with severe developmental disabilities. Am J Ment Retard. Jan. 1994;98(4):490-8. X-4, X-5. [pmid: 8148125].
226 Romero JC, Santolaria F, Gonzalez-Reimers E, et al. Chronic alcoholic myopathy and nutritional status. Alcohol. Nov-Dec. 1994;11(6):549-55. X-3, X-4. [pmid: 7865157].
227 Stallion A, Foley-Nelson T, Chance WT, et al. Parenteral vs enteral nutrition in tumor-bearing rats. JPEN J Parenter Enteral Nutr. Mar-Apr. 1994;18(2):148-53. X-3, X-4. [pmid: 8201750].
228 Taylor LA, Weiner T, Lacey SR, et al. Chronic lung disease is the leading risk factor correlating with the failure (wrap disruption) of antireflux procedures in children. J Pediatr Surg. Feb. 1994;29(2):161-4. discussion 4-6. X-3, X-4, X-5. [pmid: 8176586].
229 Tcheremenska AR, Gisel EG. Use of substitute food textures for standard eating assessment in children with cerebral palsy and children without disabilities. Am J Occup Ther. Jul. 1994;48(7):626-32. X-4. [pmid: 7943152].
230 van der Meer SB, Poggi F, Spada M, et al. Clinical outcome of long-term management of patients with vitamin B12-unresponsive methylmalonic acidemia. J Pediatr. Dec. 1994;125(6 Pt 1):903-8. X-3, X-4, X-5. [pmid: 7996362].
231 Winter S. Preoperative assessment of the child with neuromuscular scoliosis. Orthop Clin North Am. Apr. 1994;25(2):239-45. X-1. [pmid: 8159398].
232 Zickler CF, Dodge NN. Office management of the young child with cerebral palsy and difficulty in growing. J Pediatr Health Care. May-Jun. 1994;8(3):111-20. X-1, X-4, X-5. [pmid: 7799175].
233 Largest Medicare cuts in history. Maine Nurse. 1995;4. X-1, X-3, X-4, X-5.
234 Spinal cord injury and related neurological disorders: treatment and rehabilitation. Rehab R&D Prog Rep. 1995;32:268-92. X-1, X-3, X-4, X-5.
235 Alexandrov AV, Bladin CF, Meslin EM, et al. Do-not-resuscitate orders in acute stroke. Neurology. Apr. 1995;45(4):634-40. X-3, X-4. [pmid: 7723947].
236 Bagwell CE. Gastroesophageal reflux in children. Surg Annu. 1995;27:133-63. X-1. [pmid: 7597547].
237 Brook I. Anaerobic infections in children with neurological impairments. Am J Ment Retard. May. 1995;99(6):579-94. X-1. [pmid: 7632426].
238 Cameron BH, Blair GK, Murphy JJ 3rd, et al. Morbidity in neurologically impaired children after percutaneous endoscopic versus Stamm gastrostomy. Gastrointest Endosc. Jul. 1995;42(1):41-4. X-3. [pmid: 7557175].
239 Casas MJ, McPherson KA, Kenny DJ. Durational aspects of oral swallow in neurologically normal children and children with cerebral palsy: an ultrasound investigation. Dysphagia. Summer. 1995;10(3):155-9. X-4. [pmid: 7614854].
240 Clark GF. Nutritional needs of children with developmental disabilities and the school lunch program. Phys Occup Ther Pediatr. 1995;15(1):83-9. X-1, X-3, X-4, X-5. [pmid: 21275625].
241 Coggan AR. Muscle biopsy as a tool in the study of aging. J Gerontol A Biol Sci Med Sci. Nov. 1995;50(Spec No):30-4. X-3. [pmid: 7493214].
242 Collins JB 3rd, Georgeson KE, Vicente Y, et al. Comparison of open and laparoscopic gastrostomy and fundoplication in 120 patients. J Pediatr Surg. Jul. 1995;30(7):1065-70. discussion 70-1. X-3. [pmid: 7472934].
243 Duh QY, Senokozlieff-Englehart AL, Siperstein AE, et al. Prospective evaluation of the safety and efficacy of laparoscopic jejunostomy. West J Med. Feb. 1995;162(2):117-22. X-3, X-4, X-5. [pmid: 7725683].
244 Dutton JA, Jackson JE, Hughes JM, et al. Pulmonary arteriovenous malformations: results of treatment with coil embolization in 53 patients. AJR Am J Roentgenol. Nov. 1995;165(5):1119-25. X-3, X-4. [pmid: 7572487].
245 Eibling DE, Snyderman CH, Eibling C. Laryngotracheal separation for intractable aspiration: a retrospective review of 34 patients. Laryngoscope. Jan. 1995;105(1):83-5. X-1, X-3, X-4. [pmid: 7837920].
246 Fonkalsrud EW, Ellis DG, Shaw A, et al. A combined hospital experience with fundoplication and gastric emptying procedure for gastroesophageal reflux in children. J Am Coll Surg. Apr. 1995;180(4):449-55. X-3. [pmid: 7719549].
247 Gisel E, Alphonce E. Classification of eating impairments based on eating efficiency in children with cerebral palsy. Dysphagia. 1995;10. X-5.
248 Hassall E. Wrap session: is the Nissen slipping? Can medical treatment replace surgery for severe gastroesophageal reflux disease in children?. Am J Gastroenterol. Aug. 1995;90(8):1212-20. X-1. [pmid: 7639217].
249 Heine RG, Reddihough DS, Catto-Smith AG. Gastro-oesophageal reflux and feeding problems after gastrostomy in children with severe neurological impairment. Dev Med Child Neurol. Apr. 1995;37(4):320-9. X-3. [pmid: 7698523].
250 Henderson RC, Lin PP, Greene WB. Bone-mineral density in children and adolescents who have spastic cerebral palsy. J Bone Joint Surg Am. Nov. 1995;77(11):1671-81. X-2, X-4, X-5. [pmid: 7593076].
251 Iannettoni MD, Whyte RI, Orringer MB. Catastrophic complications of the cervical esophagogastric anastomosis. J Thorac Cardiovasc Surg. Nov. 1995;110(5):1493-500. discussion 500-1. X-3, X-4, X-5. [pmid: 7475201].
252 Kohli H, Bloch R. Percutaneous endoscopic gastrostomy: a community hospital experience. Am Surg. Mar. 1995;61(3):191-4. X-3, X-4, X-5. [pmid: 7887526].
253 Legge L. “Renaissance nurse”: Naida Colby suggests return to natural, spiritual healing. Minnesota Nursing Accent. 1995;67(4):3-4. X-1, X-3, X-4, X-5.
254 Mazzini L, Corra T, Zaccala M, et al. Percutaneous endoscopic gastrostomy and enteral nutrition in amyotrophic lateral sclerosis. J Neurol. Oct. 1995;242(10):695-8. X-3, X-4. [pmid: 8568533].
255 Myhr U, von Wendt L, Norrlin S, et al. Five-year follow-up of functional sitting position in children with cerebral palsy. Dev Med Child Neurol. Jul. 1995;37(7):587-96. X-3, X-4, X-5. [pmid: 7615145].
256 North KN, Korson MS, Gopal YR, et al. Neonatal-onset propionic acidemia: neurologic and developmental profiles, and implications for management. J Pediatr. Jun. 1995;126(6):916-22. X-3, X-4, X-5. [pmid: 7539836].
257 Reilly S, Skuse D, Mathisen B, et al. The objective rating of oral-motor functions during feeding. Dysphagia. Summer. 1995;10(3):177-91. X-4. [pmid: 7614860].
258 Singh V, Brockbank MJ, Frost RA, et al. Multidisciplinary management of dysphagia: the first 100 cases. J Laryngol Otol. May. 1995;109(5):419-24. X-3, X-4, X-5. [pmid: 7797998].
259 Skuse D, Stevenson J, Reilly S, et al. Schedule for oral-motor assessment (SOMA): methods of validation. Dysphagia. Summer. 1995;10(3):192-202. X-4. [pmid: 7614861].
260 Stallings VA, Cronk CE, Zemel BS, et al. Body composition in children with spastic quadriplegic cerebral palsy. J Pediatr. May. 1995;126(5 Pt 1):833-9. X-4. [pmid: 7752019].
261 Stevenson RD, Roberts CD, Vogtle L. The effects of non-nutritional factors on growth in cerebral palsy. Dev Med Child Neurol. Feb. 1995;37(2):124-30. X-4. [pmid: 7851668].
262 Veit F, Schwagten K, Auldist AW, et al. Trends in the use of fundoplication in children with gastro-oesophageal reflux. J Paediatr Child Health. Apr. 1995;31(2):121-6. X-3, X-4, X-5. [pmid: 7794612].
263 Vento BA, Durrant JD, Palmer CV, et al. Middle ear effects secondary to nasogastric intubation. Am J Otol. Nov. 1995;16(6):820-2. X-4. [pmid: 8572150].
264 Weber TR. A prospective analysis of factors influencing outcome after fundoplication. J Pediatr Surg. Jul. 1995;30(7):1061-3. discussion 3-4. X-3, X-4, X-5. [pmid: 7472933].
265 Wilson WR, Hariri SM. Experience with percutaneous endoscopic gastrostomy on an otolaryngology service. Ear Nose Throat J. Nov. 1995;74(11):760-2. X-3, X-4, X-5. [pmid: 8536563].
266 Wing SS, Haas AL, Goldberg AL. Increase in ubiquitin-protein conjugates concomitant with the increase in proteolysis in rat skeletal muscle during starvation and atrophy denervation. Biochem J. May. 1. 1995;307(Pt 3):639-45. X-3, X-4. [pmid: 7741691].
267 Functional electrical stimulation: general. Rehab R&D Prog Rep. 1996;33:69-80. X-3, X-4, X-5.
268 Independent living aids: general. Rehab R&D Prog Rep. 1996;33:124-37. X-1, X-3, X-4, X-5.
269 Azcue MP, Zello GA, Levy LD, et al. Energy expenditure and body composition in children with spastic quadriplegic cerebral palsy. J Pediatr. 1996;129:870-6. X-4, X-5. [pmid: 8969729].
270 Brown N. How should very low birthweight babies best be managed in Papua New Guinea?. P N G Med J. Mar. 1996;39(1):12-5. X-4. [pmid: 9522845].
271 Chait PG, Weinberg J, Connolly BL, et al. Retrograde percutaneous gastrostomy and gastrojejunostomy in 505 children: a 4 1/2-year experience. Radiology. Dec. 1996;201(3):691-5. X-3, X-4, X-5. [pmid: 8939217].
272 Chavin K, Field G, Chandler J, et al. Save the child's esophagus: management of major disruption after repair of esophageal atresia. J Pediatr Surg. Jan. 1996;31(1):48-51. discussion 2. X-3, X-4, X-5. [pmid: 8632285].
273 Chossegros C, Cheynet F, Gola R, et al. Clinical results of therapeutic temporomandibular joint arthroscopy: a prospective study of 34 arthroscopies with prediscal section and retrodiscal coagulation. Br J Oral Maxillofac Surg. Dec. 1996;34(6):504-7. X-4. [pmid: 8971443].
274 Conley SF, Kodali S, Beecher RB, et al. Changes in deglutition following tonsillectomy in neurologically impaired children. Int J Pediatr Otorhinolaryngol. Jun. 1996;36(1):13-21. X-4. [pmid: 8803687].
275 Corwin DS, Isaacs JS, Georgeson KE, et al. Weight and length increases in children after gastrostomy placement. J Am Diet Assoc. Sep. 1996;96(9):874-9. X-3. [pmid: 8784331].
276 Dahl M, Thommessen M, Rasmussen M, et al. Feeding and nutritional characteristics in children with moderate or severe cerebral palsy. Acta Paediatr. Jun. 1996;85(6):697-701. X-4, X-5. [pmid: 8816207].
277 Davalos A, Ricart W, Gonzalez-Huix F, et al. Effect of malnutrition after acute stroke on clinical outcome. Stroke. Jun. 1996;27(6):1028-32. X-3, X-4. [pmid: 8650709].
278 Deruty R, Pelissou-Guyotat I, Amat D, et al. Complications after multidisciplinary treatment of cerebral arteriovenous malformations. Acta Neurochir (Wien). 1996;138(2):119-31. X-3. [pmid: 8686534].
279 Fonkalsrud EW, Ament ME. Gastroesophageal reflux in childhood. Curr Probl Surg. Jan. 1996;33(1):1-70. X-1. [pmid: 8536488].
280 Gerber ME, Gaugler MD, Myer CM 3rd, et al. Chronic aspiration in children. When are bilateral submandibular gland excision and parotid duct ligation indicated?. Arch Otolaryngol Head Neck Surg. Dec. 1996;122(12):1368-71. X-4. [pmid: 8956752].
281 Griffiths M. Single-stage percutaneous gastrostomy button insertion: a leap forward. JPEN J Parenter Enteral Nutr. May-Jun. 1996;20(3):237-9. X-3, X-5. [pmid: 8776700].
282 Heine RG, Catto-Smith AG, Reddihough DS. Effect of antireflux medication on salivary drooling in children with cerebral palsy. Dev Med Child Neurol. Nov. 1996;38(11):1030-6. X-4. [pmid: 8913184].
283 Heloury Y, Plattner V, Mirallie E, et al. Laparoscopic Nissen fundoplication with simultaneous percutaneous endoscopic gastrostomy in children. Surg Endosc. Aug. 1996;10(8):837-41. X-3, X-4, X-5. [pmid: 8694949].
284 Hotokezaka M, Adams RB, Miller AD, et al. Laparoscopic percutaneous jejunostomy for long term enteral access. Surg Endosc. Oct. 1996;10(10):1008-11. X-3, X-4, X-5. [pmid: 8864096].
285 Humphrey GM, Najmaldin AS. Laparoscopic Nissen fundoplication in disabled infants and children. J Pediatr Surg. Apr. 1996;31(4):596-9. X-3, X-4, X-5. [pmid: 8801322].
286 Hussain A, Woolfrey S, Massey J, et al. Percutaneous endoscopic gastrostomy. Postgrad Med J. Oct. 1996;72(852):581-5. X-1. [pmid: 8977937].
287 Khoshoo V, Zembo M, King A, et al. Incidence of gastroesophageal reflux with whey- and casein-based formulas in infants and in children with severe neurological impairment. J Pediatr Gastroenterol Nutr. Jan. 1996;22(1):48-55. X-4, X-5. [pmid: 8788287].
288 Mahoney RM, Phalangas A. Consumer evaluation of powered feeding devices. Proceedings of the RESNA 1996 Annual Conference: exploring New Horizons. 1996. 134-6. X-4, X-5.
289 Martin D, Merkel E, Tucker KK, et al. Cachectic effect of ciliary neurotrophic factor on innervated skeletal muscle. Am J Physiol. Nov. 1996;271(5 Pt 2):R1422-8. X-3, X-4. [pmid: 8945982].
290 McCarey DW, Buchanan E, Gregory M, et al. Home enteral feeding of children in the west of Scotland. Scott Med J. Oct. 1996;41(5):147-9. X-4, X-5. [pmid: 8912986].
291 Migliore M, Payne HR, Jeyasingham K. Pharyngo-oesophageal dysphagia: surgery based on clinical and manometric data. Eur J Cardiothorac Surg. 1996;10(5):365-71. X-3, X-4, X-5. [pmid: 8737694].
292 Norrie MW, Lane MR. Percutaneous endoscopic gastronomy feeding tubes: a retrospective review at Auckland Hospital 1993-4. N Z Med J. Aug. 9. 1996;109(1027):299-301. X-3, X-5. [pmid: 8773675].
293 Ockenga J, Suttmann U, Selberg O, et al. Percutaneous endoscopic gastrostomy in AIDS and control patients: risks and outcome. Am J Gastroenterol. Sep. 1996;91(9):1817-22. X-3, X-4, X-5. [pmid: 8792705].
294 O'Neill JK, O'Neill PJ, Goth-Owens T, et al. Caregiver evaluation of anti-gastroesophageal reflux procedures in neurologically impaired children: what is the real-life outcome?. J Pediatr Surg. Mar. 1996;31(3):375-80. X-3. [pmid: 8708906].
295 Pick N, McDonald A, Bennett N, et al. Pulmonary aspiration in a long-term care setting: clinical and laboratory observations and an analysis of risk factors. J Am Geriatr Soc. Jul. 1996;44(7):763-8. X-3, X-4. [pmid: 8675922].
296 Pucciarelli S, Toppan P, Fede A, et al. Percutaneous endoscopic gastrostomy for feeding. A comparison between neurologic and neoplastic indications. ORL J Otorhinolaryngol Relat Spec. Sep-Oct. 1996;58(5):253-7. X-3, X-4, X-5. [pmid: 8936474].
297 Ramachandran V, Ashcraft KW, Sharp RJ, et al. Thal fundoplication in neurologically impaired children. J Pediatr Surg. Jun. 1996;31(6):819-22. X-3, X-5. [pmid: 8783112].
298 Ravelli A, Richards CA, Spitz L. Is Nissen fundoplication the optimal treatment for gastroesophageal reflux in children with neurological impairment?. J Pediatr Gastroenterol Nutr. 1996;22:411. X-3, X-4, X-5.
299 Robertson FM, Crombleholme TM, Latchaw LA, et al. Modification of the “push” technique for percutaneous endoscopic gastrostomy in infants and children. J Am Coll Surg. Mar. 1996;182(3):215-8. X-3, X-4, X-5. [pmid: 8603240].
300 Shiao SY, Brooker J, DiFiore T. Desaturation events during oral feedings with and without a nasogastric tube in very low birth weight infants. Heart Lung. May-Jun. 1996;25(3):236-45. X-3, X-4. [pmid: 8635924].
301 Smith D, Soucy P. Complications of long-term jejunostomy in children. J Pediatr Surg. Jun. 1996;31(6):787-90. X-3, X-4, X-5. [pmid: 8783104].
302 Spillane AJ, Currie B, Shi E. Fundoplication in children: experience with 106 cases. Aust N Z J Surg. Nov. 1996;66(11):753-6. X-5. [pmid: 8918384].
303 Stallings VA, Zemel BS, Davies JC, et al. Energy expenditure of children and adolescents with severe disabilities: a cerebral palsy model. Am J Clin Nutr. Oct. 1996;64(4):627-34. X-4. [pmid: 8839510].
304 Walters S. The sooner we start, the farther they'll go… the nurse's role in early intervention. Chart. 1996;93(3):7. X-1, X-3, X-4, X-5.
305 Yanai J, Abu-Roumi M, Silverman WF, et al. Neural grafting as a tool for the study and reversal of neurobehavioral birth defects. Pharmacol Biochem Behav. Dec. 1996;55(4):673-81. X-3, X-4. [pmid: 8981599].
306 ATSDR Child Health Initiative. Healthy children — toxic environments: acting on the unique vulnerability of children who dwell near hazardous waste sites. Report of the Child Health Workgroup Board of Scientific Counselors. 1997:41. X-9.
307 Child health services: building a research agenda. Report to the Committee on Appropriations, U.S. House of Representatives. 1997:31. X-9.
308 Independent living aids. General. Rehab R&D Prog Rep. 1997;34:132-42. X-1, X-3, X-4, X-5.
309 Independent living aids. Robotics. Rehab R&D Prog Rep. 1997;34:142-52. X-1, X-3, X-4, X-5.
310 Orthotics. Rehab R&D Prog Rep. 1997;34:231-41. X-1, X-3, X-4, X-5.
311 Spinal cord injury and related neurological disorders. Treatment and rehabilitation. Rehab R&D Prog Rep. 1997;34:283-301. X-1, X-3, X-4, X-5.
312 The leading edge. Research excellence 1997 honour roll. ConceRN. 1997;26(2):6. X-1, X-3, X-4, X-5.
313 Akpunonu BE, Mutgi AB, Roberts C, et al. Modified barium swallow does not affect how often PEGs are placed after stroke. J Clin Gastroenterol. Mar. 1997;24(2):74-8. X-3, X-4. [pmid: 9077720].
314 Alexander F, Wyllie R, Jirousek K, et al. Delayed gastric emptying affects outcome of Nissen fundoplication in neurologically impaired children. Surgery. Oct. 1997;122(4):690-7. discussion 7-8. X-3, X-4, X-5. [pmid: 9347844].
315 Allen RD, Al-Harbi IS, Morris JG, et al. Diabetic neuropathy after pancreas transplantation: determinants of recovery. Transplantation. Mar. 27. 1997;63(6):830-8. X-3, X-4. [pmid: 9089222].
316 Bianchi A. Total esophagogastric dissociation: an alternative approach. J Pediatr Surg. Sep. 1997;32(9):1291-4. X-3, X-4. [pmid: 9314245].
317 Bishop NJ, Morley R, Day JP, et al. Aluminum neurotoxicity in preterm infants receiving intravenous-feeding solutions. N Engl J Med. May. 29. 1997;336(22):1557-61. X-3, X-4. [pmid: 9164811].
318 Bohmer CJ, Niezen-de Boer MC, Klinkenberg-Knol EC, et al. Gastro-oesophageal reflux disease in institutionalised intellectually disabled individuals. Neth J Med. Oct. 1997;51(4):134-9. X-4. [pmid: 9446923].
319 Borowitz SM, Sutphen JL, Hutcheson RL. Percutaneous endoscopic gastrostomy without an antireflux procedure in neurologically disabled children. Clin Pediatr (Phila). Jan. 1997;36(1):25-9. X-3. [pmid: 9007344].
320 Cameron BH, Cochran WJ, McGill CW. The uncut Collis-Nissen fundoplication: results for 79 consecutively treated high-risk children. J Pediatr Surg. Jun. 1997;32(6):887-91. X-3, X-4, X-5. [pmid: 9200093].
321 Cook SP, Lawless S, Mandell GA, et al. The use of the salivagram in the evaluation of severe and chronic aspiration. Int J Pediatr Otorhinolaryngol. Sep. 18. 1997;41(3):353-61. X-4. [pmid: 9350494].
322 Crocker MD, MacKay-Lyons M, McDonnell E. Forced use of the upper extremity in cerebral palsy: a single-case design. Am J Occup Ther. Nov-Dec. 1997;51(10):824-33. X-4. [pmid: 9394143].
323 Dalla Vecchia LK, Grosfeld JL, West KW, et al. Reoperation after Nissen fundoplication in children with gastroesophageal reflux: experience with 130 patients. Ann Surg. Sep. 1997;226(3):315-21. discussion 21-3. X-3, X-4, X-5. [pmid: 9339938].
324 Deshpande AA, Millis SR, Zafonte RD, et al. Risk factors for acute care transfer among traumatic brain injury patients. Arch Phys Med Rehabil. Apr. 1997;78(4):350-2. X-3, X-4. [pmid: 9111452].
325 Eltumi M, Sullivan PB. Nutritional management of the disabled child: the role of percutaneous endoscopic gastrostomy. Dev Med Child Neurol. Jan. 1997;39(1):66-8. X-1, X-3, X-4, X-5. [pmid: 9003733].
326 Fox VL, Abel SD, Malas S, et al. Complications following percutaneous endoscopic gastrostomy and subsequent catheter replacement in children and young adults. Gastrointest Endosc. Jan. 1997;45(1):64-71. X-3, X-4, X-5. [pmid: 9013172].
327 Gilchrist BF, Luks FI, DeLuca FG, et al. A modified feeding Roux-en-Y jejunostomy in the neurologically damaged child. J Pediatr Surg. Apr. 1997;32(4):588-9. X-3, X-4, X-5. [pmid: 9126760].
328 Heiskala H, Tokola R, Tammisto P, et al. Carbamazepine- or oxcarbazepine-induced hyponatraemia or leucopenia, or both, in residents with a developmental disability. J Intellect Dev Disabil. Dec. 1997;22(4):275-80. X-4.
329 Humphrey GM, Najmaldin A. Laparoscopic gastrostomy in children. Pediatr Surg Int. Sep. 1997;12(7):501-4. X-3, X-4, X-5. [pmid: 9238116].
330 Isch JA, Rescorla FJ, Scherer LR 3rd, et al. The development of gastroesophageal reflux after percutaneous endoscopic gastrostomy. J Pediatr Surg. Feb. 1997;32(2):321-2. discussion 2-3. X-3, X-4. [pmid: 9044145].
331 Kennedy M, McCombie L, Dawes P, et al. Nutritional support for patients with intellectual disability and nutrition/dysphagia disorders in community care. J Intellect Disabil Res. Oct. 1997;41(Pt 5):430-6. X-3, X-4, X-5. [pmid: 9373824].
332 Martin RE, Neary MA, Diamant NE. Dysphagia following anterior cervical spine surgery. Dysphagia. Winter. 1997;12(1):2-8. discussion 9-10. X-3, X-4. [pmid: 8997826].
333 Olteanu-Nerbe V, Uhl E, Steiger HJ, et al. Dural arteriovenous fistulas including the transverse and sigmoid sinuses: results of treatment in 30 cases. Acta Neurochir (Wien). 1997;139(4):307-18. X-3, X-4. [pmid: 9202770].
334 Peters JM, Simpson P, Tolia V. Experience with gastrojejunal feeding tubes in children. Am J Gastroenterol. Mar. 1997;92(3):476-80. X-3, X-5. [pmid: 9068473].
335 Rosenberg AA, Kennaugh JM, Moreland SG, et al. Longitudinal follow-up of a cohort of newborn infants treated with inhaled nitric oxide for persistent pulmonary hypertension. J Pediatr. Jul. 1997;131(1 Pt 1):70-5. X-3, X-4. [pmid: 9255194].
336 Savin J, Ogden GR. Third molar surgery—a preliminary report on aspects affecting quality of life in the early postoperative period. Br J Oral Maxillofac Surg. Aug. 1997;35(4):246-53. X-3, X-4. [pmid: 9291262].
337 Schumacher G, Platz KP, Mueller AR, et al. Liver transplantation: treatment of choice for hepatic and neurological manifestation of Wilson's disease. Clin Transplant. Jun. 1997;11(3):217-24. X-3, X-4. [pmid: 9193846].
338 Shiao SY. Comparison of continuous versus intermittent sucking in very-low-birth-weight infants. J Obstet Gynecol Neonatal Nurs. May-Jun. 1997;26(3):313-9. X-3, X-4, X-5. [pmid: 9170595].
339 Strauss D, Kastner T, Ashwal S, et al. Tubefeeding and mortality in children with severe disabilities and mental retardation. Pediatrics. Mar. 1997;99(3):358-62. X-3, X-5. [pmid: 9041288].
340 Sullivan PB. Gastrointestinal problems in the neurologically impaired child. Baillieres Clin Gastroenterol. Sep. 1997;11(3):529-46. X-1, X-3, X-4, X-5. [pmid: 9448914].
341 Tawfik R, Dickson A, Clarke M, et al. Caregivers' perceptions following gastrostomy in severely disabled children with feeding problems. Dev Med Child Neurol. Nov. 1997;39(11):746-51. X-3. [pmid: 9393888].
342 Thorne SE, Radford MJ, Armstrong EA. Long-term gastrostomy in children: caregiver coping. Gastroenterol Nurs. Mar-Apr. 1997;20(2):46-53. X-3, X-4, X-5. [pmid: 9223969].
343 Thorne SE, Radford MJ, McCormick J. The multiple meanings of long-term gastrostomy in children with severe disability. J Pediatr Nurs. Apr. 1997;12(2):89-99. X-3, X-4, X-5. [pmid: 9103777].
344 Urban KG, Terris DJ. Percutaneous endoscopic gastrostomy by head and neck surgeons. Otolaryngol Head Neck Surg. Apr. 1997;116(4):489-92. X-3, X-4, X-5. [pmid: 9141399].
345 Zamir O, Udassin R, Seror D, et al. Laparoscopic Nissen fundoplication in children under 2 years of age. Surg Endosc. Dec. 1997;11(12):1202-5. X-3. [pmid: 9373294].
346 Functional outcomes. Rehab R&D Prog Rep. 1998;35:314-24. X-1, X-3, X-4, X-5.
347 Spinal cord injury and related neurological disorders: general. Rehab R&D Prog Rep. 1998;35:251-63. X-1, X-3, X-4, X-5.
348 Trends in disability prevalence and their causes: proceedings of the Fourth National Disability Statistics and Policy Forum. Disability forum report. 1998;50. X-11.
349 Bachrach S, Melnychuk JO, Vinton NE, et al. Percutaneous endoscopic gastrostomy (PEG) tubes for enteral nutrition support (ENS) in neurologically impaired children. Dev Med Child Neurol. 1998;40:16. X-3, X-5.
350 Balan KK, Vinjamuri S, Maltby P, et al. Gastroesophageal reflux in patients fed by percutaneous endoscopic gastrostomy (PEG): detection by a simple scintigraphic method. Am J Gastroenterol. Jun. 1998;93(6):946-9. X-4. [pmid: 9647025].
351 Bohmer CJ, Niezen-de Boer RC, Klinkenberg-Knol EC, et al. Omeprazole: therapy of choice in intellectually disabled children. Arch Pediatr Adolesc Med. Nov. 1998;152(11):1113-8. X-4. [pmid: 9811290].
352 Borovoy J, Furuta L, Nurko S. Benefit of uncooked cornstarch in the management of children with dumping syndrome fed exclusively by gastrostomy. Am J Gastroenterol. May. 1998;93(5):814-8. X-3, X-4, X-5. [pmid: 9625134].
353 Bosscha K, Nieuwenhuijs VB, Vos A, et al. Gastrointestinal motility and gastric tube feeding in mechanically ventilated patients. Crit Care Med. Sep. 1998;26(9):1510-7. X-3, X-4. [pmid: 9751586].
354 Ceriati E, Guarino N, Zaccara A, et al. Gastroesophageal reflux in neurologically impaired children: partial or total fundoplication?. Langenbecks Arch Surg. Oct. 1998;383(5):317-9. X-3, X-5. [pmid: 9860222].
355 Fonkalsrud EW, Ashcraft KW, Coran AG, et al. Surgical treatment of gastroesophageal reflux in children: a combined hospital study of 7467 patients. Pediatrics. Mar. 1998;101(3 Pt 1):419-22. X-3, X-4, X-5. [pmid: 9481007].
356 Gisel EG, Birnbaum R, Schwartz S. Feeding impairments in children: diagnosis and effective intervention. Int J Orofacial Myology. 1998;24:27-33. X-1. [pmid: 10635165].
357 Hanley GP, Piazza CC, Keeney KM, et al. Effects of wrist weights on self-injurious and adaptive behavior. J Appl Behav Anal. 1998;31(2):307-10. X-1, X-4. [pmid: 9652108].
358 Inge TH, Carmeci C, Ohara LJ, et al. Outcome of Nissen fundoplication using intraoperative manometry in children. J Pediatr Surg. Nov. 1998;33(11):1614-7. X-3, X-4, X-5. [pmid: 9856878].
359 Iskowitz M. Pediatrics and DD: airways issues and dysphagia. Adv Occup Ther Pract. 1998;14(23):18-66. X-1, X-3, X-4, X-5.
360 Kang A, Zamora SA, Scott RB, et al. Catch-up growth in children treated with home enteral nutrition. Pediatrics. Oct. 1998;102(4 Pt 1):951-5. X-3. [pmid: 9755271].
361 Khan NZ, Ferdous S, Munir S, et al. Mortality of urban and rural young children with cerebral palsy in Bangladesh. Dev Med Child Neurol. Nov. 1998;40(11):749-53. X-4. [pmid: 9881804].
362 Khattak IU, Kimber C, Kiely EM, et al. Percutaneous endoscopic gastrostomy in paediatric practice: complications and outcome. J Pediatr Surg. Jan. 1998;33(1):67-72. X-3, X-4. [pmid: 9473103].
363 Kimber C, Kiely EM, Spitz L. The failure rate of surgery for gastro-oesophageal reflux. J Pediatr Surg. Jan. 1998;33(1):64-6. X-4. [pmid: 9473102].
364 King TA, Jackson GL, Josey AS, et al. The effect of profound umbilical artery acidemia in term neonates admitted to a newborn nursery. J Pediatr. Apr. 1998;132(4):624-9. X-4. [pmid: 9580760].
365 Lepage C, Noreau L, Bernard PM, et al. Profile of handicap situations in children with cerebral palsy. Scand J Rehabil Med. Dec. 1998;30(4):263-72. X-4. [pmid: 9825391].
366 Liptak GS. The child who has severe neurologic impairment. Pediatr Clin North Am. Feb. 1998;45(1):123-44. X-1, X-4. [pmid: 9491090].
367 Loser C, Wolters S, Folsch UR. Enteral long-term nutrition via percutaneous endoscopic gastrostomy (PEG) in 210 patients: a four-year prospective study. Dig Dis Sci. Nov. 1998;43(11):2549-57. X-3, X-4, X-5. [pmid: 9824149].
368 Mayr J, Sauer H, Huber A, et al. Modified Toupet wrap for gastroesophageal reflux in childhood. Eur J Pediatr Surg. Apr. 1998;8(2):75-80. X-3, X-5. [pmid: 9617604].
369 Ohtawa T, Katagiri M, Harada T. A study of sternocleidomastoid muscular atrophy after modified neck dissection. Surg Today. 1998;28(1):46-58. X-3, X-4. [pmid: 9505317].
370 Osamura T, Hasegawa K, Yoshioka H, et al. Total body bone development during early childhood in very low birth weight infants without cerebral palsy and mental retardation. J Nutr Sci Vitaminol (Tokyo). Apr. 1998;44(2):269-77. X-3, X-4. [pmid: 9675707].
371 Overeynder JC, Turk MA. Cerebral palsy and aging: a framework for promoting the health of older persons with cerebral palsy. Topics in Geriatric Rehabilitation. 1998;13(3):19-24. X-1, X-4, X-5.
372 Petridou E, Koussouri M, Toupadaki N, et al. Diet during pregnancy and the risk of cerebral palsy. Br J Nutr. May. 1998;79(5):407-12. X-4. [pmid: 9682658].
373 Plioplys AV, Kasnicka I, Lewis S, et al. Survival rates among children with severe neurologic disabilities. South Med J. Feb. 1998;91(2):161-72. X-3, X-4, X-5. [pmid: 9496870].
374 Pou AM, Carrau RL, Eibling DE, et al. Laryngeal framework surgery for the management of aspiration in high vagal lesions. Am J Otolaryngol. Jan-Feb. 1998;19(1):1-7. X-3, X-4. [pmid: 9470943].
375 Richards CA, Andrews PL, Spitz L, et al. Nissen fundoplication may induce gastric myoelectrical disturbance in children. J Pediatr Surg. Dec. 1998;33(12):1801-5. X-3, X-4, X-5. [pmid: 9869055].
376 Rogers B, Andrus J, Msall ME, et al. Growth of preterm infants with cystic periventricular leukomalacia. Dev Med Child Neurol. Sep. 1998;40(9):580-6. X-4. [pmid: 9766734].
377 Samson-Fang L, Stevenson RD. Linear growth velocity in children with cerebral palsy. Dev Med Child Neurol. Oct. 1998;40(10):689-92. X-4. [pmid: 9851238].
378 Sane SS, Towbin A, Bergey EA, et al. Percutaneous gastrostomy tube placement in patients with ventriculoperitoneal shunts. Pediatr Radiol. Jul. 1998;28(7):521-3. X-3, X-4, X-5. [pmid: 9662573].
379 Sauve RS, Robertson C, Etches P, et al. Before viability: a geographically based outcome study of infants weighing 500 grams or less at birth. Pediatrics. Mar. 1998;101(3 Pt 1):438-45. X-3, X-4. [pmid: 9481011].
380 Schulte LS. JWOD CRP's: social entrepreneurs and the business of rehabilitation. American Rehabilitation. 1998;24(1):2-9. X-1, X-3, X-4, X-5.
381 Shimozono M, Townsend JC, Ilsen PF, et al. Acute vision loss resulting from complications of ethanol abuse. J Am Optom Assoc. May. 1998;69(5):293-303. X-3. [pmid: 9610037].
382 Shteyer E, Rothman E, Constantini S, et al. Gastroesophageal reflux in infants with hydrocephalus before and after ventriculoperitoneal shunt operation. Pediatr Neurosurg. Sep. 1998;29(3):138-41. X-3, X-4. [pmid: 9838266].
383 Simpson B, Ricketts RR, Parker PM. Prosthetic patch stabilization of crural repair in antireflux surgery in children. Am Surg. Jan. 1998;64(1):67-9. discussion 9-70. X-3, X-4, X-5. [pmid: 9457040].
384 Spalding K, McKeever P. Mothers' experiences caring for children with disabilities who require a gastrostomy tube. J Pediatr Nurs. Aug. 1998;13(4):234-43. X-4, X-5. [pmid: 9753909].
385 Sprague J, Flannery B, Szidon K. Functional analysis and treatment of mealtime problem behavior for a person with developmental disabilities. J Behav Educ. Sep. 1998;8(3):381-92. X-3.
386 Strauss DJ, Shavelle RM, Anderson TW. Life expectancy of children with cerebral palsy. Pediatr Neurol. Feb. 1998;18(2):143-9. X-4, X-5. [pmid: 9535300].
387 Strauss DJ, Shavelle RM, Anderson TW. Long-term survival of children and adolescents after traumatic brain injury. Arch Phys Med Rehabil. 1998;79(9):1095-100. X-3, X-4, X-5. [pmid: 9749690].
388 Sulaeman E, Udall JN Jr., Brown RF, et al. Gastroesophageal reflux and Nissen fundoplication following percutaneous endoscopic gastrostomy in children. J Pediatr Gastroenterol Nutr. Mar. 1998;26(3):269-73. X-3. [pmid: 9523860].
389 Suresh-Babu MV, Thomas AG. Nutrition in children with cerebral palsy. J Pediatr Gastroenterol Nutr. Apr. 1998;26(4):484-5. X-4, X-5. [pmid: 9552153].
390 Thorne SE, Radford MJ. A comparative longitudinal study of gastrostomy devices in children. West J Nurs Res. Apr. 1998;20(2):145-59. discussion 59-65. X-5. [pmid: 9550928].
391 Trachtenbarg DE, Golemon TB. Office care of the premature infant: Part II. Common medical and surgical problems. Am Fam Physician. May. 15. 1998;57(10):2383-90. 400. 2. X-1. [pmid: 9614410].
392 1999 Academy Annual Assembly Abstracts. Paper presentations and poster presentations. Arch Phys Med Rehabil. 1999;80(9):1118-205. X-11.
393 1999 ACRM 76th Annual Meeting Abstracts. Arch Phys Med Rehabil. 1999;80(8):968-81. X-11.
394 1999 Annual meeting of the Scientific paper and poster abstracts for the American Academy for Cerebral Palsy & Developmental Medicine, Washington DC, on September 15-18, 1999. Dev Med Child Neurol. 1999;41:1-46. X-11.
395 European Academy of Childhood Disability. Annual Meeting 1999. Dev Med Child Neurol. 1999;41:3-23. X-11. [pmid: 10068042].
396 Arnbjornsson E, Larsson LT, Lindhagen T. Complications of laparoscopy-aided gastrostomies in pediatric practice. J Pediatr Surg. Dec. 1999;34(12):1843-6. X-3, X-4, X-5. [pmid: 10626869].
397 Bauer ML, Lyrene RK. Chronic aspiration in children: evaluation of the lipid-laden macrophage index. Pediatr Pulmonol. Aug. 1999;28(2):94-100. X-4. [pmid: 10423308].
398 Bustorff-Silva J, Fonkalsrud EW, Perez CA, et al. Gastric emptying procedures decrease the risk of postoperative recurrent reflux in children with delayed gastric emptying. J Pediatr Surg. Jan. 1999;34(1):79-82. discussion -3. X-3, X-4, X-5. [pmid: 10022148].
399 Carrau RL, Pou A, Eibling DE, et al. Laryngeal framework surgery for the management of aspiration. Head Neck. Mar. 1999;21(2):139-45. X-3, X-4. [pmid: 10091982].
400 Chan AK. Nutrition concerns in children diagnosed with cerebral palsy. Support Line. 1999;21(6):11-6. X-1, X-4, X-5.
401 Chang SD, Lopez JR, Steinberg GK. The usefulness of electrophysiological monitoring during resection of central nervous system vascular malformations. J Stroke Cerebrovasc Dis. November -December. 1999;8(6):412-22. X-3, X-4, X-5. [pmid: 17895195].
402 Cohen Z, Fishman S, Yulevich A, et al. Nissen fundoplication and Boix-Ochoa antireflux procedure: comparison between two surgical techniques in the treatment of gastroesophageal reflux in children. Eur J Pediatr Surg. Oct. 1999;9(5):289-93. X-3. [pmid: 10584185].
403 Dall'Oglio I, Cianchi D, Somma R. PEGS in children: nursing considerations. Gastroenterol Nurs. Mar-Apr. 1999;22(2):47-51. X-1. [pmid: 10382411].
404 Danielson PD, Emmens RW. Esophagogastric disconnection for gastroesophageal reflux in children with severe neurological impairment. J Pediatr Surg. Jan. 1999;34(1):84-6. discussion 7. X-3, X-4, X-5. [pmid: 10022149].
405 Darwish H. Living with cerebral palsy and tube feeding: easier to feed but at what cost?. J Pediatr. Sep. 1999;135(3):272-3. X-1, X-3, X-4, X-5. [pmid: 10484786].
406 Duncan B, Barton LL, Lloyd J, et al. Dietary considerations in osteopenia in tube-fed nonambulatory children with cerebral palsy. Clin Pediatr (Phila). Mar. 1999;38(3):133-7. X-4, X-5. [pmid: 10349077].
407 Esmailian F, Dox H, Sadeghi A, et al. Retrograde cerebral perfusion as an adjunct to prolonged hypothermic circulatory arrest. Chest. Oct. 1999;116(4):887-91. X-3, X-4. [pmid: 10531148].
408 Fonkalsrud EW, Bustorff-Silva J, Perez CA, et al. Antireflux surgery in children under 3 months of age. J Pediatr Surg. Apr. 1999;34(4):527-31. X-3, X-4, X-5. [pmid: 10235314].
409 Gauderer MW. Gastrostomy button conversion into a combined gastric and jejunal access device. J Pediatr Surg. Jan. 1999;34(1):202-3. X-3, X-4, X-5. [pmid: 10022172].
410 Ghika J, Ghika-Schmid F, Fankhauser H, et al. Bilateral contemporaneous posteroventral pallidotomy for the treatment of Parkinson's disease: neuropsychological and neurological side effects. Report of four cases and review of the literature. J Neurosurg. Aug. 1999;91(2):313-21. X-3. [pmid: 10433321].
411 Heikenen JB, Werlin SL, Brown CW. Electrogastrography in gastrostomy-tube-fed children. Dig Dis Sci. Jul. 1999;44(7):1293-7. X-3, X-4, X-5. [pmid: 10489908].
412 Hermann RP, Phalangas AC, Mahoney RM, et al. Powered feeding devices: an evaluation of three models. Arch Phys Med Rehabil. Oct. 1999;80(10):1237-42. X-5. [pmid: 10527080].
413 Hoffer EK, Cosgrove JM, Levin DQ, et al. Radiologic gastrojejunostomy and percutaneous endoscopic gastrostomy: a prospective, randomized comparison. J Vasc Interv Radiol. Apr. 1999;10(4):413-20. X-3, X-4, X-5. [pmid: 10229468].
414 Hogan SE. Knee height as a predictor of recumbent length for individuals with mobility-impaired cerebral palsy. J Am Coll Nutr. Apr. 1999;18(2):201-5. X-4. [pmid: 10204839].
415 Kawame H, Hannibal MC, Hudgins L, et al. Phenotypic spectrum and management issues in Kabuki syndrome. J Pediatr. Apr. 1999;134(4):480-5. X-3, X-4. [pmid: 10190924].
416 Kirshblum S, Johnston MV, Brown J, et al. Predictors of dysphagia after spinal cord injury. Arch Phys Med Rehabil. Sep. 1999;80(9):1101-5. X-3, X-4. [pmid: 10489016].
417 Lipton GE, Miller F, Dabney KW, et al. Factors predicting postoperative complications following spinal fusions in children with cerebral palsy. J Spinal Disord. Jun. 1999;12(3):197-205. X-3, X-4, X-5. [pmid: 10382772].
418 Mujica VR, Conklin J. When it's hard to swallow. What to look for in patients with dysphagia. Postgrad Med. Jun. 1999;105(7):131-4. 41. 2. 45. X-1. [pmid: 10376055].
419 Nakao FS, Brant CQ, Stanich P, et al. Nutritional status improvement in neurologically impaired patients by percutaneous endoscopic gastrostomy feeding. Arq Gastroenterol. Jul-Sep. 1999;36(3):148-53. X-3, X-4, X-5. [pmid: 10751902].
420 Nuttin B, Ivanhoe C, Albright L, et al. Intrathecal baclofen therapy for spasticity of cerebral origin: cerebral palsy and brain injury. Neuromodulation. Apr. 1999;2(2):120-32. X-1, X-4. [pmid: 22151115].
421 Paulsen RD, Steinberg GK, Norbash AM, et al. Embolization of rolandic cortex arteriovenous malformations. Neurosurgery. Mar. 1999;44(3):479-84. discussion 84-6. X-3, X-4. [pmid: 10069584].
422 Reid D, Rigby P, Ryan S. Functional impact of a rigid pelvic stabilizer on children with cerebral palsy who use wheelchairs: users' and caregivers' perceptions. Pediatr Rehabil. Jul-Sep. 1999;3(3):101-18. X-4. [pmid: 10797887].
423 Schroter-Morasch H, Bartolome G, Troppmann N, et al. Values and limitations of pharyngolaryngoscopy (transnasal, transoral) in patients with dysphagia. Folia Phoniatr Logop. Jul-Oct. 1999;51(4-5):172-82. X-3. [pmid: 10450024].
424 Smith SW, Camfield C, Camfield P. Living with cerebral palsy and tube feeding: A population-based follow-up study. J Pediatr. Sep. 1999;135(3):307-10. X-5. [pmid: 10484794].
425 Sullivan PB. Gastrostomy feeding in the disabled child: when is an antireflux procedure required?. Arch Dis Child. Dec. 1999;81(6):463-4. X-1, X-3, X-4, X-5. [pmid: 10569957].
426 Topping MJ, Smith JK. The development of handy 1. a robotic system to assist the severely disabled. Technol Disabil. 1999;10(2):95-105. X-1, X-3, X-4, X-5.
427 The Tri-Joint Congress 2000 “Forging Ahead Together.” Metro Toronto Convention Centre. Toronto, Ontario. May 24-27 mai, 2000. Physiotherapy Canada. 2000;52:S1-149. X-11.
428 Ahsan SF, Meleca RJ, Dworkin JP. Botulinum toxin injection of the cricopharyngeus muscle for the treatment of dysphagia. Otolaryngol Head Neck Surg. May. 2000;122(5):691-5. X-4. [pmid: 10793348].
429 Andren E, Grimby G. Dependence and perceived difficulty in activities of daily living in adults with cerebral palsy and spina bifida. Disabil Rehabil. May. 10. 2000;22(7):299-307. X-4. [pmid: 10877483].
430 Aviv JE, Liu H, Parides M, et al. Laryngopharyngeal sensory deficits in patients with laryngopharyngeal reflux and dysphagia. Ann Otol Rhinol Laryngol. Nov. 2000;109(11):1000-6. X-3, X-4. [pmid: 11089989].
431 Benoit D, Wang EE, Zlotkin SH. Discontinuation of enterostomy tube feeding by behavioral treatment in early childhood: a randomized controlled trial. J Pediatr. Oct. 2000;137(4):498-503. X-3, X-4, X-5. [pmid: 11035828].
432 Bohmer CJ, Klinkenberg-Knol EC, Niezen-de Boer MC, et al. Gastroesophageal reflux disease in intellectually disabled individuals: how often, how serious, how manageable?. Am J Gastroenterol. Aug. 2000;95(8):1868-72. X-1, X-4. [pmid: 10950028].
433 Brooks A, Millar AJ, Rode H. The surgical management of cricopharyngeal achalasia in children. Int J Pediatr Otorhinolaryngol. Nov. 30. 2000;56(1):1-7. X-3, X-4. [pmid: 11074110].
434 Center on Disability Studies UoHiaM, University of Texas, Society for DisabilityStudies. Disabil Stud Q. 2000;20(1):1-82. X-9.
435 Dall'Oglio L, Gatti C, Villa M, et al. A new and successful chance in surgical treatment of gastrooesophageal reflux in severely neurologically impaired children: Bianchi's procedure. Eur J Pediatr Surg. Oct. 2000;10(5):291-4. X-3. [pmid: 11194538].
436 Deschler DG, Doherty ET, Reed CG, et al. Prevention of pharyngoesophageal spasm after laryngectomy with a half-muscle closure technique. Ann Otol Rhinol Laryngol. May. 2000;109(5):514-8. X-3, X-4. [pmid: 10823483].
437 Gisel EG, Alphonce E, Ramsay M. Assessment of ingestive and oral praxis skills: children with cerebral palsy vs. controls. Dysphagia. Fall. 2000;15(4):236-44. X-4, X-5. [pmid: 11014887].
438 Gonzalez L, Nazario CM, Gonzalez MJ. Nutrition-related problems of pediatric patients with neuromuscular disorders. P R Health Sci J. Mar. 2000;19(1):35-8. X-4. [pmid: 10761203].
439 Hartnick CJ, Hartley BE, Miller C, et al. Pediatric fiberoptic endoscopic evaluation of swallowing. Ann Otol Rhinol Laryngol. Nov. 2000;109(11):996-9. X-3, X-4, X-5. [pmid: 11089988].
440 Hassall E, Israel D, Shepherd R, et al. Omeprazole for treatment of chronic erosive esophagitis in children: a multicenter study of efficacy, safety, tolerability and dose requirements. International Pediatric Omeprazole Study Group. J Pediatr. Dec. 2000;137(6):800-7. X-4. [pmid: 11113836].
441 Huerta G, Puri VK. Nasoenteric feeding tubes in critically ill patients (fluoroscopy versus blind). Nutrition. Apr. 2000;16(4):264-7. X-3, X-4, X-5. [pmid: 10758361].
442 Inge K, Strobel W, Wehman P, et al. Vocational outcomes for persons with severe physical disabilities: design and implementation of workplace supports. NeuroRehabilitation. 2000;15(2):175-87. X-4. [pmid: 11455094].
443 Mattson MP. Emerging neuroprotective strategies for Alzheimer's disease: dietary restriction, telomerase activation, and stem cell therapy. Exp Gerontol. Jul. 2000;35(4):489-502. X-1. [pmid: 10959037].
444 Mitchell SL, Berkowitz RE, Lawson FM, et al. A cross-national survey of tube-feeding decisions in cognitively impaired older persons. J Am Geriatr Soc. Apr. 2000;48(4):391-7. X-3, X-4, X-5. [pmid: 10798465].
445 Mooney JF 3rd. Perioperative enteric nutritional supplementation in pediatric patients with neuromuscular scoliosis. J South Orthop Assoc. Fall. 2000;9(3):202-6. X-3, X-4. [pmid: 12135303].
446 Morton RE, Pinnington L, Ellis RE. Air swallowing in Rett syndrome. Dev Med Child Neurol. Apr. 2000;42(4):271-5. X-1, X-3, X-4. [pmid: 10795567].
447 Munro N. Pulmonary challenges in neurotrauma. Crit Care Nurs Clin North Am. Dec. 2000;12(4):457-64. X-1. [pmid: 11855249].
448 Nwe TT, Singh B. Management of pain in peritonsillar abscess. J Laryngol Otol. Oct. 2000;114(10):765-7. X-3, X-4. [pmid: 11127146].
449 Palmer JB, Drennan JC, Baba M. Evaluation and treatment of swallowing impairments. Am Fam Physician. Apr. 15. 2000;61(8):2453-62. X-1. [pmid: 10794585].
450 Puntis JW, Thwaites R, Abel G, et al. Children with neurological disorders do not always need fundoplication concomitant with percutaneous endoscopic gastrostomy. Dev Med Child Neurol. Feb. 2000;42(2):97-9. X-3, X-5. [pmid: 10698326].
451 Rogers B, Wood K, Almeida J, et al. Feeding method and growth of children with cerebral palsy. Dev Med Child Neurol Suppl. 2000;42. Suppl 83. abstract E:1. X-4.
452 Socrates C, Grantham-McGregor SM, Harknett SG, et al. Poor nutrition is a serious problem in children with cerebral palsy in Palawan, the Philippines. Int J Rehabil Res. Sep. 2000;23(3):177-84. X-4. [pmid: 11131619].
453 Subramaniam R, Dickson AP. Long-term outcome of Boix-Ochoa and Nissen fundoplication in normal and neurologically impaired children. J Pediatr Surg. Aug. 2000;35(8):1214-6. X-3, X-5. [pmid: 10945696].
454 Sullivan PB, Lambert B, Rose M, et al. Prevalence and severity of feeding and nutritional problems in children with neurological impairment: Oxford Feeding Study. Dev Med Child Neurol. Oct. 2000;42(10):674-80. X-4. [pmid: 11085295].
455 Swanson M. School nursing and children: a challenge for each of us. Arkansas Nursing News. 2000;16(4):15. X-1, X-3, X-4, X-5.
456 Toder DS. Respiratory problems in the adolescent with developmental delay. Adolesc Med. Oct. 2000;11(3):617-31. X-1. [pmid: 11060558].
457 van Weissenbruch R, Kunnen M, Albers FW, et al. Cineradiography of the pharyngoesophageal segment in postlaryngectomy patients. Ann Otol Rhinol Laryngol. Mar. 2000;109(3):311-9. X-3, X-4. [pmid: 10737317].
458 Verrall TC, Berenbaum S, Chad KE, et al. Children with cerebral palsy: caregivers' nutrition knowledge, attitudes and beliefs. Can J Diet Pract Res. 2000;61(3):128-34. X-1, X-3, X-4. [pmid: 11551331].
459 Welch K, Pianta RC, Marvin RS, et al. Feeding interactions for children with cerebral palsy: Contributions of mothers' psychological state and children's skills and abilities. J Dev Behav Pediatr. Apr. 2000;21(2):123-9. X-4, X-5. [pmid: 10791480].
460 Willging JP. Benefit of feeding assessment before pediatric airway reconstruction. Laryngoscope. May. 2000;110(5 Pt 1):825-34. X-3, X-4, X-5. [pmid: 10807361].
461 Abstracts of poster and platform presentations at the 2002 Combined Sections Meeting. Pediatric Physical Therapy. 2001;13(4):190-214. X-11.
462 Academy Annual Assembly Abstracts: poster presentations. Arch Phys Med Rehabil. 2001;82(9):1298-343. X-11.
463 Detroit Institute for Children. Michigan Nurse. 2001;74(1):13. X-1, X-3, X-4, X-5.
464 Benoit D, Wang EE, Zlotkin SH. Characteristics and outcomes of children with enterostomy feeding tubes: A study of 325 children. Paediatr Child Health. Mar. 2001;6(3):132-7. X-4, X-5. [pmid: 20084224].
465 Blei AT, Cordoba J. Hepatic Encephalopathy. Am J Gastroenterol. Jul. 2001;96(7):1968-76. X-1. [pmid: 11467622].
466 Borasio GD, Voltz R, Miller RG. Palliative care in amyotrophic lateral sclerosis. Neurol Clin. Nov. 2001;19(4):829-47. X-1. [pmid: 11854102].
467 Cheung KM, Tse PW, Ko CH, et al. Clinical efficacy of proton pump inhibitor therapy in neurologically impaired children with gastroesophageal reflux: prospective study. Hong Kong Med J. Dec. 2001;7(4):356-9. X-3, X-4, X-5. [pmid: 11773669].
468 Chong SK. Gastrointestinal problems in the handicapped child. Curr Opin Pediatr. Oct. 2001;13(5):441-6. X-1, X-3, X-4, X-5. [pmid: 11801890].
469 Crysdale WS, Raveh E, McCann C, et al. Management of drooling in individuals with neurodisability: a surgical experience. Dev Med Child Neurol. Jun. 2001;43(6):379-83. X-4. [pmid: 11409826].
470 Day AS, Beasley SW, Meads A, et al. Morbidity associated with gastrostomy placement in children demands an ongoing integrated approach to care. N Z Med J. Apr. 13. 2001;114(1129):164-7. X-3, X-4, X-5. [pmid: 11400925].
471 Dehdashti AR, Muster M, Reverdin A, et al. Preoperative silk suture embolization of cerebral and dural arteriovenous malformations. Neurosurg Focus. 2001;11(5):e6. X-3, X-4. [pmid: 16466238].
472 Deswarte-Wallace J, Firouzbakhsh S, Finklestein JZ. Using research to change practice: enteral feedings for pediatric oncology patients. J Pediatr Oncol Nurs. Sep-Oct. 2001;18(5):217-23. X-3, X-4. [pmid: 11588762].
473 El-Mouzan MI, Abdullah AM, Al-Sanie AM, et al. Pattern of gastroesophageal reflux in children. Saudi Med J. May. 2001;22(5):419-22. X-3, X-4, X-5. [pmid: 11376384].
474 Engelhardt T, Strachan L, Johnston G. Aspiration and regurgitation prophylaxis in paediatric anaesthesia. Paediatr Anaesth. Mar. 2001;11(2):147-50. X-3, X-4. [pmid: 11240870].
475 Esposito C, Montupet P, Reinberg O. Laparoscopic surgery for gastroesophageal reflux disease during the first year of life. J Pediatr Surg. May. 2001;36(5):715-7. X-3. [pmid: 11329572].
476 Gangil A, Patwari AK, Aneja S, et al. Feeding problems in children with cerebral palsy. Indian Pediatr. Aug. 2001;38(8):839-46. X-5. [pmid: 11520994].
477 Gangil A, Patwari AK, Bajaj P, et al. Gastroesophageal reflux disease in children with cerebral palsy. Indian Pediatr. Jul. 2001;38(7):766-70. X-4, X-5. [pmid: 11463964].
478 Gatti C, di Abriola GF, Villa M, et al. Esophagogastric dissociation versus fundoplication: which is best for severely neurologically impaired children?. J Pediatr Surg. May. 2001;36(5):677-80. X-3. [pmid: 11329564].
479 Ghezzi A, Zaffaroni M. Neurological manifestations of gastrointestinal disorders, with particular reference to the differential diagnosis of multiple sclerosis. Neurol Sci. Nov. Suppl 2. 2001;22:S117-22. X-1. [pmid: 11794474].
480 Gormley ME Jr., Krach LE, Piccini L. Spasticity management in the child with spastic quadriplegia. Eur J Neurol. Nov. Suppl 5. 2001;8:127-35. X-4. [pmid: 11851741].
481 Govender S, Parbhoo AH, Kumar KP, et al. Anterior spinal decompression in HIV-positive patients with tuberculosis. A prospective study. J Bone Joint Surg Br. Aug. 2001;83(6):864-7. X-3, X-4. [pmid: 11521930].
482 Haapaniemi JJ, Laurikainen EA, Pulkkinen J, et al. Botulinum toxin in the treatment of cricopharyngeal dysphagia. Dysphagia. Summer. 2001;16(3):171-5. X-3, X-4, X-5. [pmid: 11453562].
483 Lafullarde T, Watson DI, Jamieson GG, et al. Laparoscopic Nissen fundoplication: five-year results and beyond. Arch Surg. Feb. 2001;136(2):180-4. X-3, X-4. [pmid: 11177138].
484 Lakin C, Braddock D, Smith G. Trends and milestones: Large state residential facilities: Status and trends in population characteristics as of June 30, 2000. Ment Retard. 2001;39(4):334-7. X-1, X-3, X-4, X-5. [pmid: 11499383].
485 Lambert AW, Huddart SN. Mesh hiatal reinforcement in Nissen fundoplication. Pediatr Surg Int. Jul. 2001;17(5-6):491-2. X-3, X-4, X-5. [pmid: 11527201].
486 Lewin JS, Bishop-Leone JK, Forman AD, et al. Further experience with Botox injection for tracheoesophageal speech failure. Head Neck. Jun. 2001;23(6):456-60. X-3, X-4. [pmid: 11360306].
487 Lifschitz CH. Feeding problems in infants and children. Curr Treat Options Gastroenterol. Oct. 2001;4(5):451-7. X-1, X-3, X-4, X-5. [pmid: 11560792].
488 Lloyd Faulconbridge RV, Tranter RM, Moffat V, et al. Review of management of drooling problems in neurologically impaired children: a review of methods and results over 6 years at Chailey Heritage Clinical Services. Clin Otolaryngol Allied Sci. Apr. 2001;26(2):76-81. X-4. [pmid: 11309045].
489 Lock G. Physiology and pathology of the oesophagus in the elderly patient. Best Pract Res Clin Gastroenterol. Dec. 2001;15(6):919-41. X-1. [pmid: 11866485].
490 Nelson M, WT R, Vasan U, S J, Comiskey E, MR P, et al. One-year outcome of auditory-tactile-visual-vestibular intervention in the neonatal intensive care unit: effects of severe prematurity and central nervous system injury. J Child Neurol. 2001;16(7):493-8. X-3, X-4, X-5. [pmid: 11453445].
491 Muller T, Schroder R, Zierz S. GCG repeats and phenotype in oculopharyngeal muscular dystrophy. Muscle Nerve. Jan. 2001;24(1):120-2. X-3, X-4. [pmid: 11150975].
492 Pashankar D, Blair GK, Israel DM. Omeprazole maintenance therapy for gastroesophageal reflux disease after failure of fundoplication. J Pediatr Gastroenterol Nutr. Feb. 2001;32(2):145-9. X-3, X-4, X-5. [pmid: 11321383].
493 Richards CA, Milla PJ, Andrews PL, et al. Retching and vomiting in neurologically impaired children after fundoplication: predictive preoperative factors. J Pediatr Surg. Sep. 2001;36(9):1401-4. X-3, X-4, X-5. [pmid: 11528615].
494 Sasaki M, Iwata H, Sugai K, et al. A severely brain-damaged case of 3-hydroxyisobutyric aciduria. Brain Dev. Jul. 2001;23(4):243-5. X-3, X-4. [pmid: 11377004].
495 Sayre JM, Pianta RC, Marvin RS, et al. Mothers' representations of relationships with their children: relations with mother characteristics and feeding sensitivity. J Pediatr Psychol. Sep. 2001;26(6):375-84. X-3, X-4. [pmid: 11490040].
496 Schuster JM, Grady MS. Medical management and adjuvant therapies in spinal metastatic disease. Neurosurg Focus. Dec. 15. 2001;11(6):e3. X-1. [pmid: 16463995].
497 Senders CW, Navarrete EG. Laser supraglottoplasty for laryngomalacia: are specific anatomical defects more influential than associated anomalies on outcome?. Int J Pediatr Otorhinolaryngol. Mar. 2001;57(3):235-44. X-3, X-4, X-5. [pmid: 11223456].
498 Suskind DL, Zeringue GP 3rd, Kluka EA, et al. Gastroesophageal reflux and pediatric otolaryngologic disease: the role of antireflux surgery. Arch Otolaryngol Head Neck Surg. May. 2001;127(5):511-4. X-3. [pmid: 11346425].
499 Thomson JD, Banta JV. Scoliosis in cerebral palsy: an overview and recent results. J Pediatr Orthop B. Jan. 2001;10(1):6-9. X-4. [pmid: 11269813].
500 Toynton SC, Saunders MW, Bailey CM. Aryepiglottoplasty for laryngomalacia: 100 consecutive cases. J Laryngol Otol. Jan. 2001;115(1):35-8. X-3, X-4, X-5. [pmid: 11233619].
501 Trauner DA, Fahmy RF, Mishler DA. Oral motor dysfunction and feeding difficulties in nephropathic cystinosis. Pediatr Neurol. May. 2001;24(5):365-8. X-3, X-4, X-5. [pmid: 11516611].
502 Troughton KE, Hill AE. Relation between objectively measured feeding competence and nutrition in children with cerebral palsy. Dev Med Child Neurol. Mar. 2001;43(3):187-90. X-3, X-4. [pmid: 11263689].
503 Walker P. Management of pressure ulcers. Oncology (Williston Park). Nov. 2001;15(11):1499-508. 511. discussion511, 515-6. X-1. [pmid: 11758876].
504 Wilson L, Oliva-Hemker M. Percutaneous endoscopic gastrostomy in small medically complex infants. Endoscopy. May. 2001;33(5):433-6. X-3, X-4, X-5. [pmid: 11396762].
505 Wilson RF, Dente C, Tyburski JG. The nutritional management of patients with head injuries. Neurol Res. Mar-Apr. 2001;23(2-3):121-8. X-1. [pmid: 11320590].
506 Zainah SH, Ong LC, Sofiah A, et al. Determinants of linear growth in Malaysian children with cerebral palsy. J Paediatr Child Health. Aug. 2001;37(4):376-81. X-4. [pmid: 11532058].
507 2002 Academy Annual Assembly Abstracts [corrected]. [published erratum appears in Arch phys med rehabil 2002 Dec;83(12):1807]. 63rd Annual Assembly of the American Academy of Physical Medicine and Rehabilitation in conjunction with the American Hospital Section for Long-Term Care and Rehabilitation and the American Medical Rehabilitation Providers Association in Orlando, FL. November 21-24, 2002. Arch Phys Med Rehabil. 2002;83(11):1641-92. X-11.
508 26th Clinical Congress at Nutrition Week: abstracts. JPEN Journal of Parenteral & Enteral Nutrition. 2002;26(4):S1-33. X-11. [pmid: 12675049].
509 European Academy of Childhood Disability Annual Meeting 2002. 24-26th October. Dev Med Child Neurol. 2002;44:3-58. X-11.
510 Proceedings of Nutrition Society: abstracts of original communications: a joint meeting of the Clinical Nutrition and Metabolism Group of the Nutrition Society and the British Association for Parenteral and Enteral Nutrition. Harrogate International Centre. 13-15 November 2001. Proceedings of the Nutrition Society. 2002;61:2A-38a. X-11, X-1, X-4, X-5.
511 Abell TL, Minocha A. Gastroparesis and the gastric pacemaker: a revolutionary treatment for an old disease. J Miss State Med Assoc. Dec. 2002;43(12):369-75. X-3. [pmid: 12647496].
512 Allen JW, Ali A, Wo J, et al. Totally laparoscopic feeding jejunostomy. Surg Endosc. Dec. 2002;16(12):1802-5. X-4. [pmid: 12140624].
513 Ashorn M, Ruuska T, Karikoski R, et al. The natural course of gastroesophageal reflux disease in children. Scand J Gastroenterol. Jun. 2002;37(6):638-41. X-3, X-4. [pmid: 12126239].
514 Ayyangar R. Health maintenance and management in childhood disability. Phys Med Rehabil Clin N Am. Nov. 2002;13(4):793-821. X-1, X-4. [pmid: 12465561].
515 Burd RS, Price MR, Whalen TV. The role of protective antireflux procedures in neurologically impaired children: a decision analysis. J Pediatr Surg. Mar. 2002;37(3):500-6. X-1, X-3, X-4, X-5. [pmid: 11877676].
516 Carr LJ. Management of cerebral palsy: the neurologist's view. Hosp Med. Oct. 2002;63(10):584-9. X-1. [pmid: 12422490].
517 Cyrkiel D. Why I became a pediatric nurse practitioner: PNP opportunities in Las Vegas are on the rise. Nevada RNformation. 2002;11(2):13. X-1, X-3, X-4, X-5.
518 Dickerson RN, Brown RO, Hanna DL, et al. Validation of a new method for estimating resting energy expenditure of non-ambulatory tube-fed patients with severe neurodevelopmental disabilities. Nutrition. Jul-Aug. 2002;18(7-8):578-82. X-4. [pmid: 12093433].
519 El-Serag HB, Bailey NR, Gilger M, et al. Endoscopic manifestations of gastroesophageal reflux disease in patients between 18 months and 25 years without neurological deficits. Am J Gastroenterol. Jul. 2002;97(7):1635-9. X-3, X-4. [pmid: 12135011].
520 Fung EB, Samson-Fang L, Stallings VA, et al. Feeding dysfunction is associated with poor growth and health status in children with cerebral palsy. J Am Diet Assoc. Mar. 2002;102(3):361-73. X-4, X-5. [pmid: 11902369].
521 Georgeson K. Results of laparoscopic antireflux procedures in neurologically normal infants and children. Semin Laparosc Surg. Sep. 2002;9(3):172-6. X-3. [pmid: 12407526].
522 Godbole P, Margabanthu G, Crabbe DC, et al. Limitations and uses of gastrojejunal feeding tubes. Arch Dis Child. Feb. 2002;86(2):134-7. X-3, X-5. [pmid: 11827911].
523 Graham GD. Arteriovenous Malformations in the Brain. Curr Treat Options Neurol. Nov. 2002;4(6):435-44. X-1, X-3, X-4. [pmid: 12354370].
524 Henderson RC, Lark RK, Kecskemethy HH, et al. Bisphosphonates to treat osteopenia in children with quadriplegic cerebral palsy: a randomized, placebo-controlled clinical trial. J Pediatr. Nov. 2002;141(5):644-51. X-4. [pmid: 12410192].
525 Hirschl RB, Yardeni D, Oldham K, et al. Gastric transposition for esophageal replacement in children: experience with 41 consecutive cases with special emphasis on esophageal atresia. Ann Surg. Oct. 2002;236(4):531-9. discussion 9-41. X-3, X-4, X-5. [pmid: 12368682].
526 Kawahara H, Nakajima K, Yagi M, et al. Mechanisms responsible for recurrent gastroesophageal reflux in neurologically impaired children who underwent laparoscopic Nissen fundoplication. Surg Endosc. May. 2002;16(5):767-71. X-4, X-5. [pmid: 11997818].
527 Kotwicki T, Szulc A. Curvature of the spine in children with cerebral palsy. Ortop Traumatol Rehabil. Jan. 31. 2002;4(1):42-7. X-4. [pmid: 17679900].
528 Lin LC, Wu SC, Chen HS, et al. Prevalence of impaired swallowing in institutionalized older people in taiwan. J Am Geriatr Soc. Jun. 2002;50(6):1118-23. X-3, X-4. [pmid: 12110075].
529 Lips J, de Haan P, de Jager SW, et al. The role of transcranial motor evoked potentials in predicting neurologic and histopathologic outcome after experimental spinal cord ischemia. Anesthesiology. Jul. 2002;97(1):183-91. X-3, X-4. [pmid: 12131121].
530 Logan LR. Facts and myths about therapeutic interventions in cerebral palsy: integrated goal development. Phys Med Rehabil Clin N Am. Nov. 2002;13(4):979-89. X-1, X-3, X-4, X-5. [pmid: 12465570].
531 Mattioli G, Esposito C, Lima M, et al. Italian multicenter survey on laparoscopic treatment of gastro-esophageal reflux disease in children. Surg Endosc. Dec. 2002;16(12):1666-8. X-3, X-5. [pmid: 12232652].
532 Mattioli G, Repetto P, Carlini C, et al. Laparoscopic vs open approach for the treatment of gastroesophageal reflux in children. Surg Endosc. May. 2002;16(5):750-2. X-3, X-4. [pmid: 11997815].
533 Menon KV, Booth M, Stratford J, et al. Laparoscopic fundoplication in mentally normal children with gastroesophageal reflux disease. Dis Esophagus. 2002;15(2):163-6. X-3. [pmid: 12220426].
534 Miele E, Staiano A, Tozzi A, et al. Clinical response to amino acid-based formula in neurologically impaired children with refractory esophagitis. J Pediatr Gastroenterol Nutr. Sep. 2002;35(3):314-9. X-5. [pmid: 12352519].
535 Montupet P. Laparoscopic Toupet's fundoplication in children. Semin Laparosc Surg. Sep. 2002;9(3):163-7. X-3, X-5. [pmid: 12407524].
536 Motion S, Northstone K, Emond A, et al. Early feeding problems in children with cerebral palsy: weight and neurodevelopmental outcomes. Dev Med Child Neurol. Jan. 2002;44(1):40-3. X-4. [pmid: 11811650].
537 Norrashidah AW, Henry RL. Fundoplication in children with gastro-oesophageal reflux disease. J Paediatr Child Health. Apr. 2002;38(2):156-9. X-3. [pmid: 12030997].
538 Olrick JT, Pianta RC, Marvin RS. Mother's and father's responses to signals of children with cerebral palsy during feeding. J Dev Phys Disabil. Mar. 2002;14(1):1-17. X-4, X-5.
539 Onari K, Kondo S, Mihara H, et al. Combined anterior-posterior fusion for cervical spondylotic myelopathy in patients with athetoid cerebral palsy. J Neurosurg. Jul. 2002;97(1 Suppl):13-9. X-4. [pmid: 12120637].
540 Oyama H, Ikeda A, Inoue S, et al. Local injection of botulinum toxin type A for hemifacial spasm. Neurol Med Chir (Tokyo). Jun. 2002;42(6):245-8. discussion 8-9. X-4. [pmid: 12116529].
541 Parameswaran MS, Soliman AM. Endoscopic botulinum toxin injection for cricopharyngeal dysphagia. Ann Otol Rhinol Laryngol. Oct. 2002;111(10):871-4. X-4. [pmid: 12389853].
542 Pimpalwar A, Najmaldin A. Results of laparoscopic antireflux procedures in neurologically impaired children. Semin Laparosc Surg. Sep. 2002;9(3):190-6. X-3, X-4, X-5. [pmid: 12407529].
543 Razeghi S, Lang T, Behrens R. Influence of percutaneous endoscopic gastrostomy on gastroesophageal reflux: a prospective study in 68 children. J Pediatr Gastroenterol Nutr. 2002;35(1):27-30. X-3, X-5. [pmid: 12142806].
544 Rodriguez RF, Contreras N. Bilateral motor cortex stimulation for the relief of central dysesthetic pain and intentional tremor secondary to spinal cord surgery: a case report. Neuromodulation. Oct. 2002;5(4):189-95. X-3, X-4. [pmid: 22150846].
545 Rosen CL, Ammerman JM, Sekhar LN, et al. Outcome analysis of preoperative embolization in cranial base surgery. Acta Neurochir (Wien). Nov. 2002;144(11):1157-64. X-3, X-4. [pmid: 12434172].
546 Rothenberg SS. Laparoscopic Nissen procedure in children. Semin Laparosc Surg. Sep. 2002;9(3):146-52. X-1. [pmid: 12407522].
547 Samson-Fang L, Fung E, Stallings VA, et al. Relationship of nutritional status to health and societal participation in children with cerebral palsy. J Pediatr. Nov. 2002;141(5):637-43. X-4, X-5. [pmid: 12410191].
548 Samuel M, Holmes K. Quantitative and qualitative analysis of gastroesophageal reflux after percutaneous endoscopic gastrostomy. J Pediatr Surg. Feb. 2002;37(2):256-61. X-3. [pmid: 11819210].
549 Schier F. Indications for laparoscopic antireflux procedures in children. Semin Laparosc Surg. Sep. 2002;9(3):139-45. X-1. [pmid: 12407521].
550 Sullivan PB, Juszczak E, Lambert BR, et al. Impact of feeding problems on nutritional intake and growth: Oxford Feeding Study II. Dev Med Child Neurol. Jul. 2002;44(7):461-7. X-3, X-4, X-5. [pmid: 12162383].
551 Tan S, Wulkan ML. Minimally invasive surgical techniques in reoperative surgery for gastroesophageal reflux disease in infants and children. Am Surg. Nov. 2002;68(11):989-92. X-3, X-4, X-5. [pmid: 12455792].
552 Thomson M, Del Buono R, Wenzl TG. Acid and non-acid gastro-oesophageal reflux in neurologically impaired children. Arch Dis Child. 2002;86:A21. X-3, X-4, X-5.
553 Thomson MA, Carver AD, Sloan RL. Percutaneous endoscopic gastrostomy feeding in a district rehabilitation service. Clin Rehabil. Mar. 2002;16(2):215-20. X-3, X-4, X-5. [pmid: 11911520].
554 Tomicic JT, Luks FI, Shalon L, et al. Laparoscopic gastrostomy in infants and children. Eur J Pediatr Surg. Apr. 2002;12(2):107-10. X-3, X-4, X-5. [pmid: 12015654].
555 Vintro AQ, Krasnoff JB, Painter P. Roles of nutrition and physical activity in musculoskeletal complications before and after liver transplantation. AACN Clin Issues. May. 2002;13(2):333-47. X-3. [pmid: 12011603].
556 Wadie GM, Lobe TE. Gastroesophageal reflux disease in neurologically impaired children: the role of the gastrostomy tube. Semin Laparosc Surg. Sep. 2002;9(3):180-9. X-3. [pmid: 12407528].
557 Wales PW, Diamond IR, Dutta S, et al. Fundoplication and gastrostomy versus image-guided gastrojejunal tube for enteral feeding in neurologically impaired children with gastroesophageal reflux. J Pediatr Surg. Mar. 2002;37(3):407-12. X-3. [pmid: 11877658].
558 Wongprasartsuk P, Stevens J. Cerebral palsy and anaesthesia. Paediatr Anaesth. May. 2002;12(4):296-303. X-1, X-3, X-4, X-5. [pmid: 11982834].
559 Abstracts of the Royal College of Paediatrics and Child Health. 7th Spring Meeting. University of York. 7-10 April 2003. Arch Dis Child. 2003;88:A1-75. X-11.
560 American Academy for Cerebral Palsy & Developmental Medicine 2003. Dev Med Child Neurol. 2003;45:1-54. X-11.
561 European Academy of Childhood Disability Annual Meeting 2003. 2-4th October. Dev Med Child Neurol. 2003;45:1-65. X-11.
562 Nutrition Week 2003 scientific abstracts. JPEN Journal of Parenteral & Enteral Nutrition 2003. Jan-Feb. 2003;27(1):S1-41. X-11.
563 Angus F, Burakoff R. The percutaneous endoscopic gastrostomy tube. Medical and ethical issues in placement. Am J Gastroenterol. Feb. 2003;98(2):272-7. X-1, X-3, X-4. [pmid: 12591040].
564 Bank N, Le D, Fabrizio M. The Precision Teaching of Food Acceptance to a Child with Cerebral Palsy. Journal of Precision Teaching & Celeration. 2003;19(2):35-6. X-1, X-4.
565 Bjornson KF, McLaughlin JF, Loeser JD, et al. Oral motor, communication, and nutritional status of children during intrathecal baclofen therapy: a descriptive pilot study. Arch Phys Med Rehabil. Apr. 2003;84(4):500-6. X-4, X-5. [pmid: 12690587].
566 Bourne MC, Wheeldon C, MacKinlay GA, et al. Laparoscopic Nissen fundoplication in children: 2-5-year follow-up. Pediatr Surg Int. Sep. 2003;19(7):537-9. X-3, X-4, X-5. [pmid: 13680291].
567 Craig GM, Scambler G, Spitz L. Why parents of children with neurodevelopmental disabilities requiring gastrostomy feeding need more support. Dev Med Child Neurol. Mar. 2003;45(3):183-8. X-3, X-4. [pmid: 12613775].
568 de Luis DA, Aller R, de Luis J, et al. Clinical and biochemical characteristics of patients with home enteral nutrition in an area of Spain. Eur J Clin Nutr. Apr. 2003;57(4):612-5. X-3, X-4. [pmid: 12700624].
569 DeLuca SC, Echols K, Ramey SL, et al. Pediatric constraint-induced movement therapy for a young child with cerebral palsy: Two episodes of care. Phys Ther. 2003;83(11):1003-13. X-3. [pmid: 14577827].
570 Dickerson RN, Brown RO, Hanna DL, et al. Energy requirements of non-ambulatory, tube-fed adult patients with cerebral palsy and chronic hypothermia. Nutrition. Sep. 2003;19(9):741-6. X-3, X-4, X-5. [pmid: 12921883].
571 Dittmar M, Spruss T, Schuierer G, et al. External carotid artery territory ischemia impairs outcome in the endovascular filament model of middle cerebral artery occlusion in rats. Stroke. Sep. 2003;34(9):2252-7. X-3, X-4. [pmid: 12893948].
572 Esposito C, Van Der Zee DC, Settimi A, et al. Risks and benefits of surgical management of gastroesophageal reflux in neurologically impaired children. Surg Endosc. May. 2003;17(5):708-10. X-3, X-5. [pmid: 12616396].
573 Field D, Garland M, Williams K. Correlates of specific childhood feeding problems. J Paediatr Child Health. May-Jun. 2003;39(4):299-304. X-4. [pmid: 12755939].
574 Finestone HM, Greene-Finestone LS. Rehabilitation medicine: 2. Diagnosis of dysphagia and its nutritional management for stroke patients. CMAJ. Nov. 11. 2003;169(10):1041-4. X-1. [pmid: 14609974].
575 Gisel EG, Tessier MJ, Lapierre G, et al. Feeding management of children with severe cerebral palsy and eating impairment: an exploratory study. Phys Occup Ther Pediatr. 2003;23(2):19-44. X-4. [pmid: 12951786].
576 Goetz CG, Leurgans S, Lang AE, et al. Progression of gait, speech and swallowing deficits in progressive supranuclear palsy. Neurology. Mar. 25. 2003;60(6):917-22. X-3, X-4. [pmid: 12654953].
577 Jaillard SM, Pierrat V, Dubois A, et al. Outcome at 2 years of infants with congenital diaphragmatic hernia: a population-based study. Ann Thorac Surg. Jan. 2003;75(1):250-6. X-3, X-4. [pmid: 12537224].
578 Katz RT. Life expectancy for children with cerebral palsy and mental retardation: Implications for life care planning. NeuroRehabilitation. 2003;18(3):261-70. X-1, X-4, X-5. [pmid: 14530591].
579 Kawame H, Matsui M, Kurosawa K, et al. Further delineation of the behavioral and neurologic features in Costello syndrome. Am J Med Genet A. Apr. 1. 2003;118A(1):8-14. X-3, X-4. [pmid: 12605434].
580 Klose J, Heldwein W, Rafferzeder M, et al. Nutritional status and quality of life in patients with percutaneous endoscopic gastrostomy (PEG) in practice: prospective one-year follow-up. Dig Dis Sci. Oct. 2003;48(10):2057-63. X-3, X-4, X-5. [pmid: 14627355].
581 Koan TS. Bilobed wide neck posterior cerebral artery aneurysm associated with fusiform basilar aneurysm, subarachnoid hemorrhage and chronic renal failure. A case report. Interv Neuroradiol. Jun. 30. 2003;9(2):185-92. X-3, X-4. [pmid: 20591269].
582 Langer JC. The failed fundoplication. Semin Pediatr Surg. May. 2003;12(2):110-7. X-1. [pmid: 12728397].
583 Lipton GE, Letonoff EJ, Dabney KW, et al. Correction of sagittal plane spinal deformities with unit rod instrumentation in children with cerebral palsy. J Bone Joint Surg Am. Dec. 2003;85-A(12):2349-57. X-3, X-4, X-5. [pmid: 14668504].
584 Marik PE, Kaplan D. Aspiration pneumonia and dysphagia in the elderly. Chest. Jul. 2003;124(1):328-36. X-3. [pmid: 12853541].
585 Munro FD. Dysphagia in children: a paediatric surgical perspective. Int J Pediatr Otorhinolaryngol. Dec. Suppl 1. 2003;67:S103-5. X-1, X-3, X-4, X-5. [pmid: 14662178].
586 Mutaf O, Abasiyanik A, Karaca I, et al. Treatment of gastroesophageal reflux with a gastric tube cardioplasty. J Pediatr Surg. Apr. 2003;38(4):571-4. X-3, X-4, X-5. [pmid: 12677568].
587 Nath U, Ben-Shlomo Y, Thomson RG, et al. Clinical features and natural history of progressive supranuclear palsy: a clinical cohort study. Neurology. Mar. 25. 2003;60(6):910-6. X-3, X-4, X-5. [pmid: 12654952].
588 Orngreen MC, Zacho M, Hebert A, et al. Patients with severe muscle wasting are prone to develop hypoglycemia during fasting. Neurology. Oct. 14. 2003;61(7):997-1000. X-3, X-4. [pmid: 14557579].
589 Piskac P, Leypold J, Hnizdil L, et al. Patient with percutaneous endoscopic gastrostomy. Bratisl Lek Listy. 2003;104(2):51-3. X-3, X-4, X-5. [pmid: 12839211].
590 Powers CJ, Levitt MA, Tantoco J, et al. The respiratory advantage of laparoscopic Nissen fundoplication. J Pediatr Surg. Jun. 2003;38(6):886-91. X-3, X-4, X-5. [pmid: 12778386].
591 Saitua F, Acuna R, Herrera P. Percutaneous endoscopic gastrostomy: the technique of choice?. J Pediatr Surg. Oct. 2003;38(10):1512-5. X-3, X-4, X-5. [pmid: 14577077].
592 Samson-Fang L, Butler C, O'Donnell M. Effects of gastrostomy feeding in children with cerebral palsy: an AACPDM evidence report. Dev Med Child Neurol. 2003;45(6):415-26. X-10. [pmid: 12785443].
593 Schwartz S, Gisel EG, Clarke D, et al. Association of occlusion with eating efficiency in children with cerebral palsy and moderate eating impairment. J Dent Child (Chic). Jan-Apr. 2003;70(1):33-9. X-4, X-5. [pmid: 12762606].
594 Schwarz SM. Feeding disorders in children with developmental disabilities. Infants & Young Children: An Interdisciplinary Journal of Special Care Practices. 2003;16(4):317-30. X-1, X-4, X-5.
595 Spitz L, McLeod E. Gastroesophageal reflux. Semin Pediatr Surg. Nov. 2003;12(4):237-40. X-1. [pmid: 14655162].
596 St Peter SD, Swain JM. Achalasia: a comprehensive review. Surg Laparosc Endosc Percutan Tech. Aug. 2003;13(4):227-40. X-1. [pmid: 12960784].
597 Steyaert H, Al Mohaidly M, Lembo MA, et al. Long-term outcome of laparoscopic Nissen and Toupet fundoplication in normal and neurologically impaired children. Surg Endosc. Apr. 2003;17(4):543-6. X-3, X-4, X-5. [pmid: 12582764].
598 Takamizawa S, Tsugawa C, Nishijima E, et al. Laryngotracheal separation for intractable aspiration pneumonia in neurologically impaired children: experience with 11 cases. J Pediatr Surg. Jun. 2003;38(6):975-7. X-3. [pmid: 12778406].
599 Van Der Sluijs BM, Hoefsloot LH, Padberg GW, et al. Oculopharyngeal muscular dystrophy with limb girdle weakness as major complaint. J Neurol. Nov. 2003;250(11):1307-12. X-3, X-4. [pmid: 14648146].
600 Ward RM, Beachy JC. Neonatal complications following preterm birth. BJOG. Apr. Suppl 20. 2003;110:8-16. X-1, X-3, X-4. [pmid: 12763105].
601 Wenzl TG, Schneider S, Scheele F, et al. Effects of thickened feeding on gastroesophageal reflux in infants: a placebo-controlled crossover study using intraluminal impedance. Pediatrics. Apr. 2003;111(4 Pt 1):e355-9. X-3, X-5. [pmid: 12671151].
602 Wolf C, Meiners TH. Dysphagia in patients with acute cervical spinal cord injury. Spinal Cord. Jun. 2003;41(6):347-53. X-3, X-4. [pmid: 12746741].
603 Zangen T, Ciarla C, Zangen S, et al. Gastrointestinal motility and sensory abnormalities may contribute to food refusal in medically fragile toddlers. J Pediatr Gastroenterol Nutr. Sep. 2003;37(3):287-93. X-4. [pmid: 12960651].
604 Abstracts: European Congress of Epidemiology, Bridging Worlds. 8-11 September 2004. Porto, Portugal. Journal of Epidemiology & Community Health. 2004;58:iii. X-11.
605 American Academy for Cerebral Palsy & Developmental Medicine 2004. Dev Med Child Neurol. 2004;46:1-50. X-1, X-3, X-4, X-5, X-11.
606 Communications to the Fifth World Congress on Science and Football. Technical University of Lisbon, Portugal. 11-15 April 2003. Journal of Sports Sciences. 2004;22(6):483-593. X-11.
607 European Academy of Childhood Disability Annual Meeting 2004. 7-9th October. Dev Med Child Neurol. 2004;46:1-45. X-1, X-3, X-4, X-5, X-11.
608 Royal College of Paediatrics and Child Health, Proceedings of the 8th Spring Meeting. University of York. 29 March-1 April 2004. Arch Dis Child. 2004;89:A1-78. X-11.
609 Blumin JH, Pcolinsky DE, Atkins JP. Laryngeal findings in advanced Parkinson's disease. Ann Otol Rhinol Laryngol. Apr. 2004;113(4):253-8. X-3, X-4. [pmid: 15112966].
610 Bozkurt M, Tutuncuoglu S, Serdaroglu G, et al. Gastroesophageal reflux in children with cerebral palsy: efficacy of cisapride. J Child Neurol. Dec. 2004;19(12):973-6. X-4. [pmid: 15704873].
611 Breau LM, Camfield CS, McGrath PJ, et al. Risk factors for pain in children with severe cognitive impairments. Dev Med Child Neurol. Jun. 2004;46(6):364-71. X-4. [pmid: 15174527].
612 Brenn BR, Theroux MC, Dabney KW, et al. Clotting parameters and thromboelastography in children with neuromuscular and idiopathic scoliosis undergoing posterior spinal fusion. Spine (Phila Pa 1976). Aug. 1. 2004;29(15):E310-4. X-4. [pmid: 15284525].
613 Buratti S, Kamenwa R, Dohil R, et al. Esophagogastric disconnection following failed fundoplication for the treatment of gastroesophageal reflux disease (GERD) in children with severe neurological impairment. Pediatr Surg Int. Oct. 2004;20(10):786-90. X-4, X-5. [pmid: 15138781].
614 Caulton JM, Ward KA, Alsop CW, et al. A randomised controlled trial of standing programme on bone mineral density in non-ambulant children with cerebral palsy. Arch Dis Child. Feb. 2004;89(2):131-5. X-4. [pmid: 14736627].
615 Chiu MJ, Chang YC, Hsiao TY. Prolonged effect of botulinum toxin injection in the treatment of cricopharyngeal dysphagia: case report and literature review. Dysphagia. Winter. 2004;19(1):52-7. X-3. [pmid: 14745647].
616 Dabney KW, Miller F, Lipton GE, et al. Correction of sagittal plane spinal deformities with unit rod instrumentation in children with cerebral palsy. J Bone Joint Surg Am. Sep. Suppl 1. 2004;86-A(Pt 2):156-68. X-4. [pmid: 15466756].
617 Damignani R, Young NL, Cole WG, et al. Impairment and activity limitation associated with epiphyseal dysplasia in children. Arch Phys Med Rehabil. Oct. 2004;85(10):1647-52. X-4. [pmid: 15468025].
618 Du R, Young WL, Lawton MT. “Tangential” resection of medial temporal lobe arteriovenous malformations with the orbitozygomatic approach. Neurosurgery. Mar. 2004;54(3):645-51. discussion 51-2. X-3, X-4. [pmid: 15028139].
619 Duncan B, Barton L, Edmonds D, et al. Parental perceptions of the therapeutic effect from osteopathic manipulation or acupuncture in children with spastic cerebral palsy. Clin Pediatr (Phila). May. 2004;43(4):349-53. X-4. [pmid: 15118778].
620 El-Serag HB, Gilger M, Carter J, et al. Childhood GERD is a risk factor for GERD in adolescents and young adults. Am J Gastroenterol. May. 2004;99(5):806-12. X-3, X-4. [pmid: 15128341].
621 Harrington JW, Brand DA, Edwards KS. Seizure disorder as a risk factor for gastroesophageal reflux in children with neurodevelopmental disabilities. Clin Pediatr (Phila). Jul-Aug. 2004;43(6):557-62. X-3, X-4, X-5. [pmid: 15248009].
622 Henry SM. Discerning differences: gastroesophageal reflux and gastroesophageal reflux disease in infants. Adv Neonatal Care. Aug. 2004;4(4):235-47. X-1. [pmid: 15368216].
623 Howden CW. Management of acid-related disorders in patients with dysphagia. Am J Med. Sep. 6. Suppl 5A. 2004;117:44S-8S. X-1. [pmid: 15478852].
624 Islam S, Teitelbaum DH, Buntain WL, et al. Esophagogastric separation for failed fundoplication in neurologically impaired children. J Pediatr Surg. Mar. 2004;39(3):287-91. discussion -91. X-1, X-4. [pmid: 15017539].
625 Jan JE, Freeman RD. Melatonin therapy for circadian rhythm sleep disorders in children with multiple disabilities: What have we learned in the last decade?. Dev Med Child Neurol. Nov. 2004;46(11):776-82. X-4. [pmid: 15540640].
626 Jesch NK, Schmidt AI, Strassburg A, et al. Laparoscopic fundoplication in neurologically impaired children with percutaneous endoscopic gastrostomy. Eur J Pediatr Surg. Apr. 2004;14(2):89-92. X-3, X-5. [pmid: 15185153].
627 Kappelle LJ, Van Der Worp HB. Treatment or prevention of complications of acute ischemic stroke. Curr Neurol Neurosci Rep. Jan. 2004;4(1):36-41. X-3. [pmid: 14683626].
628 Karlberg N, Jalanko H, Perheentupa J, et al. Mulibrey nanism: clinical features and diagnostic criteria. J Med Genet. Feb. 2004;41(2):92-8. X-3, X-4. [pmid: 14757854].
629 Kawahara H, Okuyama H, Kubota A, et al. Can laparoscopic antireflux surgery improve the quality of life in children with neurologic and neuromuscular handicaps?. J Pediatr Surg. Dec. 2004;39(12):1761-4. X-3, X-4, X-5. [pmid: 15616922].
630 Kawai M, Kawahara H, Hirayama S, et al. Effect of baclofen on emesis and 24-hour esophageal pH in neurologically impaired children with gastroesophageal reflux disease. J Pediatr Gastroenterol Nutr. Mar. 2004;38(3):317-23. X-3, X-4, X-5. [pmid: 15076634].
631 Lima M, Bertozzi M, Ruggeri G, et al. Laparoscopic antireflux surgery in neurologically impaired children. Pediatr Surg Int. Feb. 2004;20(2):114-7. X-3, X-4, X-5. [pmid: 14986034].
632 Miyazaki Y, Iwai K, Matumura S, et al. Serial changes in independent sitting in adults with severe cerebral palsy. Int J Rehabil Res. Sep. 2004;27(3):233-5. X-3, X-4, X-5. [pmid: 15319694].
633 Morris C, Bartlett D. Gross Motor Function Classification System: impact and utility. Dev Med Child Neurol. Jan. 2004;46(1):60-5. X-1, X-3. [pmid: 14974650].
634 Patwardhan N, McHugh K, Drake D, et al. Gastroenteric fistula complicating percutaneous endoscopic gastrostomy. J Pediatr Surg. Apr. 2004;39(4):561-4. X-3, X-5. [pmid: 15065028].
635 Pollet S, Gottrand F, Vincent P, et al. Gastroesophageal reflux disease and Helicobacter pylori infection in neurologically impaired children: inter-relations and therapeutic implications. J Pediatr Gastroenterol Nutr. Jan. 2004;38(1):70-4. X-4. [pmid: 14676598].
636 Popovic V, Svetel M, Djurovic M, et al. Circulating and cerebrospinal fluid ghrelin and leptin: potential role in altered body weight in Huntington's disease. Eur J Endocrinol. Oct. 2004;151(4):451-5. X-3, X-4. [pmid: 15476444].
637 Redstone F, West JF. The importance of postural control for feeding. Pediatr Nurs. Mar-Apr. 2004;30(2):97-100. X-1, X-3, X-4, X-5. [pmid: 15185730].
638 Rogers B. Feeding method and health outcomes of children with cerebral palsy. J Pediatr. Aug. 2004;145(2 Suppl):S28-32. X-1, X-3, X-4, X-5. [pmid: 15292884].
639 Shim ML, Moshang T Jr., Oppenheim WL, et al. Is treatment with growth hormone effective in children with cerebral palsy?. Dev Med Child Neurol. Aug. 2004;46(8):569-71. X-4. [pmid: 15287249].
640 Sleigh G, Brocklehurst P. Gastrostomy feeding in cerebral palsy: a systematic review. Arch Dis Child. Jun. 2004;89(6):534-9. X-10. [pmid: 15155398].
641 Sleigh G, Sullivan PB, Thomas AG. Gastrostomy feeding versus oral feeding alone for children with cerebral palsy. Cochrane Database Syst Rev. 2004;(2):CD003943. X-10. [pmid: 15106226].
642 Strauss D, Ojdana K, Shavelle R, et al. Decline in function and life expectancy of older persons with cerebral palsy. NeuroRehabilitation. 2004;19(1):69-78. X-4, X-5. [pmid: 14988589].
643 Sun JG, Ko CH, Wong V. Randomized control trial of tongue acupuncture versus sham acupuncture in improving functional outcome in cerebral palsy. J Neural Neurosurg Psychiatry. 2004;75:1054-7. X-4.
644 Tsirikos AI, Chang WN, Dabney KW, et al. Comparison of parents' and caregivers' satisfaction after spinal fusion in children with cerebral palsy. J Pediatr Orthop. Jan-Feb. 2004;24(1):54-8. X-4. [pmid: 14676534].
645 Vohr BR, Wright LL, Dusick AM, et al. Center differences and outcomes of extremely low birth weight infants. Pediatrics. Apr. 2004;113(4):781-9. X-4. [pmid: 15060228].
646 Wang JH, Luo JY, Dong L, et al. Epidemiology of gastroesophageal reflux disease: a general population-based study in Xi'an of Northwest China. World J Gastroenterol. Jun. 1. 2004;10(11):1647-51. X-4. [pmid: 15162542].
647 Wu G, Jaeger LA, Bazer FW, et al. Arginine deficiency in preterm infants: biochemical mechanisms and nutritional implications. J Nutr Biochem. Aug. 2004;15(8):442-51. X-3. [pmid: 15302078].
648 Yilmaz S, Basar P, Gisel EG. Assessment of feeding performance in patients with cerebral palsy. Int J Rehabil Res. Dec. 2004;27(4):325-9. X-4, X-5. [pmid: 15572999].
649 American Academy for Cerebral Palsy & Developmental Medicine 2005. Dev Med Child Neurol. 2005:3-52. X-11. [pmid: 15686282].
650 European Academy of Childhood Disability Annual Meeting 2005. 19-22 November. Dev Med Child Neurol. 2005;47:1-62. X-11.
651 Antao B, Ooi K, Ade-Ajayi N, et al. Effectiveness of alimemazine in controlling retching after Nissen fundoplication. J Pediatr Surg. Nov. 2005;40(11):1737-40. X-4. [pmid: 16291162].
652 Bendszus M, Monoranu CM, Schutz A, et al. Neurologic complications after particle embolization of intracranial meningiomas. AJNR Am J Neuroradiol. Jun-Jul. 2005;26(6):1413-9. X-3, X-4. [pmid: 15956508].
653 Boujaoude J, Hobeika E, Nasnas R, et al. Percutaneous endoscopic gastro-duodenostomy: modified technique. Gastroenterol Clin Biol. May. 2005;29(5):505-7. X-3, X-4, X-5. [pmid: 15980742].
654 Bouwstra H, Dijck-Brouwer DA, Boehm G, et al. Long-chain polyunsaturated fatty acids and neurological developmental outcome at 18 months in healthy term infants. Acta Paediatr. Jan. 2005;94(1):26-32. X-3, X-4. [pmid: 15858956].
655 Cortes RA, Keller RL, Townsend T, et al. Survival of severe congenital diaphragmatic hernia has morbid consequences. J Pediatr Surg. Jan. 2005;40(1):36-45. discussion -6. X-3, X-4. [pmid: 15868556].
656 de Lagausie P, Bonnard A, Schultz A, et al. Reflux in esophageal atresia, tracheoesophageal cleft, and esophagocoloplasty: Bianchi's procedure as an alternative approach. J Pediatr Surg. Apr. 2005;40(4):666-9. X-3. [pmid: 15852275].
657 Diaz DM, Gibbons TE, Heiss K, et al. Antireflux surgery outcomes in pediatric gastroesophageal reflux disease. Am J Gastroenterol. 2005;100:1844-52. X-3, X-5. [pmid: 16086723].
658 Esposito C, Langer JC, Schaarschmidt K, et al. Laparoscopic antireflux procedures in the management of gastroesophageal reflux following esophageal atresia repair. J Pediatr Gastroenterol Nutr. Mar. 2005;40(3):349-51. X-3, X-4, X-5. [pmid: 15735491].
659 Esposito C, Settimi A, Centonze A, et al. Laparoscopic-assisted jejunostomy: an effective procedure for the treatment of neurologically impaired children with feeding problems and gastroesophageal reflux. Surg Endosc. Apr. 2005;19(4):501-4. X-3, X-5. [pmid: 15959713].
660 Fortunato JE, Darbari A, Mitchell SE, et al. The limitations of gastro-jejunal (G-J) feeding tubes in children: a 9-year pediatric hospital database analysis. Am J Gastroenterol. 2005;100:186-9. X-3, X-4, X-5. [pmid: 15654799].
661 Gioltzoglou T, Cordivari C, Lee PJ, et al. Problems with botulinum toxin treatment in mitochondrial cytopathy: case report and review of the literature. J Neurol Neurosurg Psychiatry. Nov. 2005;76(11):1594-6. X-3. [pmid: 16227561].
662 Glasker S. Central nervous system manifestations in VHL: genetics, pathology and clinical phenotypic features. Fam Cancer. 2005;4(1):37-42. X-3. [pmid: 15883708].
663 Goyal A, Khalil B, Choo K, et al. Esophagogastric dissociation in the neurologically impaired: an alternative to fundoplication?. J Pediatr Surg. Jun. 2005;40(6):915-8. discussion 8-9. X-3, X-4, X-5. [pmid: 15991170].
664 Guzman R, Dubach-Schwizer S, Heini P, et al. Preoperative transarterial embolization of vertebral metastases. Eur Spine J. Apr. 2005;14(3):263-8. X-3, X-4. [pmid: 15378414].
665 Haberfellner H. ISMAR: an autotherapeutic device assisting patients from drooling to articulated speech. Pediatr Rehabil. Oct-Dec. 2005;8(4):248-62. X-1. [pmid: 16192100].
666 Jungbluth H, Zhou H, Hartley L, et al. Minicore myopathy with ophthalmoplegia caused by mutations in the ryanodine receptor type 1 gene. Neurology. Dec. 27. 2005;65(12):1930-5. X-3, X-4. [pmid: 16380615].
667 Karande S, Gupta V, Kulkarni M, et al. Prognostic clinical variables in childhood tuberculous meningitis: an experience from Mumbai, India. Neurol India. Jun. 2005;53(2):191-5. discussion 5-6. X-3, X-4. [pmid: 16010058].
668 Karim R, Desplats G, Schaetzel T, et al. Seeking optimal means to address micronutrient deficiencies in food supplements: A case study from the Bangladesh Integrated Nutrition Project. J Health Popul Nutr. Dec. 2005;23(4):369-76. X-3, X-4, X-5. [pmid: 16599108].
669 Khokhar N, Gill ML. Percutaneous endoscopic gastrostomy: nine years experience in a tertiary care centre in Pakistan. J Pak Med Assoc. Mar. 2005;55(3):108-10. X-3, X-4. [pmid: 15852746].
670 Kong CK, Wong HS. Weight-for-height values and limb anthropometric composition of tube-fed children with quadriplegic cerebral palsy. Pediatrics. Dec. 2005;116(6):e839-45. X-4, X-5. [pmid: 16322142].
671 Lamm NC, De Felice A, Cargan A. Effect of tactile stimulation on lingual motor function in pediatric lingual dysphagia. Dysphagia. Fall. 2005;20(4):311-24. X-3, X-4, X-5. [pmid: 16633877].
672 Manno CJ, Fox C, Eicher PS, et al. Early Oral-Motor Interventions for Pediatric Feeding Problems: What, When and How. J Early Intensive Behav Interv. 2005;2(3):145-59. X-1, X-4, X-5.
673 Monini S, Taurino M, Barbara M, et al. Laryngeal and cranial nerve involvement after carotid endarterectomy. Acta Otolaryngol. Apr. 2005;125(4):398-402. X-3, X-4. [pmid: 15823811].
674 Neuman HB, Phillips JD. Laparoscopic Roux-en-Y feeding jejunostomy: a new minimally invasive surgical procedure for permanent feeding access in children with gastric dysfunction. J Laparoendosc Adv Surg Tech A. Feb. 2005;15(1):71-4. X-5. [pmid: 15772483].
675 Neves-Pinto RM, Carvalho A, Araujo E, et al. Nasal septum giant pyogenic granuloma after a long lasting nasal intubation: case report. Rhinology. Mar. 2005;43(1):66-9. X-3. [pmid: 15844505].
676 Current Literature. Child Care Health Dev. Jul. 2005;31(4):489-92. X-1, X-2, X-3, X-4, X-5.
677 Pereira C, Murphy K, Jeschke M, et al. Post burn muscle wasting and the effects of treatments. Int J Biochem Cell Biol. Oct. 2005;37(10):1948-61. X-3. [pmid: 16109499].
678 Pritchard DS, Baber N, Stephenson T. Should domperidone be used for the treatment of gastro-oesophageal reflux in children? Systematic review of randomized controlled trials in children aged 1 month to 11 years old. Br J Clin Pharmacol. Jun. 2005;59(6):725-9. X-4. [pmid: 15948939].
679 Rempel G, Moussavi Z. The effect of viscosity on the breath-swallow pattern of young people with cerebral palsy. Dysphagia. Spring. 2005;20(2):108-12. X-4. [pmid: 16172819].
680 Rennie MJ, Wilkes EA. Maintenance of the musculoskeletal mass by control of protein turnover: the concept of anabolic resistance and its relevance to the transplant recipient. Ann Transplant. 2005;10(4):31-4. X-3. [pmid: 17037086].
681 Rios G. Retrospective review of the clinical manifestations and outcomes in Puerto Ricans with idiopathic inflammatory myopathies. J Clin Rheumatol. Jun. 2005;11(3):153-6. X-3, X-4. [pmid: 16357735].
682 Seabert H, Eastwood EC, Harris A. A multiprofessional children's feeding clinic. J Fam Health Care. 2005;15(3):72-4. X-1, X-4. [pmid: 16094900].
683 Silas AM, Pearce LF, Lestina LS, et al. Percutaneous radiologic gastrostomy versus percutaneous endoscopic gastrostomy: a comparison of indications, complications and outcomes in 370 patients. Eur J Radiol. Oct. 2005;56(1):84-90. X-3, X-4, X-5. [pmid: 16168268].
684 Sleigh G. Mothers' voice: a qualitative study on feeding children with cerebral palsy. Child Care Health Dev. Jul. 2005;31(4):373-83. X-4. [pmid: 15948874].
685 Stevenson R. Beyond growth: gastrostomy feeding in children with cerebral palsy. Dev Med Child Neurol. Feb. 2005;47(2):76. X-1, X-3, X-4, X-5. [pmid: 15707229].
686 Weir K, McMahon S, Chang AB. Restriction of oral intake of water for aspiration lung disease in children. Cochrane Database Syst Rev. 2005;(4):CD005303. X-4. [pmid: 16235398].
687 You SH, Jang SH, Kim YH, et al. Cortical reorganization induced by virtual reality therapy in a child with hemiparetic cerebral palsy. Dev Med Child Neurol. Sep. 2005;47(9):628-35. X-1, X-4. [pmid: 16138671].
688 Zaffuto-Sforza CD. Aging with cerebral palsy. Phys Med Rehabil Clin N Am. 2005;16(1):235-49. X-1, X-3, X-4, X-5. [pmid: 15561553].
689 Aprahamian CJ, Morgan TL, Harmon CM, et al. U-stitch laparoscopic gastrostomy technique has a low rate of complications and allows primary button placement: experience with 461 pediatric procedures. J Laparoendosc Adv Surg Tech A. Dec. 2006;16(6):643-9. X-3. [pmid: 17243889].
690 Arnbjornsson E, Backman T, Morse H, et al. Complications of video-assisted gastrostomy in children with malignancies or neurological diseases. Acta Paediatr. Apr. 2006;95(4):467-70. X-4. [pmid: 16720496].
691 Avitsland TL, Kristensen C, Emblem R, et al. Percutaneous endoscopic gastrostomy in children: a safe technique with major symptom relief and high parental satisfaction. J Pediatr Gastroenterol Nutr. Nov. 2006;43(5):624-8. X-3, X-5. [pmid: 17130739].
692 Barbiera F, Condello S, De Palo A, et al. Role of videofluorography swallow study in management of dysphagia in neurologically compromised patients. Radiol Med. Sep. 2006;111(6):818-27. X-4. [pmid: 16896559].
693 Barlow JH, Cullen-Powell LA, Cheshire A. Psychological Well-Being among Mothers of Children with Cerebral Palsy. Early Child Development and Care. 2006;176(3):421-8. X-3, X-4.
694 Benjamin DK Jr., Stoll BJ, Fanaroff AA, et al. Neonatal candidiasis among extremely low birth weight infants: risk factors, mortality rates, and neurodevelopmental outcomes at 18 to 22 months. Pediatrics. Jan. 2006;117(1):84-92. X-4. [pmid: 16396864].
695 Celik A, Loux TJ, Harmon CM, et al. Revision Nissen fundoplication can be completed laparoscopically with a low rate of complications: a single-institution experience with 72 children. J Pediatr Surg. Dec. 2006;41(12):2081-5. X-3, X-4, X-5. [pmid: 17161211].
696 Ceriati E, De Peppo F, Ciprandi G, et al. Surgery in disabled children: general gastroenterological aspects. Acta Paediatr Suppl. Jul. 2006;95(452):34-7. X-1, X-4, X-5. [pmid: 16801164].
697 Chu ML, Sala DA. The use of tiagabine in pediatric spasticity management. Dev Med Child Neurol. Jun. 2006;48(6):456-9. X-4. [pmid: 16700936].
698 Craig GM, Carr LJ, Cass H, et al. Medical, surgical, and health outcomes of gastrostomy feeding. Dev Med Child Neurol. May. 2006;48(5):353-60. X-4. [pmid: 16608543].
699 de Luis DA, Aller R, Izaola O, et al. Experience of 6 years with home enteral nutrition in an area of Spain. Eur J Clin Nutr. Apr. 2006;60(4):553-7. X-3, X-4. [pmid: 16340946].
700 Del Buono R, Wenzl TG, Rawat D, et al. Acid and nonacid gastro-oesophageal reflux in neurologically impaired children: investigation with the multiple intraluminal impedance procedure. J Pediatr Gastroenterol Nutr. Sep. 2006;43(3):331-5. X-3, X-5. [pmid: 16954955].
701 Esposito C, Montupet P, van Der Zee D, et al. Long-term outcome of laparoscopic Nissen, Toupet, and Thal antireflux procedures for neurologically normal children with gastroesophageal reflux disease. Surg Endosc. Jun. 2006;20(6):855-8. X-3. [pmid: 16738969].
702 Flaksman H, Ron Y, Ben-David N, et al. Modified endoscopic swallowing test for improved diagnosis and prevention of aspiration. Eur Arch Otorhinolaryngol. Jul. 2006;263(7):637-40. X-1, X-3, X-4, X-5. [pmid: 16538506].
703 Gisel E. Gastrostomy feeding in cerebral palsy: too much of a good thing?. Dev Med Child Neurol. Nov. 2006;48(11):869. X-1, X-3, X-4, X-5. [pmid: 17115478].
704 Goessler A, Huber-Zeyringer A, Hoellwarth ME. Does epilepsy influence the outcome of antireflux procedures in neurologically impaired children?. Pediatr Surg Int. Jun. 2006;22(6):485-90. X-3, X-4, X-5. [pmid: 16736214].
705 Goldin AB, Sawin R, Seidel DD, et al. Do antireflux operations decrease the rate of reflux-related hospitalizations in children?. Pediatrics. 2006;118:2326-33. X-3, X-4, X-5. [pmid: 17142515].
706 Hamidon BB, Abdullah SA, Zawawi MF, et al. A prospective comparison of percutaneous endoscopic gastrostomy and nasogastric tube feeding in patients with acute dysphagic stroke. Med J Malaysia. Mar. 2006;61(1):59-66. X-3, X-4, X-5. [pmid: 16708735].
707 Hoeve LJ, Goedegebure A, Joosten KF. Observations in a cohort of infants with severe laryngeal dyskinesia Auditory brainstem response may aid in the diagnosis. Int J Pediatr Otorhinolaryngol. Apr. 2006;70(4):683-7. X-4. [pmid: 16214226].
708 Hricko P, Storck C, Schmid S, et al. Partial cricotracheal resection for successful reversal of laryngotracheal separation in patients with chronic aspiration. Laryngoscope. May. 2006;116(5):786-90. X-3. [pmid: 16652088].
709 Jan MM. Cerebral palsy: comprehensive review and update. Ann Saudi Med. Mar-Apr. 2006;26(2):123-32. X-1. [pmid: 16761450].
710 Kim LJ, Albuquerque FC, Aziz-Sultan A, et al. Low morbidity associated with use of n-butyl cyanoacrylate liquid adhesive for preoperative transarterial embolization of central nervous system tumors. Neurosurgery. Jul. 2006;59(1):98-104. discussion 98-. X-3, X-4. [pmid: 16823305].
711 Kloek JJ, van de Laar GA, Deurloo JA, et al. Long-term results of boerema anterior gastropexy in children. J Pediatr Gastroenterol Nutr. Jul. 2006;43(1):71-6. X-3, X-4, X-5. [pmid: 16819380].
712 Ko CH, Tse PW, Chan AK. Risk factors of long bone fracture in non-ambulatory cerebral palsy children. Hong Kong Med J. Dec. 2006;12(6):426-31. X-4. [pmid: 17148794].
713 Krigger KW. Cerebral palsy: an overview. Am Fam Physician. Jan. 1. 2006;73(1):91-100. X-1, X-4. [pmid: 16417071].
714 Lall A, Morabito A, Bianchi A. “Total Gastric Dissociation (TGD)” in difficult clinical situations. Eur J Pediatr Surg. Dec. 2006;16(6):396-8. X-3, X-4. [pmid: 17211785].
715 Lall A, Morabito A, Dall'Oglio L, et al. Total oesophagogastric dissociation: experience in 2 centres. J Pediatr Surg. Feb. 2006;41(2):342-6. X-3, X-4, X-5. [pmid: 16481248].
716 Lasser MS, Liao JG, Burd RS. National trends in the use of antireflux procedures for children. Pediatrics. Nov. 2006;118(5):1828-35. X-3, X-4, X-5. [pmid: 17079551].
717 Lazarus C. Tongue strength and exercise in healthy individuals and in head and neck cancer patients. Semin Speech Lang. Nov. 2006;27(4):260-7. X-3. [pmid: 17117352].
718 Leet AI, Mesfin A, Pichard C, et al. Fractures in children with cerebral palsy. J Pediatr Orthop. Sep-Oct. 2006;26(5):624-7. X-4. [pmid: 16932102].
719 Levine A, Levi A, Dalal I, et al. Fat intolerance in developmentally impaired children with severe feeding intolerance. J Child Neurol. Feb. 2006;21(2):167-70. X-3, X-4, X-5. [pmid: 16566886].
720 Ljungdahl M, Sundbom M. Complication rate lower after percutaneous endoscopic gastrostomy than after surgical gastrostomy: a prospective, randomized trial. Surg Endosc. Aug. 2006;20(8):1248-51. X-3. [pmid: 16865614].
721 Manrique D, Settanni FA, Campones do Brasil Ode O. Surgery for aspiration: analysis of laryngotracheal separation in 23 children. Dysphagia. Oct. 2006;21(4):254-8. X-3, X-4, X-5. [pmid: 17216391].
722 McCarthy JJ, D'Andrea LP, Betz RR, et al. Scoliosis in the child with cerebral palsy. J Am Acad Orthop Surg. Jun. 2006;14(6):367-75. X-1, X-4. [pmid: 16757676].
723 McCoy AA, Fox MA, Schaubel DE, et al. Weight gain in children with hypertonia of cerebral origin receiving intrathecal baclofen therapy. Arch Phys Med Rehabil. Nov. 2006;87(11):1503-8. X-1, X-3, X-4. [pmid: 17084127].
724 Morabito A, Lall A, Lo Piccolo R, et al. Total esophagogastric dissociation: 10 years' review. J Pediatr Surg. May. 2006;41(5):919-22. X-3, X-4, X-5. [pmid: 16677883].
725 Nabika S, Oki S, Sumida M, et al. Analysis of risk factors for infection in coplacement of percutaneous endoscopic gastrostomy and ventriculoperitoneal shunt. Neurol Med Chir (Tokyo). May. 2006;46(5):226-9. discussion 9-30. X-3, X-4, X-5. [pmid: 16723814].
726 Naumann M, Albanese A, Heinen F, et al. Safety and efficacy of botulinum toxin type A following long-term use. Eur J Neurol. Dec. Suppl 4. 2006;13:35-40. X-4. [pmid: 17112348].
727 Ng RW, Wei WI. Quality of life of patients with recurrent nasopharyngeal carcinoma treated with nasopharyngectomy using the maxillary swing approach. Arch Otolaryngol Head Neck Surg. Mar. 2006;132(3):309-16. X-3, X-4. [pmid: 16549752].
728 Novak I, Cusick A. Home programmes in paediatric occupational therapy for children with cerebral palsy: Where to start?. Aust Occup Ther J. 2006;53:251-64. X-3, X-4, X-5.
729 Patil PM, Warad NM, Patil RN, et al. Cervical pharyngostomy: an alternative approach to enteral feeding. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. Dec. 2006;102(6):736-40. X-3, X-4. [pmid: 17138174].
730 Petersen MC, Kedia S, Davis P, et al. Eating and feeding are not the same: caregivers' perceptions of gastrostomy feeding for children with cerebral palsy. Dev Med Child Neurol. Sep. 2006;48(9):713-7. X-5. [pmid: 16904015].
731 Plantin I, Arnbjornsson E, Larsson LT. No increase in gastroesophageal reflux after laparoscopic gastrostomy in children. Pediatr Surg Int. Jul. 2006;22(7):581-4. X-3, X-4, X-5. [pmid: 16807719].
732 Poels BJ, Brinkman-Zijlker HG, Dijkstra PU, et al. Malnutrition, eating difficulties and feeding dependence in a stroke rehabilitation centre. Disabil Rehabil. May. 30. 2006;28(10):637-43. X-3, X-4, X-5. [pmid: 16690577].
733 Rapp CE Jr. Cerebral palsy in adulthood: “my child with cerebral palsy is now an adult. Will his medical problems change?”. Exceptional Parent. 2006;36(7):62-6. X-1, X-4, X-5.
734 Stevenson RD. Growth and health in children with moderate-to-severe cerebral palsy. Pediatrics. 2006;118:1010-8. X-4, X-5. [pmid: 16950992].
735 Stevenson RD, Conaway M, Barrington JW, et al. Fracture rate in children with cerebral palsy. Pediatr Rehabil. Oct-Dec. 2006;9(4):396-403. X-3, X-4, X-5. [pmid: 17111566].
736 van Roon D, Steenbergen B. The use of ergonomic spoons by people with cerebral palsy: effects on food spilling and movement kinematics. Dev Med Child Neurol. Nov. 2006;48(11):888-91. X-5. [pmid: 17044955].
737 Vargas M, Horcajada JP, Obach V, et al. Clinical consequences of infection in patients with acute stroke: is it prime time for further antibiotic trials?. Stroke. Feb. 2006;37(2):461-5. X-3, X-4. [pmid: 16385093].
738 Veugelers R, Penning C, van Gulik ME, et al. Feasibility of bioelectrical impedance analysis in children with a severe generalized cerebral palsy. Nutrition. Jan. 2006;22(1):16-22. X-4. [pmid: 16455444].
739 Vohr BR, Poindexter BB, Dusick AM, et al. Beneficial effects of breast milk in the neonatal intensive care unit on the developmental outcome of extremely low birth weight infants at 18 months of age. Pediatrics. Jul. 2006;118(1):e115-23. X-3, X-4, X-5. [pmid: 16818526].
740 Ward KA, Caulton JM, Adams JE, et al. Perspective: cerebral palsy as a model of bone development in the absence of postnatal mechanical factors. J Musculoskelet Neuronal Interact. Apr-Jun. 2006;6(2):154-9. X-1, X-3, X-4, X-5. [pmid: 16849825].
741 Whymark AD, Clement WA, Kubba H, et al. Laser epiglottopexy for laryngomalacia: 10 years' experience in the west of Scotland. Arch Otolaryngol Head Neck Surg. Sep. 2006;132(9):978-82. X-3, X-4, X-5. [pmid: 16982974].
742 Wilson GJ, van der Zee DC, Bax NM. Endoscopic gastrostomy placement in the child with gastroesophageal reflux: is concomitant antireflux surgery indicated?. J Pediatr Surg. Aug. 2006;41(8):1441-5. X-3, X-4, X-5. [pmid: 16863851].
743 Zaytsev AY, Stoyda AY, Smirnov VE, et al. Endovascular treatment of supra-aortic extracranial stenoses in patients with vertebrobasilar insufficiency symptoms. Cardiovasc Intervent Radiol. Sep-Oct. 2006;29(5):731-8. X-3, X-4. [pmid: 16718428].
744 Alacam A, Kolcuoglu N. Effects of two types of appliances on orofacial dysfunctions of disabled children. British Journal of Developmental Disabilities. 2007;53 part 2(105):111-23. X-3, X-4, X-5.
745 Alouf B. Care of the the adolescent female with cerebral palsy. Int J Disabil Hum Dev. Jan-Mar. 2007;6(1):3-10. X-1, X-3, X-4.
746 Backman T, Berglund Y, Sjovie H, et al. Complications of video-assisted gastrostomy in children with or without a ventriculoperitoneal shunt. Pediatr Surg Int. Jul. 2007;23(7):665-8. X-3, X-4. [pmid: 17487495].
747 Bacon JK, Betenbaugh HR, Carter EW, et al. Book reviews. Journal of Religion, Disability & Health. 2007;11(3):79-103. X-1, X-3, X-4, X-5.
748 Barlow J, Powell L, Cheshire A. The training and support programme (involving basic massage) for parents of children with cerebral palsy: an implementation study. J Bodyw Mov Ther. 2007;11(1):44-53. X-4.
749 Brigand C, Ferraro P, Martin J, et al. Risk factors in patients undergoing cricopharyngeal myotomy. Br J Surg. Aug. 2007;94(8):978-83. X-3, X-4. [pmid: 17497757].
750 Coscarelli S, Verrecchia L, Coscarelli A. Endoscopic evaluation of neurological dysphagic patients. Acta Otorhinolaryngol Ital. Dec. 2007;27(6):281-5. X-4. [pmid: 18320832].
751 Day SM, Strauss DJ, Vachon PJ, et al. Growth patterns in a population of children and adolescents with cerebral palsy. Dev Med Child Neurol. Mar. 2007;49(3):167-71. X-4, X-5. [pmid: 17355471].
752 Fowler EG, Kolobe TH, Damiano DL, et al. Promotion of physical fitness and prevention of secondary conditions for children with cerebral palsy: section on pediatrics research summit proceedings. Phys Ther. Nov. 2007;87(11):1495-510. X-1, X-4, X-11. [pmid: 17895351].
753 Goessler A, Huber-Zeyringer A, Hoellwarth ME. Recurrent gastroesophageal reflux in neurologically impaired patients after fundoplication. Acta Paediatr. Jan. 2007;96(1):87-93. X-3, X-4, X-5. [pmid: 17187611].
754 Gossler A, Schalamon J, Huber-Zeyringer A, et al. Gastroesophageal reflux and behavior in neurologically impaired children. J Pediatr Surg. Sep. 2007;42(9):1486-90. X-3, X-4, X-5. [pmid: 17848235].
755 Hashimoto N, Nozaki K, Takagi Y, et al. Surgery of cerebral arteriovenous malformations. Neurosurgery. Jul. 2007;61(1 Suppl):375-87. discussion 87-9. X-3. [pmid: 18813152].
756 Henderson RC, Grossberg RI, Matuszewski J, et al. Growth and nutritional status in residential center versus home-living children and adolescents with quadriplegic cerebral palsy. J Pediatr. Aug. 2007;151(2):161-6. X-3, X-4, X-5. [pmid: 17643769].
757 Hillesund E, Skranes J, Trygg KU, et al. Micronutrient status in children with cerebral palsy. Acta Paediatr. Aug. 2007;96(8):1195-8. X-4. [pmid: 17655620].
758 Huang M, Fan HF, Lei SN. Scalp acupuncture plus body-acupuncture for treatment of spastic cerebral palsy and its effects on bone density and trace elements in the diseased children. Chin Acupuncture Moxibust. 2007;6:395-7. X-2, X-4, X-5.
759 Jalowiec A, Grady KL, White-Williams C. Functional status one year after heart transplant. J Cardiopulm Rehabil Prev. Jan-Feb. 2007;27(1):24-32. discussion 3-4. X-3, X-4. [pmid: 17474641].
760 Juhasz-Pocsine K, Rudnicki SA, Archer RL, et al. Neurologic complications of gastric bypass surgery for morbid obesity. Neurology. May. 22. 2007;68(21):1843-50. X-3, X-4. [pmid: 17515548].
761 Khariwala SS, Chan J, Blackwell KE, et al. Temporomandibular joint reconstruction using a vascularized bone graft with Alloderm. J Reconstr Microsurg. Jan. 2007;23(1):25-30. X-3, X-4. [pmid: 17230317].
762 Krakovsky G, Huth MM, Lin L, et al. Functional changes in children, adolescents, and young adults with cerebral palsy. Res Dev Disabil. Jul-Sep. 2007;28(4):331-40. X-4. [pmid: 16772110].
763 Kristensen C, Avitsland T, Emblem R, et al. Satisfactory long-term results after Nissen fundoplication. Acta Paediatr. May. 2007;96(5):702-5. X-3. [pmid: 17462062].
764 Kuhls DA, Rathmacher JA, Musngi MD, et al. Beta-hydroxy-beta-methylbutyrate supplementation in critically ill trauma patients. J Trauma. Jan. 2007;62(1):125-31. discussion 31-2. X-3, X-4. [pmid: 17215743].
765 Lacasa JM, Jimenez JA, Ferras V, et al. Prophylaxis versus pre-emptive treatment for infective and inflammatory complications of surgical third molar removal: a randomized, double-blind, placebo-controlled, clinical trial with sustained release amoxicillin/clavulanic acid (1000/62.5 mg). Int J Oral Maxillofac Surg. Apr. 2007;36(4):321-7. X-3, X-4. [pmid: 17229548].
766 Lawrence S. Review of <i>Eating and drinking difficulties in children; A guide for practitioners</i>. Int J Lang Commun Disord. Sep. 2007;42(5):625-6. X-1, X-3, X-4.
767 Lee KS, Chen BN, Yang CC, et al. CO2 laser supraglottoplasty for severe laryngomalacia: a study of symptomatic improvement. Int J Pediatr Otorhinolaryngol. Jun. 2007;71(6):889-95. X-3, X-4. [pmid: 17416423].
768 Miller CK, Willging JP. The implications of upper-airway obstruction on successful infant feeding. Semin Speech Lang. Aug. 2007;28(3):190-203. X-3. [pmid: 17647131].
769 Miller JJ, Kahn D, Lorenz HP, et al. Infant mandibular distraction with an internal curvilinear device. J Craniofac Surg. Nov. 2007;18(6):1403-7. X-1, X-3, X-4, X-5. [pmid: 17993889].
770 Moog U, van Mierlo I, van Schrojenstein Lantman-de Valk HM, et al. Is Sanfilippo type B in your mind when you see adults with mental retardation and behavioral problems?. Am J Med Genet C Semin Med Genet. Aug. 15. 2007;145C(3):293-301. X-1. [pmid: 17640047].
771 Morrow AM, Quine S, Craig JC. Health professionals' perceptions of feeding-related quality of life in children with quadriplegic cerebral palsy. Child Care Health Dev. Sep. 2007;33(5):529-38. X-3, X-4. [pmid: 17725774].
772 Neufeld JA. Neurodevelopmental disorders. NeuroRehabilitation. Special Issue: Neurodevelopmental disorders. 2007;22(5):339-40. X-3, X-4.
773 Neufeld JA. Special issue: Neurodevelopmental disorders. NeuroRehabilitation. 2007;22(5):339-406. X-1, X-4, X-5.
774 Ngerncham M, Barnhart DC, Haricharan RN, et al. Risk factors for recurrent gastroesophageal reflux disease after fundoplication in pediatric patients: a case-control study. J Pediatr Surg. Sep. 2007;42(9):1478-85. X-3, X-4, X-5. [pmid: 17848234].
775 Oates JE, Clark JR, Read J, et al. Prospective evaluation of quality of life and nutrition before and after treatment for nasopharyngeal carcinoma. Arch Otolaryngol Head Neck Surg. Jun. 2007;133(6):533-40. X-3, X-4. [pmid: 17576902].
776 Pacilli M, Eaton S, Maritsi D, et al. Factors predicting failure of redo Nissen fundoplication in children. Pediatr Surg Int. May. 2007;23(5):499-503. X-3, X-4, X-5. [pmid: 17216234].
777 Pazardzhikliev DD, Yovchev IP. Influence of age on pharyngoesophageal spasm rates in laryngectomees. Folia Med (Plovdiv). 2007;49(3-4):42-5. X-3, X-4. [pmid: 18504933].
778 Pin T. Effectiveness of static weight-bearing exercises in children with cerebral palsy. Pediatric Physical Therapy. 2007;19(1):62-73. X-4. [pmid: 17304099].
779 Pin TW. Effectiveness of static weight-bearing exercises in children with cerebral palsy. Pediatr Phys Ther. Spring. 2007;19(1):62-73. X-4. [pmid: 17304099].
780 Ricci Maccarini A, Filippini A, Padovani D, et al. Clinical non-instrumental evaluation of dysphagia. Acta Otorhinolaryngol Ital. Dec. 2007;27(6):299-305. X-1, X-3, X-4, X-5. [pmid: 18320836].
781 Schadler G, Suss-Burghart H, Toschke AM, et al. Feeding disorders in ex-prematures: causes—response to therapy—long term outcome. Eur J Pediatr. Aug. 2007;166(8):803-8. X-3, X-4, X-5. [pmid: 17120038].
782 Srivastava R, Downey EC, Feola P, et al. Quality of life of children with neurological impairment who receive a fundoplication for gastroesophageal reflux disease. J Hosp Med. May. 2007;2(3):165-73. X-3, X-4, X-5. [pmid: 17549766].
783 Stevenson VL. Relief of symptoms in end-stage neurological conditions. Br J Hosp Med (Lond). Dec. 2007;68(12):640-3. X-3. [pmid: 18186396].
784 Strauss D, Shavelle R, Reynolds R, et al. Survival in cerebral palsy in the last 20 years: signs of improvement?. Dev Med Child Neurol. Feb. 2007;49(2):86-92. X-4, X-5. [pmid: 17253993].
785 Trappe S, Creer A, Slivka D, et al. Single muscle fiber function with concurrent exercise or nutrition countermeasures during 60 days of bed rest in women. J Appl Physiol. Oct. 2007;103(4):1242-50. X-3, X-4. [pmid: 17641219].
786 Vernon-Roberts A, Sullivan PB. Fundoplication versus post-operative medication for gastro-oesophageal reflux in children with neurological impairment undergoing gastrostomy. Cochrane Database Syst Rev. 2007;(1):CD006151. [pmid: 17253583].
787 Vohr BR, Poindexter BB, Dusick AM, et al. Persistent beneficial effects of breast milk ingested in the neonatal intensive care unit on outcomes of extremely low birth weight infants at 30 months of age. Pediatrics. Oct. 2007;120(4):e953-9. X-3, X-4, X-5. [pmid: 17908750].
788 Wilson-Costello D. Is there evidence that long-term outcomes have improved with intensive care?. Semin Fetal Neonatal Med. Oct. 2007;12(5):344-54. X-1, X-3, X-4, X-5. [pmid: 17698428].
789 Worley G, Stevenson RD, Rosenbloom L, et al. Castang and Novartis Foundation Conference on Undernutrition in children with cerebral palsy: survey of participants about decision-making for enteral (gastrostomy) feeding. J Nutr Environ Med. 2007;16(1):75-81. X-3, X-4, X-11.
790 Antle BJ, Mills W, Steele C, et al. An exploratory study of parents' approaches to health promotion in families of adolescents with physical disabilities. Child Care Health Dev. Mar. 2008;34(2):185-93. X-4. [pmid: 18257791].
791 Bachere N, Diene G, Delagnes V, et al. Early diagnosis and multidisciplinary care reduce the hospitalization time and duration of tube feeding and prevent early obesity in PWS infants. Horm Res. 2008;69(1):45-52. X-3, X-4. [pmid: 18059083].
792 Bergqvist AG, Trabulsi J, Schall JI, et al. Growth failure in children with intractable epilepsy is not due to increased resting energy expenditure. Dev Med Child Neurol. Jun. 2008;50(6):439-44. X-4. [pmid: 18422677].
793 Boucher N, Bairam A, Beaulac-Baillargeon L. A new look at the neonate's clinical presentation after in utero exposure to antidepressants in late pregnancy. J Clin Psychopharmacol. Jun. 2008;28(3):334-9. X-3, X-4. [pmid: 18480693].
794 Bozzetti F. Quality of life and enteral nutrition. Curr Opin Clin Nutr Metab Care. Sep. 2008;11(5):661-5. X-1. [pmid: 18685465].
795 Capito C, Leclair MD, Piloquet H, et al. Long-term outcome of laparoscopic Nissen-Rossetti fundoplication for neurologically impaired and normal children. Surg Endosc. Apr. 2008;22(4):875-80. X-3. [pmid: 17963001].
796 Chen A, Dimambro N, Clowry GJ. A comparison of behavioural and histological outcomes of periventricular injection of ibotenic acid in neonatal rats at postnatal days 5 and 7. Brain Res. Mar. 2008;1201:187-95. X-3, X-4. [pmid: 18295192].
797 Cuoco L, Vescovo G, Castaman R, et al. Skeletal muscle wastage in Crohn's disease: a pathway shared with heart failure?. Int J Cardiol. Jul. 4. 2008;127(2):219-27. X-3, X-4. [pmid: 17692969].
798 Gauderer MW. Experience with a hybrid, minimally invasive gastrostomy for children with abnormal epigastric anatomy. J Pediatr Surg. Dec. 2008;43(12):2178-81. X-3, X-4, X-5. [pmid: 19040930].
799 Gisel E. Interventions and outcomes for children with dysphagia. Dev Disabil Res Rev. 2008;14(2):165-73. X-1, X-3, X-4, X-5. [pmid: 18646023].
800 Hage ZA, Few JW, Surdell DL, et al. Modern endovascular and aesthetic surgery techniques to treat arteriovenous malformations of the scalp: case illustration. Surg Neurol. Aug. 2008;70(2):198-203. discussion. X-3. [pmid: 18291477].
801 Iwasaki T, Takei K, Nakamura S, et al. Secondary osteoporosis in long-term bedridden patients with cerebral palsy. Pediatr Int. Jun. 2008;50(3):269-75. X-4. [pmid: 18533934].
802 Knox V. Do parents of children with cerebral palsy express different concerns in relation to their child's type of cerebral palsy, age and level of disability?. Physiotherapy. 2008;94(1):56-62. X-4, X-5.
803 Kuo CH, Hu HM, Tsai PY, et al. A better method for preventing infection of percutaneous endoscopic gastrostomy. J Gastrointest Surg. Feb. 2008;12(2):358-63. X-3, X-4, X-5. [pmid: 18040748].
804 Kuperminc MN, Stevenson RD. Growth and nutrition disorders in children with cerebral palsy. Dev Disabil Res Rev. 2008;14(2):137-46. X-1, X-4. [pmid: 18646022].
805 Lee SL, Sydorak RM, Chiu VY, et al. Long-term antireflux medication use following pediatric Nissen fundoplication. Arch Surg. Sep. 2008;143(9):873-6. discussion 6. X-3, X-4, X-5. [pmid: 18794425].
806 Lopez M, Kalfa N, Forgues D, et al. Laparoscopic redo fundoplication in children: failure causes and feasibility. J Pediatr Surg. Oct. 2008;43(10):1885-90. X-3, X-4, X-5. [pmid: 18926226].
807 Maria Barlow K. Neurorehabilitation of children with cerebral palsy. Handb Clin Neurol. 2008;87:591-609. X-1, X-5. [pmid: 18809046].
808 Marrara JL, Duca AP, Dantas RO, et al. Swallowing in children with neurologic disorders: clinical and videofluoroscopic evaluations. Pro Fono. Oct-Dec. 2008;20(4):231-6. X-1, X-4. [pmid: 19142465].
809 Mathei J, Coosemans W, Nafteux P, et al. Laparoscopic Nissen fundoplication in infants and children: analysis of 106 consecutive patients with special emphasis in neurologically impaired vs. neurologically normal patients. Surg Endosc. Apr. 2008;22(4):1054-9. X-3, X-5. [pmid: 17943378].
810 Miles R. Life expectancy estimation in cerebral palsy —a paediatrician's approach. Clinical Risk. 2008;14(4):130-2. X-1, X-3, X-4, X-5.
811 Miyazawa R, Tomomasa T, Kaneko H, et al. Effects of pectin liquid on gastroesophageal reflux disease in children with cerebral palsy. BMC Gastroenterol. 2008;8:11. X-4, X-5. [pmid: 18412980].
812 Morrow AM, Quine S, Loughlin EV, et al. Different priorities: a comparison of parents' and health professionals' perceptions of quality of life in quadriplegic cerebral palsy. Arch Dis Child. Feb. 2008;93(2):119-25. X-3, X-4. [pmid: 17932123].
813 Msall ME, Park JJ. Neurodevelopmental management strategies for children with cerebral palsy: optimizing function, promoting participation, and supporting families. Clin Obstet Gynecol. Dec. 2008;51(4):800-15. X-1, X-4. [pmid: 18981804].
814 Munakata M, Kobayashi K, Niisato-Nezu J, et al. Olfactory stimulation using black pepper oil facilitates oral feeding in pediatric patients receiving long-term enteral nutrition. Tohoku J Exp Med. Apr. 2008;214(4):327-32. X-3, X-4. [pmid: 18441508].
815 Nakamura M, Ishii K, Watanabe K, et al. Surgical treatment of intramedullary spinal cord tumors: prognosis and complications. Spinal Cord. Apr. 2008;46(4):282-6. X-3, X-4. [pmid: 17909556].
816 O'Shea TM. Diagnosis, treatment, and prevention of cerebral palsy. Clin Obstet Gynecol. Dec. 2008;51(4):816-28. X-1, X-3, X-4, X-5. [pmid: 18981805].
817 Pacilli M, Pierro A, Lindley KJ, et al. Gastric emptying is accelerated following laparoscopic Nissen fundoplication. Eur J Pediatr Surg. Dec. 2008;18(6):395-7. X-3, X-4, X-5. [pmid: 19039735].
818 Payton C. Biomechanics support for British world class disability swimming. SportEX Medicine. 2008;(36):9-13. X-1, X-3, X-4, X-5.
819 Pearlman LS, McVittie A, Hunter K. Discharge management of an adolescent female with posterior fossa syndrome: a case report. Can J Neurosci Nurs. 2008;30(3):14-20. X-3. [pmid: 18856094].
820 Porter D, Michael S, Kirkwood C. Is there a relationship between preferred posture and positioning in early life and the direction of subsequent asymmetrical postural deformity in non ambulant people with cerebral palsy?. Child Care Health Dev. Sep. 2008;34(5):635-41. X-4. [pmid: 18796054].
821 Radell U, Tillberg E, Mattsson E, et al. Participation in age-related activities and influence of cultural factors—comments from youth and parents of children with postnatal post infectious hemiplegia in Stockholm, Sweden. Disabil Rehabil. 2008;30(11):891-7. X-4. [pmid: 17852276].
822 Roth M, Drucker R. Nutritional requirements for children with special needs. Exceptional Parent. 2008;38(2):27. X-1, X-3, X-4, X-5.
823 Saadani-Makki F, Kannan S, Lu X, et al. Intrauterine administration of endotoxin leads to motor deficits in a rabbit model: a link between prenatal infection and cerebral palsy. Am J Obstet Gynecol. Dec. 2008;199(6):651 e1-7. X-3, X-4. [pmid: 18845289].
824 Scott B, Butterworth C, Lowe D, et al. Factors associated with restricted mouth opening and its relationship to health-related quality of life in patients attending a Maxillofacial Oncology clinic. Oral Oncol. May. 2008;44(5):430-8. X-3, X-4. [pmid: 17826305].
825 Secer HI, Duz B, Izci Y, et al. Tumors of the lateral ventricle: the factors that affected the preference of the surgical approach in 46 patiens. Turk Neurosurg. Oct. 2008;18(4):345-55. X-3, X-4. [pmid: 19107680].
826 Shulman DH, Shipman B, Willis FB. Treating trismus with dynamic splinting: a cohort, case series. Adv Ther. Jan. 2008;25(1):9-16. X-3, X-4. [pmid: 18227979].
827 Silva SV, Schmidt AF, Mezzacappa MA, et al. Babies with brain damage who can not swallow: surgical management. Arq Neuropsiquiatr. Sep. 2008;66(3B):641-5. X-3, X-4, X-5. [pmid: 18949255].
828 Soguel L, Chiolero RL, Ruffieux C, et al. Monitoring the clinical introduction of a glutamine and antioxidant solution in critically ill trauma and burn patients. Nutrition. Nov-Dec. 2008;24(11-12):1123-32. X-3, X-4. [pmid: 18692364].
829 Somerville H, Tzannes G, Wood J, et al. Gastrointestinal and nutritional problems in severe developmental disability. Dev Med Child Neurol. Sep. 2008;50(9):712-6. X-3, X-4, X-5. [pmid: 18754923].
830 Soylu OB, Unalp A, Uran N, et al. Effect of nutritional support in children with spastic quadriplegia. Pediatr Neurol. Nov. 2008;39(5):330-4. X-4. [pmid: 18940556].
831 Stylianides NA, Date RS, Pursnani KG, et al. Jejunal perforation caused by a feeding jejunostomy tube: a case report. J Med Case Reports. 2008;2:224. X-1, X-3, X-4, X-5. [pmid: 18590544].
832 Sullivan P. Growth failure in children with intractable epilepsy. Dev Med Child Neurol. Jun. 2008;50(6):406. X-1, X-4. [pmid: 18489456].
833 Takahashi T, Okazaki T, Kato Y, et al. Laparoscopy-assisted percutaneous endoscopic gastrostomy. Asian J Surg. Oct. 2008;31(4):204-6. X-4, X-5. [pmid: 19010764].
834 Tannuri AC, Tannuri U, Mathias AL, et al. Gastroesophageal reflux disease in children: efficacy of Nissen fundoplication in treating digestive and respiratory symptoms. Experience of a single center. Dis Esophagus. 2008;21(8):746-50. X-3, X-4, X-5. [pmid: 18847453].
835 Terre R, Valles M, Panades A, et al. Long-lasting effect of a single botulinum toxin injection in the treatment of oropharyngeal dysphagia secondary to upper esophageal sphincter dysfunction: a pilot study. Scand J Gastroenterol. 2008;43(11):1296-303. X-3, X-4. [pmid: 18649151].
836 Townsend JL, Craig G, Lawson M, et al. Cost-effectiveness of gastrostomy placement for children with neurodevelopmental disability. Arch Dis Child. Oct. 2008;93(10):873-7. X-3, X-4, X-5. [pmid: 18456697].
837 van Zwol A, van den Berg A, Huisman J, et al. Neurodevelopmental outcomes of very low-birth-weight infants after enteral glutamine supplementation in the neonatal period. Acta Paediatr. May. 2008;97(5):562-7. X-3, X-4, X-5. [pmid: 18394100].
838 Veenker E. Enteral feeding in neurologically impaired children with gastroesophageal reflux: Nissen fundoplication and gastrostomy tube placement versus percutaneous gastrojejunostomy. J Pediatr Nurs. Oct. 2008;23(5):400-4. X-3. [pmid: 18804022].
839 Veness C, Reilly S. Mealtime interaction patterns between young children with cerebral palsy and their mothers: characteristics and relationship to feeding impairment. Child Care Health Dev. Nov. 2008;34(6):815-24. X-4, X-5. [pmid: 18785971].
840 Villar Taibo R, Martinez Olmos MA, Rodriguez Iglesias MJ, et al. Home artificial nutrition in a sanitary area of Galicia (Spain): descriptive study and proposals for the future. Nutr Hosp. Sep-Oct. 2008;23(5):433-8. X-3, X-4, X-5. [pmid: 19160893].
841 Wei L, Su ZJ, Guan FS. Randomized double-blind controlled study of therapeutic effects of Astragalus injection on children with cerebral palsy. Appl J Gen Pract. 2008;3:234-5. X-2, X-3, X-4, X-5.
842 Xu K. Clinical controlled study of acupuncture treating children with cerebral palsy. J Complement Altern Med. 2008;3:11-2. X-9.
843 Yalcin S, Ciftci AO, Senocak ME, et al. Clinical presentation and management of gastroesophageal reflux disease in a referral center in Turkey. Eur J Pediatr Surg. Jun. 2008;18(3):180-4. X-3, X-4, X-5. [pmid: 18493894].
844 Yoon YS, Ahn JY, Chang JH, et al. Pre-operative embolisation of internal carotid artery branches and pial vessels in hypervascular brain tumours. Acta Neurochir (Wien). May. 2008;150(5):447-52. discussion 52. X-3, X-4. [pmid: 18278572].
845 News. Neonatal Intensive Care. 2009;22(7):15-20. X-1, X-3, X-4, X-5.
846 Nutrition in neurologically impaired children. Paediatr Child Health. Jul. 2009;14(6):395-401. X-1, X-3, X-4, X-5. [pmid: 20592978].
847 Aharonson-Raz K, Milgram J, Chai O, et al. Fibrosis of the masseter leading to trismus and dysphagia in a mare. Vet Rec. May. 9. 2009;164(19):597-8. X-3, X-4, X-5. [pmid: 19429940].
848 Balandin S, Hemsley B, Hanley L, et al. Understanding mealtime changes for adults with cerebral palsy and the implications for support services. J Intellect Dev Disabil. Sep. 2009;34(3):197-206. X-4. [pmid: 19681000].
849 Barber N, Carden CA, Mahomed AA. Does the placement of a FRECA gastrostomy at the time of laparoscopic fundoplication impact on outcome?. Surg Endosc. Mar. 2009;23(3):598-601. X-3, X-4, X-5. [pmid: 18461387].
850 Borkhuu B, Nagaraju D, Miller F, et al. Prevalence and risk factors in postoperative pancreatitis after spine fusion in patients with cerebral palsy. J Pediatr Orthop. Apr-May. 2009;29(3):256-62. X-4. [pmid: 19305276].
851 Bostrom A, Krings T, Hans FJ, et al. Spinal glomus-type arteriovenous malformations: microsurgical treatment in 20 cases. J Neurosurg Spine. May. 2009;10(5):423-9. X-3, X-4. [pmid: 19442003].
852 Chadwick DD, Jolliffe J. A descriptive investigation of dysphagia in adults with intellectual disabilities. J Intellect Disabil Res. 2009;53(1):29-43. X-3, X-4, X-5. [pmid: 18759960].
853 Chone CT, Seixas VO, Andreollo NA, et al. Computerized manometry use to evaluate spasm in pharyngoesophageal segment in patients with poor tracheoesophageal speech before and after treatment with botulinum toxin. Braz J Otorhinolaryngol. Mar-Apr. 2009;75(2):182-7. X-4. [pmid: 19575102].
854 Cohen S, Brault JJ, Gygi SP, et al. During muscle atrophy, thick, but not thin, filament components are degraded by MuRF1-dependent ubiquitylation. J Cell Biol. Jun. 15. 2009;185(6):1083-95. X-3, X-4. [pmid: 19506036].
855 Conley SF, Beecher RB, Delaney AL, et al. Outcomes of tonsillectomy in neurologically impaired children. Laryngoscope. Nov. 2009;119(11):2231-41. X-4. [pmid: 19650126].
856 Cook SP. Candidate's Thesis: Laryngotracheal separation in neurologically impaired children: long-term results. Laryngoscope. Feb. 2009;119(2):390-5. X-4. [pmid: 19160406].
857 Donas KP, Lachat M, Rancic Z, et al. Early and midterm outcome of a novel technique to simplify the hybrid procedures in the treatment of thoracoabdominal and pararenal aortic aneurysms. J Vasc Surg. Dec. 2009;50(6):1280-4. X-3, X-4. [pmid: 19958984].
858 Fauconnier J, Dickinson HO, Beckung E, et al. Participation in life situations of 8-12 year old children with cerebral palsy: cross sectional European study. BMJ. 2009;338:b1458. X-4. [pmid: 19395424].
859 Gaines DI, Durkalski V, Patel A, et al. Dementia and cognitive impairment are not associated with earlier mortality after percutaneous endoscopic gastrostomy. JPEN J Parenter Enteral Nutr. Jan-Feb. 2009;33(1):62-6. X-3, X-4. [pmid: 18827070].
860 Heppenstall CP, Wilkinson TJ, Hanger HC, et al. Frailty: dominos or deliberation?. N Z Med J. Jul. 24. 2009;122(1299):42-53. X-1. [pmid: 19684647].
861 Jiao Q, Pruznak AM, Huber D, et al. Castration differentially alters basal and leucine-stimulated tissue protein synthesis in skeletal muscle and adipose tissue. Am J Physiol Endocrinol Metab. Nov. 2009;297(5):E1222-32. X-3, X-4. [pmid: 19755668].
862 Johnston MV. Plasticity in the developing brain: implications for rehabilitation. Dev Disabil Res Rev. 2009;15(2):94-101. X-1, X-3, X-4. [pmid: 19489084].
863 Kane TD. Laparoscopic Nissen fundoplication. Minerva Chir. Apr. 2009;64(2):147-57. X-1. [pmid: 19365315].
864 Katz RT. Are children with cerebral palsy and developmental disability living longer?. J Dev Phys Disabil. Oct. 2009;21(5):409-24. X-1, X-4, X-5.
865 Kilpinen-Loisa P, Pihko H, Vesander U, et al. Insufficient energy and nutrient intake in children with motor disability. Acta Paediatrica. Aug. 2009;98(8):1329-33. X-4. [pmid: 19432830].
866 Krause E, Hempel JM, Gurkov R. Botulinum toxin A prolongs functional durability of voice prostheses in laryngectomees with pharyngoesophageal spasm. Am J Otolaryngol. Nov-Dec. 2009;30(6):371-5. X-3, X-4. [pmid: 19880024].
867 Lemoine JK, Haus JM, Trappe SW, et al. Muscle proteins during 60-day bedrest in women: impact of exercise or nutrition. Muscle Nerve. Apr. 2009;39(4):463-71. X-3, X-4. [pmid: 19229964].
868 Manrique D, Sato J. Salivary gland surgery for control of chronic pulmonary aspiration in children with cerebral palsy. Int J Pediatr Otorhinolaryngol. Sep. 2009;73(9):1192-4. X-4. [pmid: 19535155].
869 Masiero E, Agatea L, Mammucari C, et al. Autophagy is required to maintain muscle mass. Cell Metab. Dec. 2009;10(6):507-15. X-3, X-4. [pmid: 19945408].
870 Mattioli G, Buffa P, Gandullia P, et al. Laparoscopic proximal Roux-en-Y gastrojejunal diversion in children: preliminary experience from a single center. J Laparoendosc Adv Surg Tech A. Dec. 2009;19(6):807-13. X-3, X-4. [pmid: 19405807].
871 Nair MK, George B, Padma K, et al. Developmental Evaluation Clinic—CDC experience. Indian Pediatr. Jan. 2009;46(Suppl):s63-6. X-4. [pmid: 19279373].
872 Novak I, Cusick A, Lannin N. Occupational therapy home programs for cerebral palsy: double-blind, randomised, controlled trial. Pediatrics. 2009;124:606-14. X-3, X-4.
873 Novotny NM, Jester AL, Ladd AP. Preoperative prediction of need for fundoplication before gastrostomy tube placement in children. J Pediatr Surg. Jan. 2009;44(1):173-6. discussion 6-7. X-3, X-4, X-5. [pmid: 19159739].
874 Peetsold MG, Heij HA, Kneepkens CM, et al. The long-term follow-up of patients with a congenital diaphragmatic hernia: a broad spectrum of morbidity. Pediatr Surg Int. Jan. 2009;25(1):1-17. X-3. [pmid: 18841373].
875 Reddy DR. Neurology of endemic skeletal fluorosis. Neurol India. Jan-Feb. 2009;57(1):7-12. X-3. [pmid: 19305069].
876 Santos MT, Guare RO, Celiberti P, et al. Caries experience in individuals with cerebral palsy in relation to oromotor dysfunction and dietary consistency. Spec Care Dentist. Sep-Oct. 2009;29(5):198-203. X-4. [pmid: 19740150].
877 Sathesh-Kumar T, Rollins H, Cheslyn-Curtis S. General paediatric surgical provision of percutaneous endoscopic gastrostomy in a district general hospital—a 12-year experience. Ann R Coll Surg Engl. Jul. 2009;91(5):404-9. X-3, X-4, X-5. [pmid: 19344554].
878 Schneiberg Dias S. Rehabilitation strategies to improve upper limb movement quality in children with cerebral palsy. Ph.D. 2009:210. X-9.
879 Sheridan KJ. Osteoporosis in adults with cerebral palsy. Dev Med Child Neurol. Oct. Suppl 4. 2009;51:38-51. X-1, X-3, X-4, X-5. [pmid: 19740209].
880 Solheim O, Selbekk T, Lindseth F, et al. Navigated resection of giant intracranial meningiomas based on intraoperative 3D ultrasound. Acta Neurochir (Wien). Sep. 2009;151(9):1143-51. X-3, X-4. [pmid: 19440654].
881 Srinivasan R, Irvine T, Dalzell M. Indications for percutaneous endoscopic gastrostomy and procedure-related outcome. J Pediatr Gastroenterol Nutr. Nov. 2009;49(5):584-8. X-4, X-5. [pmid: 19820413].
882 Srivastava R, Berry JG, Hall M, et al. Reflux related hospital admissions after fundoplication in children with neurological impairment: retrospective cohort study. BMJ. 2009;339:b4411. X-3, X-4, X-5. [pmid: 19923145].
883 Srivastava R, Downey EC, O'Gorman M, et al. Impact of fundoplication versus gastrojejunal feeding tubes on mortality and in preventing aspiration pneumonia in young children with neurologic impairment who have gastroesophageal reflux disease. Pediatrics. Jan. 2009;123(1):338-45. X-3, X-4, X-5. [pmid: 19117901].
884 Uchikawa K, Toikawa H, Liu M. Subscapularis motor point block for spastic shoulders in patients with cervical cord injury. Spinal Cord. Mar. 2009;47(3):249-51. X-3, X-4. [pmid: 18825158].
885 Verschueren A, Monnier A, Attarian S, et al. Enteral and parenteral nutrition in the later stages of ALS: an observational study. Amyotroph Lateral Scler. Feb. 2009;10(1):42-6. X-3, X-4. [pmid: 18615338].
886 Vogtle LK. Pain in adults with cerebral palsy: impact and solutions. Dev Med Child Neurol. Oct. Suppl 4. 2009;51:113-21. X-4. [pmid: 19740218].
887 Wilcox DD, Potvin M, Prelock PA. Oral motor interventions and cerebral pasly: using evidence to inform practice. Early Intervention & School Special Interest Section Quarterly. 2009;16(4):1-4. X-10.
888 Wilson EM, Hustad KC. Early feeding abilities in children with cerebral palsy: a parental report study. J Med Speech Lang Pathol. 2009;17(1):31-44. X-4.
889 Wortmann SB, Zweers-van Essen H, Rodenburg RJ, et al. Mitochondrial energy production correlates with the age-related BMI. Pediatr Res. Jan. 2009;65(1):103-8. X-3, X-4. [pmid: 19096353].
890 Ziegler O, Sirveaux MA, Brunaud L, et al. Medical follow up after bariatric surgery: nutritional and drug issues. General recommendations for the prevention and treatment of nutritional deficiencies. Diabetes Metab. Dec. 2009;35(6 Pt 2):544-57. X-3. [pmid: 20152742].
891 Drugs for cerebral palsy need further study. Nutrition Health Review: The Consumer's Medical Journal. 2010;(102):17. X-1, X-3, X-4, X-5.
892 Andrew MJ, Sullivan PB. Growth in cerebral palsy. Nutr Clin Pract. Aug. 2010;25(4):357-61. X-1. [pmid: 20702841].
893 Asgari S, Bassiouni H, Gizewski E, et al. AVM resection after radiation therapy—clinico-morphological features and microsurgical results. Neurosurg Rev. Jan. 2010;33(1):53-61. X-3, X-4. [pmid: 19669814].
894 Bhan A, Rao AD, Rao DS. Osteomalacia as a result of vitamin D deficiency. Endocrinol Metab Clin North Am. Jun. 2010;39(2):321-31. table of contents. X-3. [pmid: 20511054].
895 Calis EA, Veugelers R, Rieken R, et al. Energy intake does not correlate with nutritional state in children with severe generalized cerebral palsy and intellectual disability. Clin Nutr. Oct. 2010;29(5):617-21. X-4. [pmid: 20346547].
896 Clark M, Harris R, Jolleff N, et al. Worster-Drought syndrome: poorly recognized despite severe and persistent difficulties with feeding and speech. Dev Med Child Neurol. Jan. 2010;52(1):27-32. X-4. [pmid: 19824895].
897 Curtis JL, Wong G, Gutierrez I, et al. Pledgeted mattress sutures reduce recurrent reflux after laparoscopic Nissen fundoplication. J Pediatr Surg. Jun. 2010;45(6):1159-64. X-3. [pmid: 20620312].
898 Daviglus ML, Bell CC, Berrettini W, et al. NIH state-of-the-science conference statement: preventing Alzheimer's Disease and Cognitive Decline. NIH Consens State Sci Statements. Apr. 28. 2010;27(4). X-3, X-4. [pmid: 20445638].
899 Delgado MR, Hirtz D, Aisen M, et al. Pharmacologic treatment of spasticity in children and adolescents with cerebral palsy (an evidence-based review): report of the Quality Standards Subcommittee of the American Academy of Neurology and the Practice Committee of the Child Neurology Society. Neurology. Jan. 2010;74(4):336-43. X-4. [pmid: 20101040].
900 Donas KP, Rancic Z, Lachat M, et al. Novel sutureless telescoping anastomosis revascularization technique of supra-aortic vessels to simplify combined open endovascular procedures in the treatment of aortic arch pathologies. J Vasc Surg. Apr. 2010;51(4):836-41. X-3, X-4. [pmid: 20347679].
901 Elliott J, Smith M. The acute management of intracerebral hemorrhage: a clinical review. Anesth Analg. May. 1. 2010;110(5):1419-27. X-1. [pmid: 20332192].
902 Engelmann C, Gritsa S, Gratz KF, et al. Laparoscopic anterior hemifundoplication improves key symptoms without impact on GE in children with and children without neurodevelopmental delays. J Pediatr Gastroenterol Nutr. Oct. 2010;51(4):437-42. X-3, X-4, X-5. [pmid: 20531026].
903 Engelmann C, Gritsa S, Ure BM. Impact of laparoscopic anterior 270 degrees fundoplication on the quality of life and symptoms profile of neurodevelopmentally delayed versus neurologically unimpaired children and their parents. Surg Endosc. Jun. 2010;24(6):1287-95. X-3. [pmid: 20033727].
904 Erasmus CE, Van Hulst K, Van Den Hoogen FJ, et al. Thickened saliva after effective management of drooling with botulinum toxin A. Dev Med Child Neurol. Jun. 2010;52(6):e114-8. X-4. [pmid: 20163435].
905 Erkin G, Culha C, Ozel S, et al. Feeding and gastrointestinal problems in children with cerebral palsy. Int J Rehabil Res. 2010;33(3):218-24. X-4, X-5. [pmid: 20216224].
906 Field B, Scheinberg A, Cruickshank A. Health care services for adults with cerebral palsy. Aust Fam Physician. Mar. 2010;39(3):165-7. X-1, X-4. [pmid: 20369122].
907 Fortunato JE, Troy AL, Cuffari C, et al. Outcome after percutaneous endoscopic gastrostomy in children and young adults. J Pediatr Gastroenterol Nutr. Apr. 2010;50(4):390-3. X-3, X-4, X-5. [pmid: 20179645].
908 Freeman C, Ricevuto A, DeLegge MH. Enteral nutrition in patients with dementia and stroke. Curr Opin Gastroenterol. Mar. 2010;26(2):156-9. X-1. [pmid: 19907322].
909 Giambra BK, Meinzen-Derr J. Exploration of the relationships among medical health history variables and aspiration. Int J Pediatr Otorhinolaryngol. Apr. 2010;74(4):387-92. X-4. [pmid: 20163881].
910 Guimber D, Bourgois B, Beghin L, et al. Effect of multifibre mixture with prebiotic components on bifidobacteria and stool pH in tube-fed children. Br J Nutr. Nov. 2010;104(10):1514-22. X-3, X-4, X-5. [pmid: 20687970].
911 Hellwig JP. Morning sickness treatments. Nursing for Women's Health. 2010;14(6):447-53. X-1, X-3, X-4, X-5.
912 Henderson R. The effect of gastronomy tube feeding on body protein and bone mineralization in children with quadroplegic cerebral palsy. Dev Med Child Neurol. Nov. 2010;52(11):985. X-1, X-3, X-4. [pmid: 20561012].
913 Hoffman I, De Greef T, Haesendonck N, et al. Esophageal motility in children with suspected gastroesophageal reflux disease. J Pediatr Gastroenterol Nutr. Jun. 2010;50(6):601-8. X-4. [pmid: 20400913].
914 Iwanaka T, Kanamori Y, Sugiyama M, et al. Laparoscopic fundoplication for gastroesophageal reflux disease in infants and children. Surg Today. May. 2010;40(5):393-7. X-1. [pmid: 20425539].
915 Jones-Quaidoo SM, Yang S, Arlet V. Surgical management of spinal deformities in cerebral palsy. A review. J Neurosurg Spine. Dec. 2010;13(6):672-85. X-4. [pmid: 21121743].
916 Kawahara H, Mitani Y, Nose K, et al. Should fundoplication be added at the time of gastrostomy placement in patients who are neurologically impaired?. J Pediatr Surg. Dec. 2010;45(12):2373-6. X-3, X-4, X-5. [pmid: 21129548].
917 Kawahara H, Okuyama H, Nose K, et al. Physiological and clinical characteristics of gastroesophageal reflux after congenital diaphragmatic hernia repair. J Pediatr Surg. Dec. 2010;45(12):2346-50. X-3, X-4. [pmid: 21129542].
918 Krach LE, Kriel RL, Day SM, et al. Survival of individuals with cerebral palsy receiving continuous intrathecal baclofen treatment: a matched-cohort study. Dev Med Child Neurol. Jul. 2010;52(7):672-6. X-4. [pmid: 19811519].
919 Lv X, Jiang C, Li Y, et al. Clinical outcomes of endovascular treatment for intracranial pial arteriovenous fistulas. World Neurosurg. Apr. 2010;73(4):385-90. X-3, X-4. [pmid: 20849797].
920 Macchini F, Fava G, Selicorni A, et al. Barrett's esophagus and Cornelia de Lange Syndrome. Acta Paediatr. Sep. 2010;99(9):1407-10. X-3, X-4. [pmid: 20456260].
921 Madre C, Serhal L, Michaud L, et al. Prolonged enteral feeding is often required to avoid long-term nutritional and metabolic complications after esophagogastric dissociation. J Pediatr Gastroenterol Nutr. Mar. 2010;50(3):280-6. X-3, X-4, X-5. [pmid: 19668010].
922 Margaron FC, Oiticica C, Lanning DA. Robotic-assisted laparoscopic Nissen fundoplication with gastrostomy preservation in neurologically impaired children. J Laparoendosc Adv Surg Tech A. Jun. 2010;20(5):489-92. X-3, X-5. [pmid: 20518687].
923 McAfee PC, Cappuccino A, Cunningham BW, et al. Lower incidence of dysphagia with cervical arthroplasty compared with ACDF in a prospective randomized clinical trial. J Spinal Disord Tech. Feb. 2010;23(1):1-8. X-3, X-4. [pmid: 20051917].
924 Pearson EG, Downey EC, Barnhart DC, et al. Reflux esophageal stricture—a review of 30 years' experience in children. J Pediatr Surg. Dec. 2010;45(12):2356-60. X-3, X-4. [pmid: 21129544].
925 Rodrigo R, Cauli O, Gomez-Pinedo U, et al. Hyperammonemia induces neuroinflammation that contributes to cognitive impairment in rats with hepatic encephalopathy. Gastroenterology. Aug. 2010;139(2):675-84. X-3, X-4. [pmid: 20303348].
926 Rudnicki SA. Prevention and treatment of peripheral neuropathy after bariatric surgery. Curr Treat Options Neurol. Jan. 2010;12(1):29-36. X-1, X-3, X-4. [pmid: 20842487].
927 Russman BS. Intrathecal baclofen. Dev Med Child Neurol. Jul. 2010;52(7):601-2. X-1, X-3, X-4, X-5. [pmid: 19832881].
928 Rutz E, Brunner R. The pediatric LCP hip plate for fixation of proximal femoral osteotomy in cerebral palsy and severe osteoporosis. J Pediatr Orthop. Oct-Nov. 2010;30(7):726-31. X-4. [pmid: 20864861].
929 Saout V, Ombredane MP, Mouillie JM, et al. Patients in a permanent vegetative state or minimally conscious state in the Maine-et-Loire county of France: A cross-sectional, descriptive study. Ann Phys Rehabil Med. Mar. 2010;53(2):96-104. X-3, X-4. [pmid: 20149778].
930 Shah SR, Jegapragasan M, Fox MD, et al. A review of laparoscopic Nissen fundoplication in children weighing less than 5 kg. J Pediatr Surg. Jun. 2010;45(6):1165-8. X-3, X-4, X-5. [pmid: 20620313].
931 Shariff F, Kiely E, Curry J, et al. Outcome after laparoscopic fundoplication in children under 1 year. J Laparoendosc Adv Surg Tech A. Sep. 2010;20(7):661-4. X-3, X-4, X-5. [pmid: 20822420].
932 Sharp WG, Harker S, Jaquess DL. Comparison of bite-presentation methods in the treatment of food refusal. J Appl Behav Anal. 2010;43(4):739-43. X-5. [pmid: 21541159].
933 Simons JP, Mehta D, Mandell DL. Assessment of constipation in children with tracheostomy. Arch Otolaryngol Head Neck Surg. Jan. 2010;136(1):27-32. X-4. [pmid: 20083774].
934 Somerville H, O'Loughlin E. Gastrostomy feeding in cerebral palsy: enough and no more. Dev Med Child Neurol. Dec. 2010;52(12):1076. X-1, X-3, X-4, X-5. [pmid: 21175462].
935 Spentzas T, Auth M, Hess P, et al. Natural course following pediatric tracheostomy. J Intensive Care Med. Jan-Feb. 2010;25(1):39-45. X-4. [pmid: 20095079].
936 Srivastava R, Jackson WD, Barnhart DC. Dysphagia and gastroesophageal reflux disease: dilemmas in diagnosis and management in children with neurological impairment. Pediatr Ann. Apr. 2010;39(4):225-31. X-1, X-3, X-4, X-5. [pmid: 20411900].
937 Swiggum M, Hamilton ML, Gleeson P, et al. Pain assessment and management in children with neurologic impairment: a survey of pediatric physical therapists. Pediatr Phys Ther. Fall. 2010;22(3):330-5. X-4. [pmid: 20699786].
938 Thomas R, Barnes M. Life expectancy for people with disabilities. NeuroRehabilitation. 2010;27(2):201-9. X-3, X-4. [pmid: 20871150].
939 Veugelers R, Benninga MA, Calis EAC, et al. Prevalence and clinical presentation of constipation in children with severe generalized cerebral palsy. Dev Med Child Neurol. 2010;52(9):e221. X-4.
940 Viswanath N, Wong D, Channappa D, et al. Is prophylactic fundoplication necessary in neurologically impaired children?. Eur J Pediatr Surg. Jul. 2010;20(4):226-9. X-3, X-4, X-5. [pmid: 20496317].
941 Weber C, Dommerich S, Pau HW, et al. Limited mouth opening after primary therapy of head and neck cancer. Oral Maxillofac Surg. Sep. 2010;14(3):169-73. X-3, X-4. [pmid: 20358238].
942 Zaidi T, Sudall C, Kauffmann L, et al. Physical outcome and quality of life after total esophagogastric dissociation in children with severe neurodisability and gastroesophageal reflux, from the caregiver's perspective. J Pediatr Surg. Sep. 2010;45(9):1772-6. X-3, X-4, X-5. [pmid: 20850619].
943 Zhang Y, Liu J, Wang J, et al. Traditional Chinese Medicine for treatment of cerebral palsy in children: a systematic review of randomized clinical trials. J Altern Complement Med. Apr. 2010;16(4):375-95. X-4. [pmid: 20423208].
944 Abla AA, Lekovic GP, Turner JD, et al. Advances in the treatment and outcome of brainstem cavernous malformation surgery: a single-center case series of 300 surgically treated patients. Neurosurgery. Feb. 2011;68(2):403-14. discussion 14-5. X-3, X-4. [pmid: 21654575].
945 Aquilani R, Sessarego P, Iadarola P, et al. Nutrition for brain recovery after ischemic stroke: an added value to rehabilitation. Nutr Clin Pract. Jun. 2011;26(3):339-45. X-3. [pmid: 21586419].
946 Benigni I, Devos P, Rofidal T, et al. The CP-MST, a malnutrition screening tool for institutionalized adult cerebral palsy patients. Clin Nutr. Dec. 2011;30(6):769-73. X-4. [pmid: 21764187].
947 Berry JG, Agrawal R, Kuo DZ, et al. Characteristics of hospitalizations for patients who use a structured clinical care program for children with medical complexity. J Pediatr. Aug. 2011;159(2):284-90. X-3, X-4, X-5. [pmid: 21429511].
948 Brun R, Staller K, Viner S, et al. Endoscopically assisted water perfusion esophageal manometry with minimal sedation: technique, indications, and implication on the clinical management. J Clin Gastroenterol. Oct. 2011;45(9):759-63. X-3, X-4. [pmid: 21602703].
949 Clancy KJ, Hustad KC. Longitudinal changes in feeding among children with cerebral palsy between the ages of 4 and 7 years. Dev Neurorehabil. Aug. 2011;14(4):191-8. X-4. [pmid: 21732803].
950 Corrigan ML, Escuro AA, Celestin J, et al. Nutrition in the stroke patient. Nutr Clin Pract. Jun. 2011;26(3):242-52. X-1. [pmid: 21586409].
951 Cu SR, Sidman JD. Rates and risks of gastrostomy tubes in infants with cleft palate. Arch Otolaryngol Head Neck Surg. Mar. 2011;137(3):275-81. X-3. [pmid: 21422313].
952 D'Abbicco D, Praino S, Amoruso M, et al. “Syndrome in syndrome”: Wernicke syndrome due to afferent loop syndrome. Case report and review of the literature. G Chir. Nov-Dec. 2011;32(11-12):479-82. X-3. [pmid: 22217376].
953 de Oliveira Andrade PM, de Oliveira Ferreira F, Haase VG. Multidisciplinary perspective for cerebral palsy assessment after an international, classification of functioning, disability and health training. Dev Neurorehabil. 2011;14(4):199-207. X-3, X-4. [pmid: 21732804].
954 Drennan V. Research news. Primary Health Care. 2011;21(6):13. X-1, X-3, X-4, X-5.
955 Durai R, Ng PC. Simple technique of selecting the correct feeding gastrostomy button. Acta Chir Belg. Sep-Oct. 2011;111(5):351-3. X-1, X-3, X-4, X-5. [pmid: 22191144].
956 Fairhurst C. Cerebral palsy: the whys and hows. Arch Dis Child Educ Pract Ed. 2011. Nov. 4. X-1, X-3, X-4, X-5. [pmid: 22058069].
957 Foletta VC, White LJ, Larsen AE, et al. The role and regulation of MAFbx/atrogin-1 and MuRF1 in skeletal muscle atrophy. Pflugers Arch. Mar. 2011;461(3):325-35. X-3. [pmid: 21221630].
958 Fortunato JE, Cuffari C. Outcomes of percutaneous endoscopic gastrostomy in children. Curr Gastroenterol Rep. Jun. 2011;13(3):293-9. X-1. [pmid: 21409518].
959 Gadit A. Schizophrenia and Parkinson's disease: challenges in management. BMJ Case Rep. 2011;2011. X-3, X-4. [pmid: 22669999].
960 Genton L, Pichard C. Protein catabolism and requirements in severe illness. Int J Vitam Nutr Res. Mar. 2011;81(2-3):143-52. X-3. [pmid: 22139565].
961 Giordano-Nappi JH, Maluf-Filho F, Ishioka S, et al. A new large-caliber trocar for percutaneous endoscopic gastrostomy by the introducer technique in head and neck cancer patients. Endoscopy. Sep. 2011;43(9):752-8. X-3, X-4, X-5. [pmid: 21656456].
962 Hay N, Penn C. Botox(®) to reduce drooling in a paediatric population with neurological impairments: a Phase I study. Int J Lang Commun Disord. Sep-Oct. 2011;46(5):550-63. X-3, X-4, X-5. [pmid: 21899672].
963 Holt RL, Mikati MA. Care for child development: basic science rationale and effects of interventions. Pediatr Neurol. Apr. 2011;44(4):239-53. X-1. [pmid: 21397164].
964 Kunkel SD, Suneja M, Ebert SM, et al. mRNA expression signatures of human skeletal muscle atrophy identify a natural compound that increases muscle mass. Cell Metab. Jun. 8. 2011;13(6):627-38. X-3, X-4. [pmid: 21641545].
965 Magnuson B, Peppard A, Auer Flomenhoft D. Hypocaloric considerations in patients with potentially hypometabolic disease States. Nutr Clin Pract. Jun. 2011;26(3):253-60. X-1, X-4. [pmid: 21586410].
966 Mahant S, Pastor AC, Deoliveira L, et al. Well-being of children with neurologic impairment after fundoplication and gastrojejunostomy tube feeding. Pediatrics. Aug. 2011;128(2):e395-403. X-3, X-4, X-5. [pmid: 21768323].
967 Martins JR, Shiroma GM, Horie LM, et al. Factors leading to discrepancies between prescription and intake of enteral nutrition therapy in hospitalized patients. Nutrition. 2011. Nov. 24. X-3, X-5. [pmid: 22119484].
968 McKiernan SH, Colman RJ, Lopez M, et al. Caloric restriction delays aging-induced cellular phenotypes in rhesus monkey skeletal muscle. Exp Gerontol. Jan. 2011;46(1):23-9. X-3, X-4. [pmid: 20883771].
969 Nacci A, Fattori B, Segnini G, et al. Respiratory retraining therapy in long-term treatment of paradoxical vocal fold dysfunction. Folia Phoniatr Logop. 2011;63(3):134-41. X-3, X-4. [pmid: 20938193].
970 Obholzer RJ, Hornigold R, Connor S, et al. Classification and management of cervical paragangliomas. Ann R Coll Surg Engl. Nov. 2011;93(8):596-602. X-3, X-4. [pmid: 22041235].
971 O'Flaherty SJ, Janakan V, Morrow AM, et al. Adverse events and health status following botulinum toxin type A injections in children with cerebral palsy. Dev Med Child Neurol. Feb. 2011;53(2):125-30. X-4. [pmid: 21244412].
972 Omeroglu H, Inan U, Turgut K, et al. Preoperative hematological assessment of pediatric patients with cerebral palsy. Acta Orthop Traumatol Turc. 2011;45(1):1-5. X-4. [pmid: 21478656].
973 Park JH, Rhie S, Jeong SJ. Percutaneous endoscopic gastrostomy in children. Korean J Pediatr. Jan. 2011;54(1):17-21. X-3, X-4, X-5. [pmid: 21359056].
974 Rommel N. Pharyngo-esophageal motility in neurologically impaired children. J Pediatr Gastroenterol Nutr. Dec. Suppl 2. 2011;53:S21-2. X-1, X-3, X-4, X-5. [pmid: 22235456].
975 Rosenberger LH, Newhook T, Schirmer B, et al. Late accidental dislodgement of a percutaneous endoscopic gastrostomy tube: an underestimated burden on patients and the health care system. Surg Endosc. Oct. 2011;25(10):3307-11. X-3, X-4, X-5. [pmid: 21533968].
976 Streja E, Molnar MZ, Kovesdy CP, et al. Associations of pretransplant weight and muscle mass with mortality in renal transplant recipients. Clin J Am Soc Nephrol. Jun. 2011;6(6):1463-73. X-3, X-4. [pmid: 21415312].
977 Tawk RG, Tummala RP, Memon MZ, et al. Utility of pharmacologic provocative neurological testing before embolization of occipital lobe arteriovenous malformations. World Neurosurg. Sep-Oct. 2011;76(3-4):276-81. X-3, X-4. [pmid: 21986424].
978 Toporowska-Kowalska E, Gebora-Kowalska B, Jablonski J, et al. Influence of percutaneous endoscopic gastrostomy on gastro-oesophageal reflux evaluated by multiple intraluminal impedance in children with neurological impairment. Dev Med Child Neurol. Oct. 2011;53(10):938-43. X-4. [pmid: 21752017].
979 Tsai CY, Shyr YM, Chiu WC, et al. Bone changes in the mandible following botulinum neurotoxin injections. Eur J Orthod. Apr. 2011;33(2):132-8. X-3, X-4. [pmid: 20884720].
980 Tuvdendorj D, Chinkes DL, Zhang XJ, et al. Skeletal muscle is anabolically unresponsive to an amino acid infusion in pediatric burn patients 6 months postinjury. Ann Surg. Mar. 2011;253(3):592-7. X-3, X-4. [pmid: 21263308].
981 Weir KA, McMahon S, Taylor S, et al. Oropharyngeal aspiration and silent aspiration in children. Chest. Sep. 2011;140(3):589-97. X-4. [pmid: 21436244].
982 Westbom L, Bergstrand L, Wagner P, et al. Survival at 19 years of age in a total population of children and young people with cerebral palsy. Dev Med Child Neurol. Sep. 2011;53(9):808-14. X-4, X-5. [pmid: 21745199].
983 Whittingham Wee D, Boyd R. Systematic review of the efficacy of parenting interventions for children with cerebral palsy. Child: Care, Health & Development. 2011;37(4):475-83. X-10.
984 Wockenforth R, Gillespie CS, Jaffray B. Survival of children following Nissen fundoplication. Br J Surg. May. 2011;98(5):680-5. X-3. [pmid: 21351077].
985 Zoing M, Kiernan M. Motor neurone disease - caring for the patient in general practice. Aust Fam Physician. Dec. 2011;40(12):962-6. X-1, X-3, X-4. [pmid: 22146323].
986 Andrew MJ, Parr JR, Sullivan PB. Feeding difficulties in children with cerebral palsy. Arch Dis Child Educ Pract Ed. 2012. Jan. 31. X-1. [pmid: 22293504].
987 Arrowsmith FE, Allen JR, Gaskin KJ, et al. Nutritional rehabilitation increases the resting energy expenditure of malnourished children with severe cerebral palsy. Dev Med Child Neurol. Feb. 2012;54(2):170-5. X-4, X-5. [pmid: 22224669].
988 Bassani L, Harter DH. Paraspinal subfascial placement of lumbar intrathecal baclofen catheters: short-term outcomes of a novel technique. J Neurosurg Pediatr. Jan. 2012;9(1):93-8. X-4. [pmid: 22208328].
989 Becher JC, Bhushan SS, Lyon AJ. Unexpected collapse in apparently healthy newborns—a prospective national study of a missing cohort of neonatal deaths and near-death events. Arch Dis Child Fetal Neonatal Ed. Jan. 2012;97(1):F30-4. X-3, X-4. [pmid: 21715368].
990 Brun AC, Stordal K, Johannesdottir GB, et al. The effect of protein composition in liquid meals on gastric emptying rate in children with cerebral palsy. Clin Nutr. Feb. 2012;31(1):108-12. X-4. [pmid: 21835514].
991 Case-Smith J, DeLuca SC, Stevenson R, et al. Multicenter randomized controlled trial of pediatric constraint-induced movement therapy: 6-month follow-up. Am J Occup Ther. Jan-Feb. 2012;66(1):15-23. X-4, X-5. [pmid: 22389937].
992 Chen S, Jarboe MD, Teitelbaum DH. Effectiveness of a transluminal endoscopic fundoplication for the treatment of pediatric gastroesophageal reflux disease. Pediatr Surg Int. Mar. 2012;28(3):229-34. X-3, X-5. [pmid: 22124618].
993 Dahlseng MO, Finbraten AK, Juliusson PB, et al. Feeding problems, growth and nutritional status in children with cerebral palsy. Acta Paediatr. Jan. 2012;101(1):92-8. X-4, X-5. [pmid: 21767308].
994 DeLuca SC, Case-Smith J, Stevenson R, et al. Constraint-induced movement therapy (CIMT) for young children with cerebral palsy: effects of therapeutic dosage. J Pediatr Rehabil Med. 2012;5(2):133-42. X-4. [pmid: 22699104].
995 Erasmus CE, van Hulst K, Scheffer AR, et al. What could predict effectiveness of Botulinum Toxin to treat drooling: a search for evidence of discriminatory factors on the level of body functions or structures. Eur J Paediatr Neurol. Mar. 2012;16(2):126-31. X-4, X-5. [pmid: 21783393].
996 Ferm U, Ahlsen E, Bjorck-Akesson E. Patterns of communicative interaction between a child with severe speech and physical impairments and her caregiver during a mealtime activity. J Intellect Dev Disabil. 2012;37(1):11-26. X-3, X-4, X-5. [pmid: 22300257].
997 Fonseca H, Powers SK, Goncalves D, et al. Physical inactivity is a major contributor to ovariectomy-induced sarcopenia. Int J Sports Med. Apr. 2012;33(4):268-78. X-3, X-4. [pmid: 22261826].
998 Groen BB, Res PT, Pennings B, et al. Intragastric protein administration stimulates overnight muscle protein synthesis in elderly men. Am J Physiol Endocrinol Metab. Jan. 2012;302(1):E52-60. X-3, X-4. [pmid: 21917635].
999 Gupta M, Iyer N, Das D, et al. Analysis of different treatment protocols for fractures of condylar process of mandible. J Oral Maxillofac Surg. Jan. 2012;70(1):83-91. X-3, X-4. [pmid: 21549492].
1000 Karagiozoglou-Lampoudi T, Daskalou E, Vargiami E, et al. Identification of feeding risk factors for impaired nutrition status in paediatric patients with cerebral palsy. Acta Paediatr. Jun. 2012;101(6):649-54. X-4. [pmid: 22404086].
1001 Khaing ZZ, Geissler SA, Jiang S, et al. Assessing forelimb function after unilateral cervical spinal cord injury: novel forelimb tasks predict lesion severity and recovery. J Neurotrauma. Feb. 10. 2012;29(3):488-98. X-1, X-3, X-4. [pmid: 22022897].
1002 Kuhn AL, Hertel F, Boulanger T, et al. Vitamin B1 in the treatment of Wernicke's encephalopathy due to hyperemesis after gastroplasty. J Clin Neurosci. 2012. Jun. 20. X-3, X-4. [pmid: 22727204].
1003 Lepski G, Honegger J, Liebsch M, et al. Safe resection of arteriovenous malformations in eloquent motor areas aided by functional imaging and intraoperative monitoring. Neurosurgery. Jun. 2012;70(2 Suppl Operative):276-88. discussion 88-9. X-3, X-4. [pmid: 21946511].
1004 Lunardi AC, Miranda CS, Silva KM, et al. Weakness of expiratory muscles and pulmonary complications in malnourished patients undergoing upper abdominal surgery. Respirology. Jan. 2012;17(1):108-13. X-3, X-4, X-5. [pmid: 21883675].
1005 Martinez-Biarge M, Diez-Sebastian J, Wusthoff CJ, et al. Feeding and communication impairments in infants with central grey matter lesions following perinatal hypoxic-ischaemic injury. Eur J Paediatr Neurol. 2012. May. 30. X-4, X-5. [pmid: 22658307].
1006 McGowan JE, Fenton TR, Wade AW, et al. An exploratory study of sodium, potassium, and fluid nutrition status of tube-fed nonambulatory children with severe cerebral palsy. Appl Physiol Nutr Metab. Aug. 2012;37(4):715-23. X-4, X-5. [pmid: 22667347].
1007 Neff LP, Becher RD, Blackham AU, et al. A novel antireflux procedure: gastroplasty with restricted antrum to control emesis (GRACE). J Pediatr Surg. Jan. 2012;47(1):99-106. X-3, X-4, X-5. [pmid: 22244400].
1008 O'Loughlin EV, Somerville H, Shun A, et al. Antireflux surgery in children with neurological impairment: caregiver perceptions and complications. J Pediatr Gastroenterol Nutr. 2012. Jul. 9. X-3, X-5. [pmid: 22785414].
1009 Rigolet A, Musset L, Dubourg O, et al. Inflammatory myopathies with anti-Ku antibodies: a prognosis dependent on associated lung disease. Medicine. Mar. 2012;91(2):95-102. X-3, X-4. [pmid: 22391471].
1010 Rollins MD, Yoder BA, Moore KR, et al. Utility of neuroradiographic imaging in predicting outcomes after neonatal extracorporeal membrane oxygenation. J Pediatr Surg. Jan. 2012;47(1):76-80. X-3, X-4. [pmid: 22244396].
1011 Santoro A, Dasso Lang MB, Moretti E, et al. A proposed multidisciplinary approach for identifying feeding abnormalities in children with cerebral palsy. J Child Neurol. 2012;27(6):708-12. 2012-13445-003. X-4, X-5. [pmid: 22019841].
1012 Savage K, Kritas S, Schwarzer A, et al. Whey- vs casein-based enteral formula and gastrointestinal function in children with cerebral palsy. JPEN J Parenter Enteral Nutr. Jan. 2012;36(1 Suppl):118S-23S. X-5. [pmid: 22237871].
1013 Schmitt F, Caldari D, Corradini N, et al. Tolerance and efficacy of preventive gastrostomy feeding in pediatric oncology. Pediatr Blood Cancer. 2012. Apr. 10. X-3, X-4, X-5. [pmid: 22492612].
1014 Schoendorfer N, Tinggi U, Sharp N, et al. Protein levels in enteral feeds: do these meet requirements in children with severe cerebral palsy?. Br J Nutr. May. 2012;107(10):1476-81. X-4, X-5. [pmid: 22050917].
1015 Sridhar A, Bhandari JK, Lewis G, et al. Tuberculous radiculomyelitis presenting as urinary retention in a child with Down's syndrome. BMJ Case Rep. 2012. X-3, X-4. [pmid: 22602831].
1016 Tuzun EH, Guven DK, Eker L, et al. Nutritional status of children with cerebral palsy in Turkey. Disabil Rehabil. 2012. Jun. 23. X-4. [pmid: 22725837].
1017 van Venrooij LM, Verberne HJ, de Vos R, et al. Postoperative loss of skeletal muscle mass, complications and quality of life in patients undergoing cardiac surgery. Nutrition. Jan. 2012;28(1):40-5. X-3, X-4. [pmid: 21621393].
1018 Viswanathan A, Abd-El-Barr MM, Doppenberg E, et al. Initial experience with the use of an expandable titanium cage as a vertebral body replacement in patients with tumors of the spinal column: a report of 95 patients. Eur Spine J. Jan. 2012;21(1):84-92. X-3. [pmid: 21681631].