# Quality of the Literature

Table E-1 Quality assessment of randomized controlled trials

Author, Year | Sequence Generation | Allocation Concealment | Selective Reporting | Other Bias | Blinding of Participants/Personnel | Blinding of Outcome Assessment | Incomplete Outcome Data | Quality Rating
Durante 2007^1^ | Low | Low | Low | Unclear | High | Unclear | Low | Fair

Low=low risk of bias; High=high risk of bias

Table E-2 Quality assessment of cohort studies

Domain | Selection | | | | Comparability | Outcome | | | Quality Rating
Author, Year | Representativeness of exposed cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | Comparability of cohorts | Assessment of outcome | Duration of follow-up | Adequacy of follow-up of cohorts
Sullivan 2006^2^ | - | + | + | + | + | + | + | - | Fair

Table E-3 Quality assessment of systematic reviews

Domain | A priori design | Duplicate study selection/extraction | Comprehensive literature search | Status of publication as exclusion criterion | Included and excluded studies provided | Characteristics of included studies provided | Quality assessed | Quality used appropriately | Synthesis methods appropriate | Publication bias assessed | Conflict of interest stated | Rating
Author, Year
Snider, 2011^3^ | + | NR | + | - | + | + | + | + | + | - | + | Good

NA=not applicable; NR=not reported/can't answer +=yes, -=no,

Table E-4 Quality assessment of case series

Domain | Selection bias & confounding | Performance bias | | Attrition bias | | Detection bias | | | | | | | | | | Reporting bias
Author, Year | Confounding and modifying variables considered | Impact of concurrent interventions ruled out | Variation compromised conclusions | High rate of attrition | Attrition resulted in group differences | Outcome assessors blinded | Inclusion/exclusion assessed with valid & reliable measures | Measures consistent across all study participants | Interventions measured with valid & reliable measures | Interventions consistent across all study participants | Outcomes assessed with valid & reliable measures | Outcome assessment consistent across all study participants | Confounders assessed with valid & reliable measures | Confounding variables consistent across all study participants | Accounted for secular trends & regression to mean | Outcomes pre-specified | Harms pre-specified | Pre-specified outcomes reported
Adams, 2011^4^ | Yes | No | No | Yes | NR | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Thomson, 2011^5^ | No | Yes | No | No | NA | No | No | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes
Arrowsmith, 2010^6^ | No | No | No | No | No | No | Yes | Yes | Yes | Yes | Yes | Yes | NA | NA | No | Yes | No | Yes
Vernon-Roberts 2010^7^ | No | Yes | Yes | No | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes | No | Yes
Mahant 2009^8^ | Yes | No | No | Yes | NR | No | No | Yes | Yes | No | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Cheung, 2006^9^ | No | No | No | No | NA | No | Yes | Yes | Yes | Yes | Yes | Yes | No | No | No | Yes | Yes | Yes
Sullivan, 2004^10-12^ | Yes | No | No | Yes | NR | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Brant, 1999^13^ | Yes | No | Yes | No | NA | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Rempel, 1988^14^ | Yes | No | NR | Yes | NR | No | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | No | Yes | No | Yes
Shapiro, 1986^15^ | Yes | No | No | No | NA | No | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | No | Yes

NA=not applicable, NR=not rated

## References

1 Durante AP, Schettini ST, Fagundes DJ. Vertical gastric plication versus Nissen fundoplication in the treatment of gastroesophageal reflux in children with cerebral palsy. Sao Paulo Med J. Jan. 4. 2007;125(1):15-21. [pmid: 17505680].
2 Sullivan PB, Alder N, Bachlet AM, et al. Gastrostomy feeding in cerebral palsy: too much of a good thing?. Dev Med Child Neurol. Nov. 2006;48(11):877-82. [pmid: 17044953].
3 Snider, Majnemer A, Darsaklis V. Feeding Interventions for Children With Cerebral Palsy: A Review of the Evidence. Physical & Occupational Therapy in Pediatrics. 2011;31(1):58-77. [pmid: 20950250].
4 Adams MS, Khan NZ, Begum SA, et al. Feeding difficulties in children with cerebral palsy: low-cost caregiver training in Dhaka, Bangladesh. Child Care Health Dev. 2011. Nov. 15. [pmid: 22082112].
5 Thomson M, Rao P, Rawat D, et al. Percutaneous endoscopic gastrostomy and gastro-oesophageal reflux in neurologically impaired children. World J Gastroenterol. Jan. 14. 2011;17(2):191-6. [pmid: 21245991].
6 Arrowsmith F, Allen J, Gaskin K, et al. The effect of gastrostomy tube feeding on body protein and bone mineralization in children with quadriplegic cerebral palsy. Dev Med Child Neurol. Nov. 2010;52(11):1043-7. [pmid: 20497453].
7 Vernon-Roberts A, Wells J, Grant H, et al. Gastrostomy feeding in cerebral palsy: enough and no more. Dev Med Child Neurol. Dec. 2010;52(12):1099-105. [pmid: 20964670].
8 Mahant S, Friedman JN, Connolly B, et al. Tube feeding and quality of life in children with severe neurological impairment. Arch Dis Child. Sep. 2009;94(9):668-73. [pmid: 19465586].
9 Cheung KM, Tse HW, Tse PW, et al. Nissen fundoplication and gastrostomy in severely neurologically impaired children with gastroesophageal reflux. Hong Kong Med J. Aug. 2006;12(4):282-8. [pmid: 16912355].
10 Sullivan PB, Juszczak E, Bachlet AM, et al. Impact of gastrostomy tube feeding on the quality of life of carers of children with cerebral palsy. Dev Med Child Neurol. Dec. 2004;46(12):796-800. [pmid: 15581151].
11 Sullivan PB, Juszczak E, Bachlet AM, et al. Gastrostomy tube feeding in children with cerebral palsy: a prospective, longitudinal study. Dev Med Child Neurol. Feb. 2005;47(2):77-85. [pmid: 15707230].
12 Sullivan PB, Morrice JS, Vernon-Roberts A, et al. Does gastrostomy tube feeding in children with cerebral palsy increase the risk of respiratory morbidity?. Arch Dis Child. Jun. 2006;91(6):478-82. [pmid: 16446283].
13 Brant CQ, Stanich P, Ferrari AP Jr. Improvement of children's nutritional status after enteral feeding by PEG: an interim report. Gastrointest Endosc. Aug. 1999;50(2):183-8. [pmid: 10425410].
14 Rempel GR, Colwell SO, Nelson RP. Growth in children with cerebral palsy fed via gastrostomy. Pediatrics. Dec. 1988;82(6):857-62. [pmid: 3186375].
15 Shapiro BK, Green P, Krick J, et al. Growth of severely impaired children: neurological versus nutritional factors. Dev Med Child Neurol. Dec. 1986;28(6):729-33. [pmid: 3817311].