# Tools Used To Assess the Quality of the Literature

Newcastle-Ottawa Quality Assessment Form for Cohort Studies

Minimum Criteria to Assess Risk of Bias in Case Series

Cochrane Collaboration modified tool for assessing risk of bias for RCTs, PART I

Cochrane Collaboration modified tool for assessing risk of bias for RCTs, PART II

Quality Assessment Form for Systematic Reviews (AMSTAR)