# Evidence Table

Table C-1 Evidence table—Interventions for feeding and nutrition in cerebral palsy

## References

1 Durante AP, Schettini ST, Fagundes DJ. Vertical gastric plication versus Nissen fundoplication in the treatment of gastroesophageal reflux in children with cerebral palsy. Sao Paulo Med J. Jan. 4. 2007;125(1):15-21. [pmid: 17505680].
2 Sullivan PB, Alder N, Bachlet AM, et al. Gastrostomy feeding in cerebral palsy: too much of a good thing?. Dev Med Child Neurol. Nov. 2006;48(11):877-82. [pmid: 17044953].
3 Sullivan PB, Juszczak E, Bachlet AM, et al. Gastrostomy tube feeding in children with cerebral palsy: a prospective, longitudinal study. Dev Med Child Neurol. Feb. 2005;47(2):77-85. [pmid: 15707230].
4 Sullivan PB, Juszczak E, Bachlet AM, et al. Impact of gastrostomy tube feeding on the quality of life of carers of children with cerebral palsy. Dev Med Child Neurol. Dec. 2004;46(12):796-800. [pmid: 15581151].
5 Sullivan PB, Morrice JS, Vernon-Roberts A, et al. Does gastrostomy tube feeding in children with cerebral palsy increase the risk of respiratory morbidity?. Arch Dis Child. Jun. 2006;91(6):478-82. [pmid: 16446283].
6 Adams MS, Khan NZ, Begum SA, et al. Feeding difficulties in children with cerebral palsy: low-cost caregiver training in Dhaka, Bangladesh. Child Care Health Dev. 2011. Nov. 15. [pmid: 22082112].
7 Thomson M, Rao P, Rawat D, et al. Percutaneous endoscopic gastrostomy and gastro-oesophageal reflux in neurologically impaired children. World J Gastroenterol. Jan. 14. 2011;17(2):191-6. [pmid: 21245991].
8 Arrowsmith F, Allen J, Gaskin K, et al. The effect of gastrostomy tube feeding on body protein and bone mineralization in children with quadriplegic cerebral palsy. Dev Med Child Neurol. Nov. 2010;52(11):1043-7. [pmid: 20497453].
9 Vernon-Roberts A, Wells J, Grant H, et al. Gastrostomy feeding in cerebral palsy: enough and no more. Dev Med Child Neurol. Dec. 2010;52(12):1099-105. [pmid: 20964670].
10 Mahant S, Friedman JN, Connolly B, et al. Tube feeding and quality of life in children with severe neurological impairment. Arch Dis Child. Sep. 2009;94(9):668-73. [pmid: 19465586].
11 Cheung KM, Tse HW, Tse PW, et al. Nissen fundoplication and gastrostomy in severely neurologically impaired children with gastroesophageal reflux. Hong Kong Med J. Aug. 2006;12(4):282-8. [pmid: 16912355].
12 Brant CQ, Stanich P, Ferrari AP Jr. Improvement of children's nutritional status after enteral feeding by PEG: an interim report. Gastrointest Endosc. Aug. 1999;50(2):183-8. [pmid: 10425410].
13 Rempel GR, Colwell SO, Nelson RP. Growth in children with cerebral palsy fed via gastrostomy. Pediatrics. Dec. 1988;82(6):857-62. [pmid: 3186375].
14 Shapiro BK, Green P, Krick J, et al. Growth of severely impaired children: neurological versus nutritional factors. Dev Med Child Neurol. Dec. 1986;28(6):729-33. [pmid: 3817311].