# Data Extraction Forms

Abstract Review Form

Full Text Review Form

Relevance Review Form for Previous Systematic Reviews