# Search Strategies

Last updated July 16, 2012

Table A-1 PubMed search strategies (pubmed.gov interface)

Search terms | | Search results
#1 | “Neurologic Manifestations”[Mesh:NoExp] OR “Neuromuscular Manifestations”[mh] OR (neurologic^*^[tiab] AND (impairment^*^[tiab] OR impaired[tiab] OR problem^*^[tiab] OR deficit^*^[tiab])) | 91,378
#2 | (“Surgical Procedures, Operative”[MeSH] OR surgery[tiab] OR gastrostomy[tiab] OR “gastrostomy”[MeSH] OR “PEG tube”[tiab] OR “tube feeding”[tiab] OR “tube fed”[tiab] OR “tube-fed”[tiab] OR “G-tube”[tiab] OR “G tube”[tiab] OR “J-tube”[tiab] OR “J tube”[tiab] OR “gj tube”[tiab] OR “g-j tube”[tiab] OR “gastrostomy-jejunostomy tube”[tiab] OR “Jejunostomy”[Mesh] OR jejunostomy[tiab] OR gastrojejunostomy[tiab] OR “nasogastric tube”[tiab] OR “ng tube”[tiab] OR “nasogastric feeding”[tiab] OR “Enteral Nutrition”[mesh] OR “enteral feeding”[tiab] OR “enteral nutrition”[tiab] OR “Fundoplication”[mesh] OR fundoplication[tiab] OR antireflux[tiab] OR “Gastroesophageal Reflux/surgery”[Mesh] OR (reflux[tiab] AND (surgery[tiab] OR surgical[tiab])) | 2,500,978
#3 | (“Nutritional Support”[MeSH] OR “Nutritional Status”[MeSH] OR Eating[MeSH] OR “Deglutition disorders”[MeSH] OR feeding[tiab] OR nutrition[tiab] OR nutritional[tiab] OR eating[tiab] OR “Energy Intake”[mesh] OR “Feeding Behavior”[MH]) | 464,9000
#4 | #1 AND #2 AND #3 AND english[la] | 732
#5 | #3 AND editorial[pt] | 0
#6 | #3 AND letter[pt] | 4
#7 | #3 AND comment[pt] | 3
#8 | #3 AND case reports[pt] | 143
#9 | #3 AND review[pt] | 96
#10 | #3 AND news[pt] | 0
#11 | #3 AND guideline[pt] | 1
#12 | #3 AND practice guideline[pt] | 1
#13 | #3 AND historical article[pt] | 0
#14 | #3 AND jsubsetk | 0
#15 | #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 230
#16 | #4 NOT #15 | 502
#17 | #16 AND (“1980”[PDAT] : “3000”[PDAT]) [limits to 1980 to present] | 477
| [10 new items since May 2012 search]

Key: [mh] medical subject heading; [sh] subheading; [tiab] keyword in title or abstract; [la] language; [pt] publication type; jsubsetk consumer health subset; [PDAT] publication date.

* numbers may not add up as some records are indexed in multiple publication types.

Last updated July 16, 2012

Table A-2 PubMed search strategies (pubmed.gov interface)

Search terms | | Search results
#1 | (“Cerebral Palsy/drug therapy”[MeSH] OR “Cerebral Palsy/surgery”[MeSH] OR “Cerebral Palsy/diet therapy”[MeSH] OR “Cerebral Palsy/therapy”[MeSH]) OR ((“cerebral palsy”[MeSH] OR “cerebral palsy”[tiab]) AND (“Surgical Procedures, Operative”[MeSH] OR surgery[tiab] OR “Drug Therapy”[MeSH] OR “drug”[tiab] OR “pharmacotherapy”[tiab] OR gastrostomy[tiab] OR “gastrostomy”[MeSH] OR “PEG tube”[tiab] OR “tube feeding”[tiab] OR “tube fed”[tiab] OR “tube-fed”[tiab] OR “G-tube”[tiab] OR “G tube”[tiab] OR “J-tube”[tiab] OR “J tube”[tiab] OR “gj tube”[tiab] OR “g-j tube”[tiab] OR “gastrostomy-jejunostomy tube”[tiab] OR “Jejunostomy”[Mesh] OR jejunostomy[tiab] OR gastrojejunostomy[tiab] OR “nasogastric tube”[tiab] OR “ng tube”[tiab] OR “nasogastric feeding”[tiab] OR “Enteral Nutrition”[mesh] OR “enteral feeding”[tiab] OR “enteral nutrition”[tiab] OR “Orthodontic Appliances”[MeSH] OR “intraoral appliance”[tiab] OR “intraoral appliances”[tiab] OR “oral appliance”[tiab] OR “oral appliances”[tiab] OR sensorimotor[tiab] OR “Feedback, Sensory”[mesh] OR “Posture”[mesh] OR posture[tiab] OR positioning[tiab] OR position[tiab] OR “Patient Positioning”[mesh] OR “Food, Fortified”[mesh] OR “Food, Formulated”[mesh] OR “Food Additives”[mesh] OR ((food[tiab] OR “Food”[mesh]) AND (handling[tiab] OR thickness[tiab] OR thickener^*^[tiab] OR consistency[tiab] OR additive[tiab] OR texture^*^[tiab] OR composition[tiab] OR presentation[tiab] OR preparation[tiab])) OR “ThickenUp”[tiab] OR “Thick-It”[tiab] OR SimplyThick[tiab] OR “Thick and Easy”[tiab] OR “feeding device”[tiab] OR “feeding devices”[tiab] OR “Self-Help Devices”[mesh] OR “Occupational Therapy”[mesh] OR “occupational therapy”[tiab] OR “Behavior Therapy”[mesh] OR “behavior therapy”[mesh] OR “behavioral therapy”[tiab] OR “Fundoplication”[mesh] OR fundoplication[tiab] OR antireflux[tiab] OR “Gastroesophageal Reflux/surgery”[Mesh] OR (reflux[tiab] AND (surgery[tiab] OR surgical[tiab])) OR “Family Therapy”[mesh] OR “family therapy”[tiab] OR ((“Parenting”[mesh] OR parent^*^[tiab] OR family[tiab] OR caregiver^*^[tiab] OR Caregivers[mesh]) AND (behavior^*^[tiab] OR therapy[tiab] OR intervention^*^[tiab])))) | 8,232
#2 | (“Nutritional Support”[MeSH] OR “Nutritional Status”[MeSH] OR Eating[MeSH] OR “Deglutition disorders”[MeSH] OR feeding[tiab] OR nutrition[tiab] OR nutritional[tiab] OR eating[tiab] OR “Energy Intake”[mesh] OR “Feeding Behavior”[MH]) | 464,900
#3 | #1 AND #2 AND english[la] | 363
#4 | #3 AND editorial[pt] | 2
#5 | #3 AND letter[pt] | 2
#6 | #3 AND comment[pt] | 7
#7 | #3 AND case reports[pt] | 56
#8 | #3 AND review[pt] | 49
#9 | #3 AND news[pt] | 1
#10 | #3 AND guideline[pt] | 1
#11 | #3 AND practice guideline[pt] | 0
#12 | #3 AND meta-analysis[pt] | 1
#13 | #3 AND historical article[pt] | 1
#14 | #3 AND jsubsetk | 0
#15 | #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 111
#16 | #3 NOT #15 | 252
#17 | #16 AND (“1980”[PDAT] : “3000”[PDAT]) [limits to 1980 to present] | 230
| [8 new since March 2012 search]

Key: [mh] medical subject heading; [sh] subheading; [tiab] keyword in title or abstract; [la] language; [pt] publication type; jsubsetk consumer health subset; [PDAT] publication date.

* numbers may not add up as some records are indexed in multiple publication types.

Last updated July 17, 2012

Table A-3 REHABDATA search strategies (http://www.naric.com/research/rehab/ interface)

Search terms | | Search results
#1 | Exact Phrase: cerebral palsy + At Least One of: eating food feeding nutrition nutritional – limited to 1980-2012 | 47
#2 | Hand-limited to exclude items that are clearly books or from non-research periodicals, and hits from prior to 1980 | 25
| [6 new items since March 2012 search]

Used the advanced search interface for REHABDATA; http://www.naric.com/research/rehab/results.cfm?search=2&type=advanced&all=&exact=cerebral%20palsy&any=eating%20food%20feeding%20nutrition%20nutritional%20&omit=&fld1=Title&txt1=&op1=AND&fld2=Title&txt2=&op2=AND&fld3=Title&txt3=&op3=AND&fld4=Title&txt4=&dte1=1980&dte2=&available=0&online=0

Last updated July 16, 2012

Table A-4 CINAHL search strategies (EBSCOhost interface)

Search terms | | Search results
#1 | (MH “Cerebral Palsy/DT/SU/DH/TH OR ((MH “Cerebral Palsy” OR TX “Cerebral Palsy”) AND ((MH “Surgery, Operative+” OR TX “Surgery” OR MH “Drug Therapy+” OR TX “Drug” OR TX “Pharmacotherapy” OR TX “Gastrostomy” OR MH “Gastrostomy” OR MH “Gastrojejunostomy Tubes+” OR TX “PEG tube” OR TX “tube feeding” OR TX “tube fed” OR TX “tube-fed” OR TX “G-tube” OR TX “G tube” OR TX “J-tube” OR TX “J tube” OR TX “gj tube” OR TX “g-j tube” OR TX “gastrostomy-jejunostomy tube” OR MH “Jejunostomy” OR TX “jejunostomy” OR TX “gastrojejunostomy” OR TX “nasogastric tube” OR TX “ng tube” OR TX “nasogastric feeding”) OR (MH “Enteral Nutrition” OR TX “enteral feeding” OR TX “enteral nutrition”) OR (MH “Orthodontic Appliances” OR TX “intraoral appliance” OR TX “intraoral appliances” OR TX “oral appliance” OR TX “oral appliances”) OR (TX “sensorimotor” OR TX “Sensory feedback” OR MH “Feedback” OR MH “Posture+” OR TX “posture” OR TX “positioning” OR TX “position” OR MH “Patient Positioning+”) OR MH “Food Additives” OR MH “Food, Formulated” OR MH “Food, Fortified” OR ((TX “food” OR MH “Food+”) AND (TX “handling” OR TX “thickness” OR thickener^*^ OR TX “consistency” OR TX “additive^*^” OR TX “texture^*^” OR TX “composition” OR TX “presentation” OR preparation^*^)) OR TX “ThickenUP” OR TX “Thick-IT” OR TX “SimplyThick” OR TX “Thick and Easy” OR TX “feeding device” OR TX “feeding devices” OR TX “Self-Help Devices” OR MH “Assistive Technology Devices+” OR MH “Occupational Therapy+” OR TX “occupational therapy” OR MH “Behavior Modification+” OR MH “Behavior Therapy+” OR TX “behavior therapy” OR TX “behavioral therapy” OR TX “Fundoplication” OR MH “Gastric Fundus/SU” OR TX “antireflux” OR MH “Gastroesophageal Reflux/SU” OR (TX “reflux” AND (TX “surgery” OR TX “surgical”)) OR MH “Family Therapy” OR TX “family therapy” OR ((MH “Parenting” OR parent^*^ OR TX “family” OR MH “Caregivers” OR TX “caregiver^*^”) AND (TX “behavior^*^” OR TX “therapy” OR TX “intervention^*^”))))) | 2,549
#2 | (MH “Nutritional Support+” OR MH “Home Nutritional Support” OR MH “Nutritional Status” OR MH “Nutrition (Iowa NOC) (Non-Cinch)+” OR MH “Eating” OR MH “Deglutition disorders” OR TX “feeding” OR TX “nutrition” OR TX “nutritional” OR TX “eating” OR MH “Energy Intake” OR MH “Eating Behavior” OR TX “Feeding behavior”) | 139,244
#3 | S1 AND S2 AND LA “English” | 208
#4 | S3 AND PT “editorial” | 0
#5 | S3 AND PT “letter” | 0
#6 | S3 AND PT “commentary” | 6
#7 | S3 AND PT “case study” | 20
#8 | S3 AND PT “review” | 18
#9 | S3 AND PT “practice guidelines” | 1
#10 | S3 AND PT “meta analysis” | 0
#11 | S3 AND PT “historical material” | 0
#12 | S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 | 45
#13 | S3 NOT S12; - Excluding MEDLINE | 16371
#14 | Published Date from: 19800101-30001231; [limits 1980-present] | 71
| [0 new items since March 2012 search]

Key: MH CINAHL Subject Headings; + Explode Search Term; TX All Text; LA Language; PT Publication Type

* numbers may not add up as some records are indexed in multiple publication types.

Last updated July 17, 2012

Table A-5 ERIC search strategies (eric.ed.gov interface)

Search terms | | Search results
#1 | (Keywords:cerebral and Keywords:palsy) | 1,244
#2 | (Keywords:eating OR Keywords:feeding OR Keywords:nutrition OR Keywords:food OR Keywords:nutritional) | 21,718
#3 | ((Keywords:cerebral and Keywords:palsy) and (Keywords:eating OR Keywords:feeding OR Keywords:nutrition OR Keywords:food OR Keywords:nutritional)) and (Publication Type:“Journal Articles”), Publication Date:1980-2012 | 21
| [5 new items since March 2012 search]

Key: [mh] medical subject heading; [sh] subheading; [tiab] keyword in title or abstract; [la] language; [pt] publication type; jsubsetk consumer health subset; [dp] publication date.

* numbers may not add up as some records are indexed in multiple publication types.

Last updated July 17, 2012

Table A-6 OTseeker search strategies (www.otseeker.com interface)

Search terms | | Search results
#1 | “cerebral palsy” AND (eating OR feeding OR nutrition OR nutritional OR food) AND Year Published: 1980 - | 5
| [0 new items since March 2012 search]

Table A-7 PsycINFO search strategies (ProQuest CSA Illumina interface)

Search terms | | Search results
#1 | ((KW=“cerebral palsy”) AND (KW=“surgery” OR KW=“drug therapy” OR KW=“Drug” OR KW=“Pharmacotherapy” OR KW=“gastrostomy” OR KW=“Gastrojejunostomy” OR KW=“Gastrojejunostomy tube” OR KW=“PEG Tube” OR KW=“tube feeding” OR KW=“tube fed” OR KW=“G tube” OR KW=“G-Tube” OR KW=“J tube” OR KW=“J-Tube” OR KW=“GJ Tube” OR KW=“G-J Tube” OR KW=“Gastrostomy-jejunostomy tube” OR KW=“Jejunostomy” OR KW=“nasogastric tube” OR KW=“ng tube” OR KW=“nasogastric feeding” OR KW=“orthodontic appliance*” OR KW=“intraoral appliance*” OR KW=“oral appliance*” OR KW=“sensorimotor” OR KW=“Sensory Feedback” OR KW=“Feedback” OR KW=“Posture” OR KW=“Positioning” OR KW=“Position*” OR (KW=“Food” AND (KW=“handling” OR KW=“Thickness” OR KW=“thickener*” OR KW=“Consistency” OR KW=“Additive*” OR KW=“Texture*” OR KW=“Composition*” OR KW=“Presentation” OR KW=“Preparation*”)) OR KW=“Food Additive” OR KW =“Food Additives” OR KW=“Feeding device” OR KW=“Feeding devices” OR KW=“Self-help device*” OR KW=“Assistive Technology Devices” OR KW=“Assistive Technology” OR KW=“Assistive Devices” OR KW=“Occupational Therapy” OR KW=“Behavioral Therapy” OR KW=“Behavior Therapy” OR KW=“Behavior Modification” OR KW=“Behavior” OR KW=“Fundoplication” OR KW=“Gastric Fundus” OR KW=“Antireflux” OR (KW=“Reflux” AND (KW=“Surgery OR KW=“Surgical”)) OR KW=“Family Therapy” OR KW=“Family counseling” OR KW=“Psychotherapeutic Counseling” OR KW=”Parent Training” OR ((KW=“Family OR KW=“Parent*” OR KW=”Caregivers” OR KW=caregiver) AND (KW=“Behavior” OR KW=“Therapy” OR KW=“Intervention*”)))) | 1,159
#2 | KW=“Nutrition” OR KW=“Eating” OR KW=“Feeding” OR KW=“Intake” OR KW=“Nutritional” OR KW=“Eating Behavior” OR KW=“Feeding Behavior” OR KW=“food” OR KW=“Food Intake” | 110,030
#3 | #1 AND #2 AND “English” | 80
#4 | #3 AND; - Limited to Journals | 70
#5 | #4 limited to 1980 to 2012 | 62

Key: KW Keyword

Table A-8 Description of Databases

Database | Description
PubMed | The database comprises of citations and abstracts from the fields of biomedicine and health. It coverage includes life sciences, behavioral sciences, chemical sciences, and bioengineering from MEDLINE, life science journals, and online books with over 21 million citations. PubMed was developed by the National Center for Biotechnology Information (NCBI) at the U.S. National Library of Medicine (NLM).
REHABDATA | Database for disability and rehabilitation research. Content includes physical, mental, and psychiatric disabilities, independent living, vocational rehabilitation, special education, and assistive technology. Document categories include reports, studies, and papers funded by the National Institute on Disability and Rehabilitation Research, rehabilitation-related articles, and published books. The database indexes over 70,000 documents from 1956 to present. REHABDATA is produced by the National Rehabilitation Information Center.
CINAHL (Cumulative Index to Nursing and Allied Health Literature | The cumulative index to nursing and allied health literature (CINAHL) indexes literature from the fields of nursing and allied health. The database includes health care books, nursing dissertations, conference proceedings, standards of practice, and book chapters. CINAHL provides indexing for more than 3,000 journals from 1981 to present.
ERIC (Education Resources Information Center) | Database compiled of records including journal articles, books, research syntheses, conference papers, technical reports, policy papers, and other education-related materials with more than 1.4 million bibliographic records. ERIC is sponsored by the Institute of Education Sciences (IES) of the U.S. Department of Education.
OTseeker (Occupational Therapy Systematic Evaluation of Evidence) | Database contains abstracts of systematic reviews and randomized controlled trials relevant to occupational therapy with over 8,500 articles in its database. OTseeker was developed by a team of occupational therapists from the University of Queensland School of Health and Rehabilitation Sciences and the University of Sydney, Australia.
PsycINFO | Abstracting and indexing database with records from peer-reviewed journals, books, and dissertations in behavioral sciences and mental health. Professional coverage of related disciplines including psychology, medicine, law, social work, neuroscience, business, and nursing. PsycINFO holds more than 3 million records and 2,500 journals, with coverage from 1597-present (comprehensive coverage 1880-present), and is produced by the American Psychological Association (APA).