# Acronyms/Abbreviations/Symbols

AHRQ: Agency for Healthcare Research and Quality
AMSTAR: Assessment of Multiple Systematic Reviews
CER: Comparative Effectiveness Review
CINAHL^®^: Cumulative Index of Nursing and Allied Health Literature
CP: Cerebral palsy
EHC: Effective Health Care
ERIC^sm^: Educational Resources Information Center
GER: Gastroesophageal reflux
GERD: Gastroesophageal reflux disease
GJ-Tube: Gastrojejunal tube
GMFCS: Gross Motor Function Classification System
G-Tube: Gastrostomy tube
HealthSTAR: Health Services Technology, Administration and Research
ISMAR: Innsbruck Sensorimotor Activator and Regulator
J-Tube: Jejunostomy tube
KI: Key informant
MEDLINE^®^: Medical Literature Analysis and Retrieval System
PEDro: Physiotherapy Evidence Database
PEG: Percutaneous endoscopic gastrostomy
QOL: Quality of life
RCT: Randomized controlled trial
SD: Standard deviation
SOE: Strength of evidence
SQCP: Spastic quadriplegic cerebral palsy
TEP: Technical Expert Panel
TOO: Task Order Officer
VAS: Visual Analog Scale