# Results

In this chapter, we present the results of our systematic review of the literature and synthesis of the extracted data on outcomes on the effectiveness and comparative effectiveness of local hepatic therapy for unresectable CRC metastases to the liver. The Key Questions (KQs) for this review are: KQ1 (effectiveness) and KQ2 (harms) of local hepatic therapy for unresectable CRC metastases to the liver in patients whose disease is refractory to systemic chemotherapy and who have no or minimal extrahepatic disease; and KQ3 (effectiveness) and KQ4 (harms) of local hepatic therapy for unresectable CRC metastases to the liver in patients who are also receiving systemic chemotherapy and have no extrahepatic disease.

We first describe the results of our literature searches and then present the results for KQ1 and KQ2, which include a list of key points, an overview of the included literature, and a detailed synthesis of the data. This is followed by the same for KQ3 and KQ4. We identified 937 nonduplicate titles or abstracts with potential relevance, and of these, 189 proceeded to full-text review (Figure 3). Thirty-one articles were included in the review, including one hand-searched article and five articles from gray literature identified through other sources (the American Society of Clinical Oncology, American Society of Clinical Oncology Gastrointestinal Cancers, Surgical Society of Oncology, and Radiosurgical Society). The 31 arms represent 30 distinct studies: 1 RCT, 12 prospective case series, and 17 retrospective case series. Twenty-three studies pertain to KQ1, 23 studies to KQ2, 7 studies to KQ3, and 7 studies to KQ4.

Figure 3 PRISMA diagram for identified published literature

Figure 3 is a PRISMA diagram illustrating the review of articles identified via literature search for this systematic review. 937 records were identified through the literature search. 181 records were excluded due to a publication date prior to the year 2000. 756 titles were screened and 353 were excluded. 403 abstracts were screened and 160 abstracts were excluded. The remaining 243 records were retrieved and the full-text articles were assessed for eligibility. An additional 219 articles were excluded with reasons given in Appendix F. 24 articles were included in this report from the literature search and one additional record was found through hand searching. Five articles were included from the gray literature search and one hand searched article for a total of 30 articles in this systematic review.

## Results of Literature Searches

Of the 937 records identified through the literature search, we excluded 913 at various stages of screening and included 24 records.63–86 We included one hand-searched article,87 two published studies from scientific information packets,88,89 and three articles from conference abstracts.90–92 A total of 30 articles were included in this report: 29 case-series and one RCT87 for which a single arm was abstracted as a case series. This RCT compared RFA with systemic chemotherapy to systemic chemotherapy alone. The scope of the review was liver-directed therapy versus liver-directed therapy. Systemic chemotherapy alone was not a relevant intervention or comparator for this review. Only the RFA combined with systemic chemotherapy arm was abstracted and included in this report as it is relevant for KQ3 and KQ4.

The PRISMA diagram (Figure 3) depicts the flow of search screening and study selection.53 A list of full-text studies with reason for exclusion is presented in Appendix F.

Our searches of various gray literature sources yielded five published studies that we added to the articles identified in the search of publications databases and that were included in the analyses presented in this evidence review.88–92

We evaluated the results of the gray literature search as follows:

- Regulatory information: The search yielded six results, but no new studies were identified from this source.
- Clinical trial registries (ClinicalTrials.gov): The search yielded 259 clinical trials; we excluded 219 trials during the title and abstract screen. Twenty-five of the remaining 40 trials were excluded. Among the 15 trials remaining, 2 contained too little information to make a conclusion about their relevance to the KQs of this report. Of the remaining 13 studies, three had been terminated, seven were ongoing or recruiting, and three had been completed. We found no publications for the three completed trials. All terminated studies cited low recruitment as the reason for study termination.
- Abstracts and conference papers: The search yielded 174 citations, and we excluded 132 during the title and abstract screen. Of the remaining 42 items, two were duplicates and 37 did not meet inclusion criteria after full-text review. The three remaining references met all inclusion criteria and were included in this report.90–92
- Manufacturer database: Scientific information packets were received from Accuray (manufacturers of the CyberKnife^®^ SBRT system) and SIRTEX (manufacturers of the Yttrium-90–infused SIR-Spheres microspheres). The submissions consisted of 55 published references, listings of clinical trials, or conference abstracts. Of the 55 references, we excluded 53 during the abstract and title screen. The remaining two references met the inclusion criterion and were included in this report.88,89

## Overview of the Literature

Thirty-one arms within 30 studies met our inclusion criteria and addressed local hepatic therapy for unresectable CRC metastases to the liver. Nine studies were conducted in the United States, four in Italy, four in Germany, three in Australia, three in Japan, two in the United Kingdom, two in Korea, and one study each in France, the Netherlands, and Turkey (Table 4). The number of patients in each study ranged from 6 to 140.

Table 4 Characteristics of studies included in this review by intervention

Characteristic | RFA | TACE | HAI | RE | DEB | SBRT | RFA With SC | HAI With SC | RE With SC | Total Arms^*^
Total | 1 | 2^a^ | 2 | 13^a^ | 3 | 3 | 3 | 2 | 2 | 31
Study Design
Prospective Case Series | 0 | 0 | 0 | 6 | 2 | 1 | 2^b^ | 1 | 1 | 13
Retrospective Case Series | 1 | 2 | 2 | 7 | 1 | 2 | 1 | 1 | 1 | 18
Outcomes Reported
Overall Survival | 1 | 2 | 2 | 13 | 3 | 3 | 3 | 2 | 2 | 31
Quality of Life | 0 | 0 | 0 | 1 | 1 | 0 | 1 | 0 | 0 | 3
Time to Recurrence | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Length of Stay | 0 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 2
Local Recurrence | 1 | 0 | 0 | 0 | 0 | 2 | 3 | 0 | 0 | 6
Adverse Events | 1 | 2 | 2 | 13 | 3 | 3 | 3 | 2 | 2 | 31
Study Population
United States | 0 | 2 | 0 | 7 | 1 | 0 | 0 | 0 | 0 | 10
Europe | 1 | 0 | 1 | 4 | 2 | 2 | 1 | 0 | 1 | 12
Australia | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | 1 | 3
Asia | 0 | 0 | 1 | 1 | 0 | 1 | 1 | 2 | 0 | 6
Total Participants (N) | 68 | 142 | 67 | 454 | 157 | 43 | 101 | 36 | 159 | 1,227

DEB = drug-eluting beads; HAI = hepatic arterial infusion; RE = radioembolization; N = number; RFA = radiofrequency ablation, SBRT = stereotactic body radiotherapy; SC = systemic chemotherapy; TACE = transarterial chemoembolization

Note: No studies reporting on cryosurgical ablation, MWA, TAE, 3D-CRT, or IMRT met inclusion criteria for this review.

* The total number of articles included in this review is 30.

a Hong et al. reports on both TACE and RE interventions.

b The study by Ruers et al. is an RCT that was extracted as a case series.

All 30 studies had clearly defined questions and well-described interventions, used validated outcome measures, and had conclusions that were supported by the data. Studies varied on how well they described the study population, how well they described their results, and acknowledgement of sponsorship and funding. Fifteen studies did not have well-described patient populations,63,65,67,70,74,78,79,81,83–86,88,89,91 and three studies lacked well-described results.67,70,74

Fifteen studies were rated as good quality,64,66,68,69,71–73,75–77,80,82,87,90,92 12 studies as fair quality,57,63,65,78,79,81,84–86,88,89,91 and three as poor quality.67,70,74

## Key Questions 1 and 2 Effectiveness and Harms of Therapies in Patients Refractory to Systemic Chemotherapy

KQs 1 and 2 focus on the comparative effectiveness (KQ1) and harms (KQ2) of the various local hepatic therapies in patients with unresectable colorectal cancer (CRC) metastases to the liver and who have minimal evidence of extrahepatic disease and whose disease is refractory to systemic therapy (i.e., are not eligible to receive systemic chemotherapy).

### Key Points

- The evidence is insufficient to draw conclusions about overall survival, quality of life, or adverse events. Due to the absence of comparative data, we are limited in drawing conclusions regarding the efficacy and effectiveness of these interventions. Risk of bias is a primary concern in observational studies. Intended effects are likely to be biased by preferential prescribing of the intervention based on the patients’ prognosis.
- All studies were case series. Carey and Boden quality rankings were converted into AHRQ “good,” “fair,” and “poor” ratings. Eleven studies were rated as good quality,66,68,69,71,73,75–77,82,90,92 nine studies as fair quality,63,65,78,83,84,86,88,89,91 and three as poor quality.67,70,74
- The assessment of applicability of the study findings to clinical practice is limited by the poor characterization of the patient populations (e.g., number and size of metastases, performance status) and variability in the delivery of the interventions (e.g., surgical approach, dose and drugs delivered).

### Description of Included Studies

Twenty-three case series63,65–71,73–78,82–84,86,88–92 met inclusion criteria to address KQ1 and KQ2. Of the 23 case series, nine were prospective66,67,70,73–76,78,88 and 14 were retrospective.63,65,68,69,71,77,82–84,86,89–92 The total number of patients for whom data were abstracted from the 23 studies was 932. Three studies included patients treated with TACE with DEB;67,75,90 and two articles reported on TACE alone;63,68 three on SBRT;71,82,88 thirteen on RE;65,66,68,70,73,76–78,84,86,89,91,93 two on HAI,83,92 and one on RFA.69 All studies initiated treatment in patients after January 1, 2000, except for the study by Albert and colleagues21 on TACE. We included this study because it reported on relatively large numbers of patients treated, and analyses showed no differences in outcomes before and after 2000. Table 5 shows the summary of the study and patient characteristics, including number of patients enrolled, study design, intervention period, and intervention, and patient demographics.

Table 5 Local hepatic therapies for CRC metastases to the liver: Summary of study characteristics KQ1 and KQ2

Study NΘ (% CRC) Rating | Study Design | Intervention Period | Intervention | Median Age (Range) | Previous Resection % | Median ECOG Score (Range) | Previous Local Hepatic Therapy %
Martin et al., 2012^86^_,_^a^ 24 (100) Fair | Retrospective case series | 02/2005–02/2009 | RE with Y90 via hepatic artery catheter infusion | 63 (35–83) | NR | NR | NR
Kucuk et al., 2011^84^ 78 (44.9) Fair | Retrospective case series | 06/2006–10/2010 | SIRT with Y90 via hepatic artery catheter under intermittent fluoroscopic visualization | Mean: 62.4 | 2.6 | NR | RFA: 7.7 Chemoembolization: 2.6
Aliberti et al., 2011^90^ 82 (100) Good | Retrospective case series | 12/2005–09/2011 | TACE with irinotecan (100–2000 mg) in DC Beads (2–4 ml of beads) | 61.8 (46–82) | NR | 1 (0–2) | NR
Martin et al., 2011^75^ 55 (100) Good | Prospective case series | 10/2006–08/2008 | Intervention: TACE with DEB; Drug: irinotecan; Dose: median 185 mg, range 150–650 mg; Site: femoral or axillary artery | 60 (34–82) | 20 | 1 (0–2) | Ablation: 9.1
Vautravers-Dewas et al., 2011^82^ 42 (66.7) Good | Retrospective case series | 07/2007–04/2009 | Intervention: SBRT; Radiation dose: 40 Gy and 45 Gy; Site: noninvasive | (23–82) | 51.1 | NR | RFA: 7
Albert et al., 2011^63^ 121 (100) Fair | Retrospective case series | 03/1992–07/2008 | Intervention: TACE; Drug: mitomycin C, doxorubicin, cisplatin; Site: femoral artery | Mean: 61.9 | 17 | 0 (0 - ) | RFA: 17
Nace et al., 2011^89^ 51 (100) Fair | Retrospective case series | 08/2002–05/2008 | RE with Y90 (delivery dose 50 Gy) via hepatic artery | 64 (37–83) | 23.5 | NR (0–1) | RFA: 21.6; HAI 9.8
Stintzing et al., 2010^88^ 6 (100) Fair | Prospective case series | NR | Radiosurgery (24 Gy) for a single session | 66.5 (51–76) | 83.5 | NR | RFA: 17.6
Nishiofuku et al., 2010^92^ 55 (100) Good | Retrospective case series | 04/2005–03/2008 | HAI of 5-FU (1000 mg/m^2^) via continuous 5-hour infusion once a week; Catheter inserted from left subclavian artery or right femoral artery | 62 (30–78) | 22 | 1 (0–3) | NR
Nishiofuku et al., 2010^92^ 55 (100) Good | Retrospective case series | 04/2005–03/2008 | HAI of 5-FU (1000 mg/m2) via continuous 5-hour infusion once a week; Catheter inserted from left subclavian artery or right femoral artery | 62 (30–78) | 22 | 1 (0–3) | NR
Cosimelli et al., 2010^66^ 50 (100) Good | Prospective case series | 05/2005–08/2007 | Intervention: RE; Drug: Y90; Site: hepatic artery | 67 (34–85) | 24 | 0 (0–3) | NR
Kim et al., 2009^71^ 9 (100) Good | Retrospective case series | 06/2004–12/2006 | Intervention: SBRT; Radiation dose: median 42 Gy, range 36–51 Gy; Site: noninvasive | 57 (35–74) | NR | NR (1–2) | NR
Cianni et al., 2009^65^ 41 (100) Fair | Retrospective case series | 02/2005–01/2008 | Intervention: RE; Y90 dose: mean 1.82 GBq; Site: hepatic artery | NR (33–77) | NR | 0.7 (0 - ) | TACE: 4.8; RFA or cryosurgical ablation: 19.5
Mulcahy et al., 2009^76^ 72 (100) Good | Prospective case series | 2003–2007 | Intervention: RE; Y90 dose: median 118 Gy; Site: hepatic artery | 61 (54–86) | NR | 0 (0–2) | NR
Jakobs et al., 2008^91^ 41 (100) Fair | Retrospective case series | 10/2003–04/2007 | Intervention: RE; Y90 dose: mean 1.9 GBq (range 0.7–2.8 GBq). | NR | NR | NR | NR
Sato et al., 2008^78^ 137 (37.2) Fair | Prospective case series | 2002–2006 | Intervention: RE; Y90 dose: median 1.83 GBq, range 0.7–6.9 GBq, median 112.8 Gy, range 27–180 Gy; Site: hepatic artery | NR | NR | 0 (0–3) | Local hepatic therapy (unspecified): 16
Vogl et al., 2008^83^ 55 (21.8) Fair | Retrospective case series | 2002–2006 | Intervention: HAI; Drug: mitomycin C, gemcitabine; Site: femoral artery | 63.5 (54–80) | NR | NR | NR
Hong et al., 2009^68^ 21 (100) Good | Retrospective case series | 01/2001–03/2006 | Intervention: TACE; Drug: cisplatin, doxorubicin, mitomycin C; Site: femoral artery | 67 (32–88) | 23 | NR | Cryosurgical ablation: 4.8, Radiation: 4.8, RFA: 9.5
Hong et al., 2009^68^ 21 (100) Good | Retrospective case series | 01/2001–03/2006 | Intervention: RE; Y90 dose: median 112.9 Gy/tx, median 113.0 Gy/pt; Site: femoral artery | 67 (51–80) | 20 | NR | RFA: 6.7, TACE: 13.3
Rowe et al., 2007^77^ 24 (29.2) Good | Retrospective case series | 07/2004–11/2005 | Intervention: RE; Y90 dose: median 103 Gy, range 41–145 Gy, median 1.8 GBq, range 1.5–2.0 GBq; Site: hepatic artery | 57 (53 – 68) | NR | 1 (0–2) | NR
Jiao et al., 2007^70^ 21 (47.6) Poor | Prospective case series | 06/2004 – NR | Intervention: RE; Y90 dose: mean 1.9 GBq, range 1.2–2.5 GBq; Site: femoral catheter or hepatic artery port | NR (40–75) | 31 | NR | RFA: 48
Fiorentini et al., 2007^67^ 20 (100) Poor | Prospective case series | 11/2005 – ongoing (06/2007) | Intervention: TACE with DEB; Drug: irinotecan; Site: hepatic artery | NR | NR | 1 (0–2) | NR
Jakobs et al., 2006^69^ 68 (100) Good | Retrospective case series | 01/2000–06/2004 | Intervention: RFA; Site: percutaneous | (38–87) | 16 | NR | HAI: 3, TACE: 3
Lewandowski et al., 2005^73^ 27 (100) Good | Prospective case series | 06/2001–12/2003 | Intervention: RE; Y90 dose: range 135–150 Gy; Site: lobar | 68 (54–86) | NR | 0 (0–2) | NR
Lim et al., 2005^74^ 30 (100) Poor | Prospective case series | 01/2002–03/2004 | Intervention: RE; Drug: Y90 | 61.7 (36–77) | NR | 0 (0 – 2) | NR

CRC = colorectal cancer; DEB = drug-eluting bead; ECOG = Eastern Cooperative Oncology Group; GBq = Gigabecquerel; Gy = Gray; HAI = hepatic arterial infusion; Mets = Metastases; NR = not reported; RE = radioembolization; RFA = radiofrequency ablation; SBRT = stereotactic body radiation therapy; SIRT = selective internal radiotherapy; TACE = transarterial chemoembolization; tx = treatment; pt = patient; Y90 = Yttrium-90

a Data on patient characteristics from this case series include patients with extrahepatic disease; information on outcomes is for patients with non-extrahepatic disease.

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

Patients ranged in age from 30 to 91 years, but they were generally in their late 50s or early 60s. Thirteen studies reported rates of previous resection that ranged from 2.6 to 83.5 percent.63,64,66,68–70,75,82,84,88,89,91,92 Five studies reported median ECOG scores of 0–1, with a range of 0–3.^66,67,73,75,77^ In all but two studies,72,81 patients had been treated with prior lines of systemic chemotherapy, and 11 studies reported patient experience with prior local hepatic therapy.63,68–70, 75,78,82,84,88,89,91 Lines of previous systemic chemotherapy are presented in Appendix D.

The included evidence is clinically diverse with respect to the number of patients undergoing previous resection and local hepatic therapy. Variations are also present in the treatments—in terms of the drugs or dosage—within a given intervention.

Data on tumor characteristics were inconsistently reported across studies and are detailed in Table 6. Synchronous or metachronous disease status was reported in eight studies and synchronous disease ranged from 17 to 73 percent.66,68,71,75,83,91,92,94 Bilobar or unilobar disease was reported in six studies and bilobar disease ranged from 66.7 to 95.1 percent.65,66,68,73,76,86 Eight studies reported liver involvement, but used nonuniform measurements.65,67,70,73,75–77,90 Four studies reported mean or median number of hepatic lesions.69,71,75,82 Six studies reported the mean size of hepatic lesions, which ranged from 2.9 to 12cm.66,68,69,82,90,94 Presence of extrahepatic metastases were reported by five studies and ranged from 33 to 81 percent of patients.63,66,68,91,92 Although extrahepatic disease was reported by these studies, the patients were all described as having liver-dominant disease (i.e., majority of the disease is confined to the liver).

Table 6 Local hepatic therapies for CRC metastases to the liver: Summary of tumor characteristics KQ1 and KQ2

Study NΘ (% CRC) Rating | Synchronous (%) | Bilobar (%) | Median Liver Involvement (%) (Range) | Mean and Median Number of Hepatic Lesions (Range) | Mean Size of Hepatic Lesion(s) (cm) (Range) | Other Liver Involvement %
Martin et al., 2012^86^_,_^d^ 24 (100) Fair | NR | 67 | NR | NR | NR | Extrahepatic metastasis 45.8
Kucuk et al., 2011^84^ 78 (44.9) Fair | NR | NR | NR | NR | NR | NR
Aliberti et al., 2011^90^ 82 (100) Good | NR | NR | 33 (25–50) | NR | 12 (6.5–32) | NR
Martin et al., 2011^75^ 55 (100) Good | 30.9 | NR | NR | Median: 4 (1–20) | NR | 50 Percent liver involvement : 30.9
Vautravers-Dewas et al., 2011^82^ 42 (66.7) Good | NR | NR | NR | Mean: 1.4 (1–4) | 3.4 (.7–10) | WHO 0: 94.4; WHO 1: 11.1; WHO 2: 2.2; WHO 3: 2.2
Albert et al., 2011^63^ 121 (100) Fair | 49 | NR | NR | NR | NR | Extrahepatic metastasis 46
Nace et al., 2011^89^ 51 (100) Fair | NR | NR | NR | NR | NR | NR
Stintzing et al., 2010^88^ 6 (100) Fair | NR | NR | NR | NR | NR | NR
Nishiofuku et al., 2010^92^ 55 (100) Good | 65.5 | NR | NR | NR | NR | limited extrahepatic disease 81.8
Cosimelli et al., 2010^66^ 50 (100) Good | 72 | 70 | NR | NR | (5–8) | ≤4 hepatic mets: 42; >4 hepatic mets: 58
Kim et al., 2009^71^_,_^a^ 9 (100) Good | 55.6 | NR | NR | Mean: 1.4 Median: 1 (1–2) | NR | NR
Cianni et al., 2009^65^_,_^b^ 41 (100) Fair | NR | 95.1 | NR | NR | NR | 50 Percent liver involvement : 24.3
Mulcahy et al., 2009^76^ 72 (100) Good | NR | 83 | NR | NR | NR | Liver replacement ≤25 percent: 78; Liver replacement 26–50 percent: 19; Liver replacement ≥50 percent: 3
Jakobs et al., 2008^91^ 41 (100) Fair | 73 | NR | NR | NR | NR | Limited extrahepatic disease 17
Sato et al., 2008^78^ 137 (37.2) Fair | NR | NR | NR | NR | NR | Tumor burden 0–25 percent: 80; Tumor burden 26–50 percent: 15; Tumor burden 51–75 percent: 5
Vogl et al., 2008^83^_,_^c^ 55 (21.8) Fair | 17 | NR | NR | NR | NR | Tumor burden 50–75 percent: 16.7
Hong et al., 2009^68^ 21 (100) Good | 66.7 | 66.7 | NR | NR | 9.3 (5–16) | Extrahepatic spread: 43
Hong et al., 2009^68^ 21 (100) Good | 53.3 | 86.7 | NR | NR | 8.2 (2–19) | Extrahepatic spread: 33
Rowe et al., 2007^77^ 24 (29.2) Good | NR | NR | 25 (3–49) | NR | NR | NR
Jiao et al., 2007^70^ 21 (47.6) Poor | NR | NR | NR | NR | NR | Tumor Volume <25 percent:14, Tumor Volume 25–50 percent:81, Tumor Volume >51 percent:5
Fiorentini et al., 2007^67^ 20 (100) Poor | NR | NR | 40 (20–70) | NR | NR | NR
Jakobs et al., 2006^69^ 68 (100) Good | NR | NR | NR | Mean: 2.7 (1–5) | 2.3 (.5–5) | NR
Lewandowski et al., 2005^73^ 27 (100) Good | NR | 78 | NR | NR | NR | Liver replacement by tumor ≤25 percent: 78; 26–50 percent: 19; >50 percent: 3
Lim et al., 2005^74^ 30 (100) Poor | NR | NR | NR | NR | NR | NR

CRC = colorectal cancer; Mets = metastases; NR = not reported; WHO = World Health Organization

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Total liver tumor volume: median, 72.8 ml (range 3.4–271.1 ml).

b All patients had multiple lesions and four patients (9.7%) had other metastatic involvement (pathologic lymph nodes and bone metastases).

c Median tumor volume: 79.2 ml (range 6.6–1,384.4 ml).

d Data on patient characteristics from this case series include patients with extrahepatic disease; information on outcomes is for patients with non-extrahepatic disease.

## Detailed Synthesis

Table 7 displays the outcomes reported. All studies reported overall survival. All studies reported on adverse events, but four studies aggregated these events by multiple primary cancer sites, which did not permit us to extract CRC-specific adverse events.69,70,77,78 Eight studies also reported progression-free survival.63,65,66,71,75,90,92,93 Three studies reported on both liver-specific progression-free survival and overall progression-free survival;63, 75, 92 no studies reported on liver-specific progression-free survival alone; and the remaining five studies reported overall progression-free survival alone.65,66,71,74,90 Jakobs et al. (2006)69 attempted to calculate the time to recurrence statistic but were unable to do so because of the low rate of recurrence (18%). Two studies reported on length of stay,63,67 and two studies reported on quality of life.66,67 We report data on individual outcomes, except for results on overall progression-free survival and liver-specific progression-free survival, which are located in Appendix D.

Table 7 Outcomes reported for Key Questions 1 and 2

Study NΘ (% CRC) Rating | OS | QOL | TTR | LOS | LR | AE
Albert et al., 2011^63^ 121 (100) Fair | • | NR | NR | • | NR | •
Aliberti et al., 2011^90^ 82 (100) Good | • | NR | NR | NR | NR | •
Cianni et al., 2009^65^ 41 (100) Fair | • | NR | NR | NR | NR | •
Cosimelli et al., 2010^66^ 50 (100) Good | • | • | NR | NR | NR | •
Fiorentini et al., 2007^67^ 20 (100) Poor | • | • | NR | • | NR | •
Hong et al., 2009^68^ 21 (100) Good | • | NR | NR | NR | NR | •
Jakobs et al., 2006^69^ 68 (100) Good | • | NR | •^a^ | NR | • | •^a^
Jakobs et al., 2008^91^ 41 (100) Fair | • | NR | NR | NR | NR | •
Jiao et al., 2007^70^ 21 (47.6) Poor | • | NR | NR | NR | NR | •^a^
Kim et al., 2009^71^ 9 (100) Good | • | NR | NR | NR | • | •
Kucuk et al., 2011^84^ 78 (44.9) Fair | • | NR | NR | NR | NR | •
Lewandowski et al., 2005^73^ 27 (100) Good | • | NR | NR | NR | NR | •
Lim et al., 2005^74^ 30 (100) Poor | • | NR | NR | NR | NR | •
Martin et al., 2011^75^ 55 (100) Good | • | NR | NR | NR | NR | •
Martin et al., 2012^86^ 24 (100) Fair | • | NR | NR | NR | NR | •
Mulcahy et al., 2009^76^ 72 (100) Good | • | NR | NR | NR | NR | •
Nace et al., 2011^89^ 51 (100) Fair | • | NR | NR | NR | NR | •
Nishiofuku et al., 2010^92^ 55 (100) Good | • | NR | NR | NR | NR | •
Rowe et al., 2007^77^ 24 (29.2) Good | • | NR | NR | NR | NR | •
Sato et al., 2008^78^ 137 (37.2) Fair | • | NR | NR | NR | NR | •^a^
Stintzing et al., 2010^88^ 6 (100) Fair | • | NR | NR | NR | • | •
Vautravers-Dewas et al., 2011^82^ 42 (66.7) Good | • | NR | NR | NR | NR | •
Vogl et al., 2008^83^ 55 (21.8) Fair | • | NR | NR | NR | NR | •

AE = adverse events; CRC = colorectal cancer; LOS = length of stay; LR = local recurrence; NR = not reported; OS = overall survival; QOL = quality of life; TTR = time to recurrence

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

“•” indicates that this outcome was reported in the article.

a Paper reported an outcome of interest but these were grouped with multiple primary presentation sites, which did not permit us to identify CRC-specific data.

### Overall Survival

All studies reported on outcomes related to overall survival (Table 8, which is organized by intervention). One RFA study by Jakobs et al. (2006)69 did not report mean or median survival measures, but did report 1-, 2-, and 3-year survival rates of 96 percent, 71 percent, and 68 percent, respectively, from the time of study treatment. Three studies in our report used TACE with DEB. Median survival was reported by two75,90 studies and ranged from 19 to 25 months from study treatment. Florentini et al. (2007) reported only a 1-year survival rate of 61 percent.67 Two studies reported on TACE alone.63,68 Both studies reported median survival from time of diagnosis of liver metastases, which ranged from 26.3 to 27 months. Thirteen studies of RE with Yttrium-90 were included in this review.65,66,68,70,73,74,76–78,84,86,89,91 One of these studies involved systemic chemotherapy in addition to RE and is therefore not presented in this summary of results.30 Eight studies reported survival from study treatment; median survival ranged from 4 to 15.2 months.70,73,77,78,84,86,89,91 One of these studies84 did not reach median survival at a follow up of 3 years. Three studies reported survival starting from diagnosis of liver metastases, which ranged from 31 to 34.6 months.66,68,76 Two studies did not indicate the time point from which survival was measured.65,74 HAI was used in two studies in our review,83,92 and reported median survival from the start of study treatment as 6.7 and 9.7 months.83,92 Three studies reported SBRT in this review and all defined survival from time of study treatment.71,82,88 Median survival values reported in two studies were 17 and 25 months.71,88 The third SBRT study only reported 1- and 2-year survival rates of 95 percent and 58 percent, respectively.82

Table 8 Local hepatic therapies for CRC metastases to the liver: Outcomes related to overall survival KQ1 and KQ2

Intervention | Survival Time From | Mean or Median Overall Survival (95% CI) | 1-Year Survival (%) | 2-Year Survival (%) | 3-Year Survival (%) | 5-Year Survival (%) | Study NΘ (% CRC) Rating
RFA | Study Treatment | NR | 96 | 71 | 68 | NR | Jakobs et al., 2006^69,f^ 68 (100) Good
Intervention: TACE with DEB; Drug: irinotecan | Study Treatment | Median: 25 | ~78^g^ | ~52^g^ | ~21^g^ | NR | Aliberti et al., 2011^90^ 82 (100) Good
Intervention: TACE with DEB; Drug: irinotecan | Study Treatment | Median: 19 | 75 | NR | NR | NR | Martin et al., 2011^75,a^ 55 (100) Good
Intervention: TACE with DEB; Drug: irinotecan | NR | NR | 61^*^ | NR | NR | NR | Fiorentini et al., 2007^67,b^ 20 (100) Poor
Intervention: TACE; Drug: mitomycin C, doxorubicin, cisplatin | Diagnosis of Liver Mets | Median: 27 | 85 | 55 | NR | 6 | Albert et al., 2011^63,a^ 121 (100) Fair
Intervention: TACE; Drug: cisplatin, doxorubicin, mitomycin C; Site: femoral artery | Diagnosis of Liver Mets | Median: 26.3 | NR | NR | NR | NR | Hong et al., 2009^68^ 21 (100) Good
Intervention: RE; Drug: Y90 | Study Treatment | Median: 11.9 (4.1 to 25.7) | NR | NR | NR | NR | Martin et al., 2012^86,h^ 24 (100) Fair
Intervention: RE; Drug: Y90 | Study Treatment | Median not reached | ~88^g^ | ~77^g^ | ~77^g^ | NR | Kucuk et al., 2011^84^ 78 (44.9) Fair
Intervention: RE; Drug: Y90 | Study Treatment | Mean: 14.4 Median: 10.2 (7.5 to 13.0) | NR | NR | NR | NR | Nace et al., 2011^89^ 51 (100) Fair
Intervention: RE; Drug: Y90 | Diagnosis of Liver Mets | Median: 31 (29 to 34) | 50.4 | 19.6 | NR | NR | Cosimelli et al., 2010^66,b^ 50 (100) Good
Intervention: RE; Drug: Y90 | NR | Median: 11.8 | NR | NR | NR | NR | Cianni et al., 2009^65,b^ 41 (100) Fair
Intervention: RE; Drug: Y90 | Diagnosis of Liver Mets | Median: 34.6 (24.4 to 41.8) | NR | NR | NR | 17.7 | Mulcahy et al., 2009^76^ 72 (100) Good
Intervention: RE; Drug: Y90 | Study Treatment | Mean: 13.9 Median: 15.2 | 53.7 | 26.7 | NR | NR | Sato et al., 2008^78,b^ 137 (37.2) Fair
Intervention: RE; Drug: Y90 | Diagnosis of Liver Mets | Median: 32.8 | NR | NR | NR | NR | Hong et al., 2009^68,a^ 15 (100) Good
Intervention: RE; Drug: Y90 | Study Treatment | Median: 10.5 | ~40^g^ | ~27^g^ | ~16^g^ | NR | Jakobs et al., 2008^91^ 41 (100) Fair
Intervention: RE; Drug: Y90 | Study Treatment | Median: ~4^g^ | ~23^g^ | 14.3 | NR | NR | Jiao et al., 2007^70,d^ 21 (47.6) Poor
Intervention: RE; Drug: Y90 | Study Treatment | Mean: 11.1 Median: 9 | ~27^g^ | ~20^g^ | NR | NR | Rowe et al., 2007^77,b^ 24 (29.2) Good
Intervention: RE; Drug: Y90 | NR | NR | ~20^g^ | NR | NR | NR | Lim et al., 2005^74^ 30 (100) Poor
Intervention: RE; Drug: Y90 | Study Treatment | Median: 9.4 (7.3 to 13.5) | NR | NR | NR | NR | Lewandowski et al., 2005^73,c^ 27 (100) Good
Intervention: HAI; Drug: mitomycin C, gemcitabine | Study Treatment | Median: 9.7 | ~48^g^ | ~30^g^ | NR | NR | Vogl et al., 2008^83,a^ 55 (21.8) Fair
Intervention: HAI; Drug: 5-FU 1000 mg/m^2^ | Study Treatment | Median: 6.7 (5 to 8.3) | ~18^g^ | ~5^g^ | NR | NR | Nishiofuku et al., 2010^92^ 55 (100) Good
Intervention: SBRT; Radiation dose: 40 Gy and 45 Gy; Site: noninvasive | Study Treatment | NR | ~95^g^ | 58 | NR | NR | Vautravers-Dewas et al., 2011^82^ 42 (66.7) Good
Intervention: SBRT; Radiation dose: 40 Gy and 45 Gy; Site: noninvasive | Study Treatment | Median: 25 | 53 | 40 | 40 | NR | Kim et al., 2009^71^ 9 (100) Good
Intervention: SBRT; Radiation dose: 24 Gy to the 70% isodose; Site: noninvasive | Study Treatment | Mean: 18.3 Median: 17.0 | NR | NR | NR | NR | Stintzing et al., 2010^88^ 6 (100) Fair

CI = confidence interval; CRC = colorectal cancer; Gy = Gray; HAI = hepatic arterial infusion; Mets = metastases; NR = not reported; RE = radioembolization; SBRT = stereotactic body radiation therapy; TACE = transarterial chemoembolization

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Treatment through the femoral or axillary artery.

b Treatment through the hepatic artery.

c Lobar treatment site.

d Femoral catheter or hepatic artery port.

e Site: percutaneous and intraoperatively.

f Site: percutaneous.

g Survival estimates were extracted by the EPC from survival curves presented in the article.

h Data on this outcome are for patients with non-extrahepatic disease (n=11).

Direct comparisons of overall survival cannot be made from the published data because there are no comparative studies and the studies measured survival from different starting points (i.e., time of diagnosis or time of treatment).

### Quality of Life

Two studies reported on quality of life.66,67 Cosimelli and colleagues used a battery of questionnaires to assess both cancer and disease-specific quality of life (The European Organization for Research and Treatment of Cancer [EORTC] Quality of Life Questionnaire [QLQ] C30, EORTC QLQ C38, and EORTC QLQ LMC-21).66 They also assessed anxiety and depression (Hamilton Rating Scale for Depression [HAM-D]) and patient satisfaction (EORTC QLQ SAT-32). They reported quality of life measures on 14 of 50 enrolled subjects. The study authors provided no insight as to why only 14 of the participants had available data on quality of life. Six weeks after treatment, the quality of life of 14 patients treated with RE was not adversely affected, and patients’ anxiety levels were significantly reduced from pretreatment levels. No significant difference was observed in depression score pre- and post-treatment. In a study of chemoembolization with irinotecan-eluting beads, Fiorentini and colleagues stated that 18 of 20 patients reported improvement in quality of life post-treatment.41 They used the Edmonton Symptom Assessment System in this study, but only reported qualitatively that these patients had improved without providing any metrics.

### Length of Stay

Mean length of stay was reported by two studies63,67 of TACE and ranged from 1.3 to 3 days. No direct comparisons can be made based on the published studies.

### Time to Progression

Time to progression was not reported in any of the included studies.

### Local Recurrence

Outcomes related to local recurrence are summarized in Table 9. In this report, local recurrence is defined as recurrence of the liver metastases in the area previously treated. This constitutes a treatment failure or failure to treat the entire lesion and is considered an adverse event. One RFA study reported a local recurrence rate of 18 percent.69 Local recurrence was also reported in two studies of SBRT, both of which reported a rate of 33.3 percent.71,88

Table 9 Local hepatic therapies for unresectable CRC metastases to the liver: Adverse events KQ1 and KQ2

Intervention | Local Recurrence N (%) | Biloma (%) | Liver Failure (%) | Elevated Alkaline Phosphatase N (%) | Elevated Bilirubin N (%) | Rare Adverse Events | Study NΘ (% CRC) Rating
RFA | 12 (18) | NR | NR | NR | NR | No major complications. | Jakobs et al., 2006^69^ 68 (100) Good
Intervention: TACE with DEB; Drug: irinotecan; | NR | NR | NR | NR | 41 (50) | NR | Aliberti et al., 2011^90^ 82 (100) Good
Intervention: TACE with DEB; Drug: irinotecan; | NR | NR | 3 | NR | NR | All AE are from the number of DEB treatments (99) and not from the total 55 patients. 3% of patients had severe liver dysfunction, 1 patient died. 1% had cholecystitis, 1% had gastritis, and 1% had myocardial infarction, which was the cause of death in 1 patient. | Martin et al., 2011^75^ 55 (100) Good
Intervention: TACE with DEB; Drug: irinotecan; | NR | NR | NR | NR | NR | Liver abscess: 5% (1 patient) | Fiorentini et al., 2007^67^ 20 (100) Poor
Intervention: TACE; Drug: mitomycin C, doxorubicin, cisplatin | NR | NR | NR | Grade 1:10% Grade 2: 7% Grade 3: 2% | Grade 1: 1% | Prolonged in-hospital visits after major complications occurred in 11% (20) of the 174 treatments. These included hepatic infarction in 4, hematoma at the site of catheterization in 3, infection in 3, acute edema in 2, myocardial infarction in 2, pulmonary embolism in1, transient ischemic attack in 1, hypoxia in 1, and abnormal heart rhythm in 1. Thirty-day mortality was 3.6%. | Albert et al., 2011^63^ 121 (100) Fair
Intervention: TACE; Drug: cisplatin, doxorubicin, mitomycin C; | NR | NR | NR | NR | NR | 1 (2.7%) pulmonary embolism in the CE group. | Hong et al., 2009^68^ 21 (100) Good
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | No major complications. | Martin et al., 2012^86^ 24 (100) Fair
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | No major complications. | Kucuk et al., 2011^84^ 78 (44.9) Fair
Intervention: RE; Drug: Y90 | NR | NR | 0 | NR | NR | Ventricular tachycardia: 1 (2%) | Nace et al., 2011^89^ 51 (100) Fair
Intervention: RE; Drug: Y90 | R | NR | 2 | NR | NR | NR | Cosimelli et al., 2010^66^ 50 (100) Good
Intervention: RE; Drug: Y90 | NR | NR | 2.4 | NR | NR | NR | Cianniet al., 2009^65^ 41 (100) Fair
Intervention: RE; Drug: Y90 | NR | NR | NR | 6 (8) | 9 (13) | GI ulcer | Mulcahy, et al., 2009^76^ 72 (100) Good
Intervention: RE; Drug: Y90 | NR | Nonspecific to CRC | NR | NR | Nonspecific to CRC | Included non-CRC patients in this article and did not report specific adverse events for CRC mets to the liver Significant toxicity included grade 3 or 4 bilirubin toxicity, 1 GI ulceration, 1 radiation-induced cholecystitis, 2 bilomas, and 1 hepatic abscess. | Sato et al., 2008^78,b^ 137 (37.2) Fair
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | 1 (2.7%) pulmonary embolism | Hong et al., 2009^68^ 15 (100) Good
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | 8 (10) | One patient (2.4%) presented with acute grade 4 cholecystitis 4 weeks after radioembolization and was referred for surgery. | Jakobs et al., 2008^91^ 41 (100) Fair
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | Gastric/duodenal ulceration: 4 (13%); severe disabling pain, anorexia, and nausea: 1 (3.3%); radiation hepatitis: 1 (3.3%) | Lim et al., 2005^93^ 30 (100) Poor
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | Included non-CRC patients in this article and did not report specific adverse events for CRC mets to the liver. Four rare adverse events occurred post-SIRT: 1 cholecystitis followed by fibrosis and portal hypertension; 1 peptic ulceration in the lesser curvature of the stomach; and 2 radiation hepatitis. | Jiao et al., 2007^70,c^ 21 (47.6) Poor
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | Toxicity data were only available for 14 of 24 patients and not reported specifically for CRC mets to the liver. One patient had a symptomatic gastric ulcer postsurgery and 1 patient had a femoral artery plaque rupture with thromboembolism in the lower extremity. | Rowe et al., 2007^77,b^ 24 (29.2) Good
Intervention: RE; Drug: Y90 | NR | NR | NR | NR | NR | One case of radiation-induced ulceration caused by technical error and 1 case of right plural effusion 1 month after treatment. | Lewandowski et al., 2005 73 27 (100) Good
Intervention: HA; Drug: mitomycin C, gemcitabine | NR | NR | NR | NR | NR | No common toxicity criteria grade III, IV, or V adverse events were observed. | Vogl et al., 2008^83,a^ 55 (21.8) Fair
Intervention: HAI; Drug: 5-FU 1000 mg/m^2^ | NR | NR | NR | NR | 1 (1.8) | NR | Nishiofuku et al., 2010^92^ 55 (100) Good
Intervention: SBRT | 2 (33.3%) | NR | NR | NR | NR | NR | Stintzing et al., 2010^88^ 6 (100) Fair
Intervention: SBRT | NR | NR | NR | NR | NR | One patient had cirrhotic failure at 5 months; 1 patient had gastric ulceration; 1 patient had esophagitis; and 1 patient had grade 3 epidermitis. No grade 4 toxicity was observed. | Vautravers-Dewas et al., 2011^82^ 42 (66.7) Good
Intervention: SBRT | 3 (33.3%) | NR | NR | NR | NR | No grade 3 or 4 acute complications | Kim et al., 2009^71^ 9 (100) Good

CE = chemoembolization; DEB = drug-eluting beads; HAI = hepatic arterial infusion; NR = not reported; RE = radioembolization; SBRT = stereotactic body radiation therapy; TACE = transarterial chemoembolization.

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Treatment through the femoral or axillary artery.

b Treatment through the hepatic artery.

c Femoral catheter or hepatic artery port.

### Adverse Events

Twenty-four studies reported on adverse events with varying levels of detail and are presented in Table 9 by intervention. One TACE study reported a patient who developed a hepatic abscess.67 Liver failure was reported in three studies, two on RE65,66 and one75 on TACE with DEB intervention. Two studies—one on TACE63 and one on RE76—reported elevated alkaline phosphatase levels. Elevated bilirubin was reported in five studies, one on TACE with DEB90, one on TACE63, two on RE76,91, and one on HAI92. Elevated transaminase levels were reported in one RE article,76 which also reported elevated bilirubin and alkaline phosphatase. Although these results from liver function tests could point to disease progression, in the time period following a local hepatic therapy they are more likely to reflect an adverse effect of the treatment. Only Aliberti et al. reported liver function test results immediately after treatment.90 Other liver function tests were evaluated as acute or late toxicity76,91 or were not reported63,92 at the time adverse events were evaluated. Two authors indicated that liver function toxicity was likely a result of progressive disease or biliary obstruction.76,91 One TACE with DEB study reported one death from myocardial infarction75 and one TACE study reported a 30-day morality rate of 3.6 percent.63 A description of rare adverse events is included in Table 9. No study reported on injury to adjacent organs, hepatic hemorrhage, or steatohepatitis.

### Multivariate Analyses

Univariate or multivariate analyses of prognostic factors for overall survival including, but not limited to, ECOG score, presence of extrahepatic disease, and treatment response, were variously reported in six case series63,73,76,78,91,92 of local hepatic therapies. All analyses reported on overall survival as the dependent variable.

Among the patient or tumor characteristics found to be associated with improved overall survival were the following: ECOG status (0 vs. ≥1 and in another study 0 or 1 vs. ≥2), performance status (0 or 1 vs. ≥ 2), number of extrahepatic metastases sites (0 or 1 vs. ≥2), number of lines of previous chemotherapy (0–1 vs. ≥ 2), performance status (0 or 1 vs. ≥ 2), carcinoembryonic antigen response (Yes, No), and Response Evaluation Criteria in Solid Tumors (RECIST).

## Key Questions 3 and 4

Key Questions 3 and 4 focus on the comparative effectiveness (KQ3) and harms (KQ4) of the various local hepatic therapies in patients who are receiving local hepatic therapy as an adjunct to systemic therapy for unresectable CRC metastases to the liver and who have no evidence of extrahepatic disease.

### Key Points

- No conclusions on overall survival, quality of life, length of stay, time to recurrence, local recurrence, or adverse events can be drawn from the body of evidence comparing local hepatic therapies for unresectable CRC metastases to the liver. No comparative studies met the inclusion criteria for this review.
- The literature base for this review is comprised of case series and one RCT87 that was abstracted as a case-series study due to a nonrelevant comparator. Four studies were ranked as good quality,64,72,80,87 and three were ranked as fair quality.79,81,85
- The assessment of applicability of the study findings to clinical practice is limited by the poor characterization of the patient populations (e.g., number and size of metastases, performance status) and variability in the delivery of the interventions (e.g., surgical approach, dose and drugs delivered)

### Description of Included Studies

Table 10, Table 11, and Table 12 show the study, patient, and tumor characteristics, including study design, intervention period, intervention, number of patients enrolled, and patient demographics for studies of local hepatic therapies for patients with unresectable CRC metastases to the liver who are receiving local hepatic therapy as an adjunct to systemic therapy. Table 13 through Table 15 present data on study outcomes. Seven studies were included, 64,72,79–81,85,87 six of which were case series. One RCT87 was included in the review but was abstracted as a case-series study because the comparator, systemic chemotherapy, was an intervention outside the scope of this review. Of the six case series, three were prospective64,80,81 and three were retrospective.72,79,85 The total number of patients for which data were abstracted from the five studies was 296. Two studies included patients treated with RE with concurrent systemic chemotherapy;64,72 three articles reported on RFA with chemotherapy;80,85,87 and two reported on patients treated with HAI and systemic chemotherapy.79,81 All studies treated patients after January 1, 2000.

Table 10 Local hepatic therapies adjunctive to systemic chemotherapy for CRC metastases to the liver: Summary of study characteristics KQ3 and KQ4

Study NΘ (% CRC) Rating | Study Design | Intervention Period | Intervention
Ruers et al., 2012^87^ 60 (100) Good | RCT^a^ | 04/2002–06/2007 | RFA and systemic treatment with 5-FU/L/oxaliplatin, with bevacizumab added post 10/2005.
Lee et al., 2012^85^ 28 (100) Fair | Retrospective case series | 07/2002–04/2008 | Percutaneous RFA performed under real-time sonographic guidance. The radiofrequency current was applied for 12 minutes at 200 W to create a radius of ablation at least 10 mm larger than the largest tumor diameter.
Kosmider et al., 2011^72^ 19 (100) Good | Retrospective case series | 01/2002–10/2008 | Intervention: RE with systemic chemotherapy; Drug: FOLFOX or 5-FU; Y90 dose: median 1.96 GBq, mean 2.08 GBq, range 1.60–2.60 GBq; Site: hepatic artery
Sgouros et al., 2011^80^ 13 (100) Good | Prospective case series | 09/2000–08/2004 | Intervention: RFA with systemic chemotherapy; Drug: FOLFIRI; Site: percutaneous
Chua et al. 2011^64^ 140 (100) Good | Prospective case series | 03/2006 – 05/2009 | Intervention: RE with systemic chemotherapy; Drug: Y90 dose: mean 1.8 GBq, median 1.8 GBq, range 0.4–2.6 GBq; Site: femoral or brachial artery
Seki et al., 2009^79^ 20 (100) Fair | Retrospective case series | 07/2004 – 01/2008 | Intervention: HAI followed by systemic chemotherapy; Drug: 5-FU, FOLFOX4, or FOLFOX6; Site: hepatic artery, IV
Tsutsumi et al., 2008^81^ 16 (100) Fair | Prospective case series | 08/2003 – 09/2006 | Intervention: HAI with concurrent systemic chemotherapy; Drug: 5-FU and l-leucovorin, UFT and UZEL; Site: femoral artery, oral

5-FU = 5-florouracil; CRC = colorectal cancer; HAI = hepatic arterial infusion; RE = radioembolization; RFA = radiofrequency ablation; UFT = tegafur-uracil; UZEL = UFT and leucovorin

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Data from this RCT were abstracted and treated as case series data because the comparator in the RCT was outside the scope of this review.

Table 11 Local hepatic therapies adjunctive to systemic chemotherapy for CRC metastases to the liver: Summary of patient characteristics KQ3 and KQ4

Study NΘ (% CRC) Rating | Study Design | Median Age (Range) | Previous Resection (%) | ECOG Score Median (Range) | Previous Systemic Chemotherapy (%) | Previous Local Hepatic Therapy (%)
Ruers et al., 2012^87^ 60 (100) Good | RCT^a^ | 64 (31–79) | 15 | NR | NR | NR
Lee et al., 2012^85^ 28 (100) Fair | Retrospective case series | 61 (32–82) | NR | NR | NR | NR
Kosmider et al., 2011^72^ 19 (100) Good | Retrospective case series | 62 (44–75) | NR | 0 (0–1) | 0 | NR
Sgouros et al., 2011^80^ 13 (100) Good | Prospective case series | 77 (47–84) | NR | NR | 76.9 | NR
Chua et al., 2011^64^ 140 (100) Good | Prospective case series | 64 (37–85) | 27 | 0 (0–2) | 94 | SIRT: 66, Ablation 6
Seki et al., 2009^79^ 20 (100) Fair | Retrospective case series | 49 | NR | NR | NR | NR
Tsutsumi et al., 2008^81^ 16 (100) Fair | Prospective case series | 62 (43–74) | NR | NR | NR | NR

CRC = colorectal cancer; ECOG = Eastern Cooperative Oncology Group; NR = not reported; SIRT = selective internal radiation therapy

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Data from this RCT were abstracted and treated as case series data because the comparator in the RCT was outside the scope of this review.

Table 12 Local hepatic therapies adjunctive to systemic chemotherapy for CRC metastases to the liver: Summary of tumor characteristics KQ3 and KQ4

Study NΘ (% CRC) Rating | Synchronous (%) | Bilobar (%) | % Median Liver Involvement (Range) | Median Number of Hepatic Lesions (Range) | Mean Size of Hepatic Lesion(s) (cm) (Range) | Median Size of Hepatic Lesion(s) (cm) | Other Liver Involvement
Ruers et al., 2012^87^ 60 (100) Good | 38.3 | NR | NR | 4 (1–9) | NR | NR | NR
Lee et al., 2012^85^ 28 (100) Fair | 50 | NR | NR | NR | NR | NR | NR
Kosmider et al., 2011^72^ 19 (100) Good | 95 | NR | 40 (25–65) | NR | NR | NR | NR
Sgouros et al., 2011^80^ 13 (100) Good | NR | NR | NR | 1 (1–3) | 3 (1.5–5.5) | NR | Sum of the maximum diameters of liver metastases per patient at inclusion in cm; Mean: 4.1, Range: 2–8
Chua et al., 2011^64^ 140 (100) Good | NR | 90 | NR | NR | NR | NR | % liver involvement 0–25% (55%); 26–50 (36%); 51–75 (9%)
Seki et al., 2009^79^ 20 (100) Fair | NR | NR | NR | NR | NR | NR | Liver involvement ≤60%: 85; Liver involvement >60%: 15
Tsutsumi et al., 2008^81^ 16 (100) Fair | NR | NR | NR | NR | NR | NR | NR

CRC = Colorectal cancer; NR = not reported

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

Table 13 Outcomes reported for Key Questions 3 and 4

Study NΘ (% CRC) Rating | OS | QOL | LOS | TTR | LR | AE
Ruers et al., 2012^87^ 60 (100) Good | • | • | NR | NR | • | •
Lee et al., 2012^85^ 28 (100) Fair | • | NR | NR | NR | • | •
Kosmider et al., 2011^72^ 19 (100) Good | • | NR | NR | NR | NR | •
Sgouros et al., 2011^80^ 13 (100) Good | • | NR | NR | NR | NR | •
Chua et al., 2011^64^ 140 (100) Good | • | NR | NR | NR | • | •
Seki, et al., 2009^79^ 20 (100) Fair | • | NR | NR | NR | NR | •
Tsutsumi et al., 2008^81^ 16 (100) Fair | • | NR | NR | NR | NR | •

AE = adverse events; LOS = length of stay; LR = local recurrence; OS = overall survival; QOL = quality of life; TTR = time to recurrence

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

“•” Indicates that this outcome was reported in the article.

Table 14 Local hepatic therapies for CRC metastases to the liver: Outcomes related to overall survival for patients receiving local hepatic therapy as an adjunct to systemic therapy KQ3 and KQ4

Intervention | Survival Time From | Median OS (95% CI) | 1-Year Survival (%) | 2-Year Survival (%) | 3-Year Survival (%) | Study NΘ (% CRC) Rating
Intervention: RE with concurrent systemic chemotherapy; Drug: FOLFOX or 5-FU; Y90 dose: median 1.96 GBq, mean 2.08 GBq, range 1.60–2.60 GBq; Site: hepatic artery | Study Treatment | 37.8 | ~83^a^ | ~73^a^ | ~52^a^ | Kosmider et al., 2011^72^ 19 (100) Good
Intervention: RE with systemic chemotherapy: Drug: Y90 dose: mean 1.8 GBq, median 1.8 GBq, range 0.4–2.6 GBq; Site: femoral or brachial artery | Study Treatment | 9 (6.4 to 11.3) | 42 | 22 | 20 | Chua et al., 2010^64^ 140 (100) Good
Intervention: RFA and systemic chemotherapy: Drug: FOLFIRI; Site: percutaneous | Study Enrollment | 24 (17 to 31.1) | NR | NR | NR | Sgouros et al., 2011^80^ 13 (100) Good
Intervention: RFA and systemic chemotherapy; Drug: FOLFIRI or FOLFOX; Site: percutaneous | Study Treatment | 24 | ~88^a^ | ~54^a^ | ~28^a^ | Lee et al., 2012^85^ 28 (100) Fair
RFA followed by systemic treatment with 5-FU/L/oxaliplatin, with bevacizumab added post 10/2005 | Randomization | 45.3 (33.1 to NA) | 88.1 | 72.8 | 45.7 | Ruers et al., 2012^87^ 60 (100) Good
Intervention: HAI followed by systemic chemotherapy; Drug: 5-FU, FOLFOX4 or FOLFOX6; Site: hepatic artery, IV | NR | 30.1 | ~90^a^ | ~72^a^ | ~15^a^ | Seki et al., 2009^79^ 20 (100) Fair
Intervention: HAI with concurrent systemic chemotherapy; Drug: 5-FU and l-leucovorin, UFT and UZEL; Site: femoral artery, oral | NR | 22.0 (19.2 to 26.2) | NR | NR | NR | Tsutsumi et al., 2008^81^ 16 (100) Fair

CRC = colorectal cancer; GBq = Gigabecquerel; HAI = hepatic arterial infusion; NR = not reported; OS = overall survival; RE = radioembolization; RFA = radiofrequency ablation

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Survival estimates were approximated by the EPC from survival curves presented in the manuscript.

Table 15 Local hepatic therapies for unresectable CRC metastases to the liver: Adverse events for patients receiving local hepatic therapy as an adjunct to systemic therapy KQ3 and KQ4

Intervention | Local Recurrence N (%) | Injury to Organs (%) | Liver Failure (%) | Elevated Alkaline Phosphatase N (%) | Elevated Bilirubin N (%) | Rare AE | Study NΘ (% CRC) Rating
Intervention: RE with concurrent systemic chemotherapy; Drug: FOLFOX or 5-FU; Y90 dose: median 1.96 GBq, mean 2.08 GBq, range 1.60–2.60 GBq; Site: hepatic artery | NR | 5.3 | 5.3 | 5 (26.3) | 5 (26.3) | AEs include extrahepatic metastases and 1 (5.3%) treatment-related death from hepatic failure (presumed to be radiation hepatitis). Gastroduodenitis was present in 3 patients (15.8%) and 1 (5.3%) grade 3 anorexia was observed. | Kosmider et al., 2011^72^ 19 (100) Good
Intervention: RE with systemic chemotherapy; Y90 dose: mean 1.8 GBq, median 1.8 GBq, range 0.4–2.6 GBq; Site: femoral or brachial artery | NR | 1 | NR | NR | NR | Three patients (2%) developed radiation-induced liver dysfunction. | Chua et al., 2011^64^ 13 (100) Good
Intervention: RFA and systemic chemotherapy; Drug: FOLFIRI; Site: percutaneous | (81.3) | NR | NR | NR | NR | One patient discontinued chemotherapy early after developing bacterial endocarditis that required a prolonged course of antibiotics. Another patient died suddenly during treatment. The cause of death was determined postmortem as acute cardiomyopathy thought to be related to 5-FU toxicity. | Sgouros et al., 2011^80^ 140 (100) Good
Intervention: RFA and systemic chemotherapy; Drug: FOLFIRI or FOLFOX; Site: percutaneous | 22 (78.6) | NR | NR | NR | NR | One patient (3.6%) suffered from a 10-cm subcapsular hematoma. | Lee et al., 2012^85^ 28 (100) Fair
Intervention: RFA with concurrent systemic chemotherapy; Drug: FOLFOX 4; Site: laparoscopic or percutaneous | 27 (45) | 3.5 | 1.8 | NR | 3 (5.3) | Respiratory failure: 1 (1.8%); wound infection: 3 (5.3%); postoperative death: 1 (1.8%); need for reoperation: 3 (5.3%); Tolerance to systemic chemotherapy (Grade 3–4), neutropenia: 14 (27.5%); cardiotoxicity 5 (9.8%); diarrhea: 10 (19.6%); vomiting: 5 (9.8%); nausea: 7 (13.7%); other gastrointestinal toxicity: 4 (7.8%); pulmonary: 3 (5.9); renal 1 (2); neuropathy: 9 (17.6); fatigue: 7 (13.7); hypertension: 2 (3.9) | Ruers et al., 2012^87^ 60 (100) Good
Intervention: HAI followed by systemic chemotherapy; Drug: 5-FU, FOLFOX4 or FOLFOX6; Site: hepatic artery, IV | NR | NR | NR | NR | NR | 1 patient resected post HAI, and 1 patient discontinued treatment during HAI therapy due to grade 3 hypersensitivity and sensory neuropathy. No grade 4 toxicity was reported. | Seki et al., 2009^79^ 20 (100)
Intervention: HAI with concurrent systemic chemotherapy; Drug: 5-FU and l-leucovorin, UFT and UZEL; Site: femoral artery, oral | NR | NR | NR | NR | NR | Only grade 1 and 2 toxicity was reported. No hematologic toxicity was encountered. | Tsutsumi et al., 2008^81^ 16 (100) Fair

CRC = colorectal cancer; GBq = Gigabecquerel; HAI = hepatic arterial infusion; NR = not reported; OS = overall survival; RE = radioembolization; RFA = radiofrequency ablation

Θ This N reflects the total number of patients enrolled in the study from any primary site. The percentage of CRC patients included in this report is presented in parentheses.

a Survival estimates were approximated by the EPC from survival curves presented in the manuscript.

Patients ranged in age from 31 to 84 years, but were generally in their 60s. One study reported the ECOG score, with a median value of 0 and a range of 0 to 2.^64^ Two studies reported rates of resection for previous CRC liver metastases of 15 and 27 percent,64,87 and three studies64,72,80 reported the proportion of patients who had received prior systemic chemotherapy, which ranged from 0 to 94 percent. One study64 reported patient experience with prior local hepatic therapy, with 66 percent of patients having prior RE and 6 percent having had prior ablation.

Tumor characteristics were inconsistently reported across studies, with synchronous or metachronous disease status reported in three studies72,85,87; bilobar or unilobar disease reported in two studies;64,85 degree of liver involvement reported in three studies;64,72,79 number of hepatic lesions reported by two studies;80,87 and lesion size reported in two studies.80,85 The details of these characteristics are presented in Table 12.

## Detailed Synthesis

Table 13 displays the outcomes reported by study for KQ3 and KQ4. All studies reported overall survival and adverse events. Four studies reported on overall progression-free survival.72, 79, 80, 87 Local recurrence was reported in three studies.64, 85, 87 One study reported on quality of life.87 We report data on individual outcomes, except for results on overall progression-free survival and liver-specific progression-free survival, which are located in Appendix D. No study reported on median time to recurrence, length of stay, or liver progression-free survival.

### Overall Survival

Outcomes related to overall survival are summarized in Table 14, which is organized by intervention. All studies reported median overall survival. No direct comparisons can be made from the published data.

RFA was performed in three studies as an adjunct to systemic chemotherapy for unresectable CRC liver metastases.80,85,87 Ruers et al. (2012) reported a median survival of 45.3 months from time of randomization; Lee et al. (2012) reported a median survival of 24 months and Sgouros et al. (2011) reported a median survival of 24 months from study enrollment. Radioembolization was given as an adjunct to systemic chemotherapy in two studies, both of which reported survival from time of study treatment with a range of 9 to 37.8 months.64,72 HAI as an adjunct to systemic chemotherapy was reported in two studies. In both studies, the authors did not report the time point from which survival was measured.79,81 Survival ranged from 22 to 30.1 months.

### Quality of Life

One study by Ruers and colleagues87 reported on the outcome of quality of life for patients treated with RFA and concurrent systemic chemotherapy. Quality of life was assessed by the EORTC QLQ-C30 questionnaire at baseline, every 6 weeks during study treatment, and during study followup. A 20-point difference is considered a significant change. Of the 60 patients enrolled, it is unclear how many of them were included in the analysis of quality of life. For those with available data, health-related quality of life declined 27 points following RFA. At 4 to 8 weeks post-RFA, prior to the start of systemic chemotherapy, the scores had risen to approximately 10 points below baseline. No other studies reported on quality of life and no direct comparisons can be made based on the published evidence.

### Length of Stay

Mean length of stay was not reported by any studies.

### Time to Recurrence

Time to recurrence was not reported in any of the included studies.

### Local Recurrence

Outcomes related to local recurrence are summarized in Table 15. In this report, local recurrence is defined as recurrence of the liver metastases in the area previously treated. This constitutes a treatment failure or failure to treat the entire lesion and is considered an adverse event. Three RFA studies reported local recurrence rates between 45 and 81.3 percent.64,85,87

### Adverse Events

Outcomes related to adverse events are summarized in Table 15, which is organized by intervention. One study of RE and one study of RFA reported injury to adjacent organs and liver failure.72,80 Elevated bilirubin was reported in two studies72,87 and elevated alkaline phosphatase and transaminases were reported in one study.72 Kosmider et al.72 reported elevated liver function test results within 60 days post-treatment that were not related to progressive disease and normalized shortly thereafter; Ruers et al.87 did not report when the patients had hepatic dysfunction related to elevated bilirubin. Lee et al. reported one patient (3.6 percent) who suffered from a 10-cm subcapsular hematoma.85 Local recurrence was reported by three studies.64,85,87 A single postoperative death was reported in two RFA studies.80,87 No direct comparisons can be made based on the published evidence.

### Multivariate Analyses

Relevant univariate or multivariate analyses of prognostic factors for overall survival including, but not limited to, ECOG score, presence of extra hepatic disease, and treatment response, were reported in one case-series study52 of RE for unresectable CRC metastasis to the liver among patients who are candidates for local hepatic therapy as an adjunct to systemic therapy (Appendix D). These analyses reported on overall survival as the dependent variable; none evaluated factors associated with frequency of adverse events. Among the patient or tumor characteristics found to be associated with overall survival were extrahepatic disease (no vs. yes) and treatment response (complete vs. partial). Although these analyses may be hypothesis generating, they do not address the comparative benefit of radiotherapy techniques.

### Overall Conclusions for Key Questions 1–4

- The body of evidence is insufficient to assess effectiveness or comparative effectiveness based on overall survival, quality of life, length of stay, time to progression, local recurrence, and adverse events for local hepatic therapy for the treatment of unresectable CRC metastases to the liver among patients whose disease is refractory to systemic therapy.
- The body of evidence is insufficient to assess effectiveness or comparative effectiveness based on overall survival, quality of life, length of stay, time to recurrence, local recurrence and adverse events for local hepatic therapy as an adjunct to systemic therapy for the treatment of unresectable CRC metastases to the liver.
- The assessment of applicability of the study findings to clinical practice is limited by the poor characterization of the patient populations (e.g., number and size of metastases, performance status) and variability in the delivery of the interventions (e.g., surgical approach, dose and drugs delivered).

For all Key Questions, we could only find case-series evidence that met inclusion criteria. There were no comparative studies, which limits our ability to draw conclusions for all key questions.