# References

1 Bruckner HW. Adenocarinoma of the colon and rectum. Bast RC, Kufe DW, Pollock RE, editors. Holland-Frei Cancer Medicine. 5th edition. Ontario. B C Decker. 2000.
2 Tierney RP, Ballantyne GH, Modlin IM. The adenoma to carcinoma sequence. Surg Gynecol Obstet. Jul. 1990;171(1):81-94. [pmid: 2163117].
3 Minsky BD, Cohen AM, Enker WE, et al. Preoperative 5-FU, low-dose leucovorin, and radiation therapy for locally advanced and unresectable rectal cancer. Int J Radiat Oncol Biol Phys. Jan. 15. 1997;37(2):289-95. [pmid: 9069299].
4 Steinbach G, Heymsfield S, Olansen NE, et al. Effect of caloric restriction on colonic proliferation in obese persons: implications for colon cancer prevention. Cancer Res. Mar. 1. 1994;54(5):1194-7. [pmid: 8118805].
5 DeCosse JJ, Tsioulias GJ, Jacobson JS. Colorectal cancer: Detection, treatment, and rehabilitation. CA Cancer J Clin. Jan–Feb. 1994;44(1):27-42. [pmid: 8281470].
6 Wargovich MJ. New dietary anticarcinogens and prevention of gastrointestinal cancer. Dis Colon Rectum. Jan. 1988;31(1):72-5. [pmid: 3284725].
7 American Joint Committee on Cancer. In Manual for Staging of Cancer. 2nd ed. Philidelphia. Lippincott.
8 Surveillance Epidemiology and End Results. Cancer of the Colon and Rectum - SEER Stat Fact Sheet. 2012. seer.cancer.gov/statfacts/html/colorect.html. Accessed on August 3rd 2012.
9 American Joint Committee on Cancer. AJCC Cancer Staging Manual. 7 ed. Springer. 2010.
10 Wagner JS, Adson MA, Van Heerden JA, et al. The natural history of hepatic metastases from colorectal cancer. A comparison with resective treatment. Ann Surg. May. 1984;199(5):502-8. [pmid: 6721600].
11 Gill S, Blackstock AW, Goldberg RM. Colorectal cancer. Mayo Clin Proc. Jan. 2007;82(1):114-29. [pmid: 17285793].
12 Flanders VL, Gervais DA. Ablation of liver metastases: Current status. J Vasc Interv Radiol. 2010;21(8 Suppl):S214-22. [pmid: 20656231].
13 Gilbert HA, Kagan AR. Metastases: incidence, detection, and evaluation without histologic confirmation. Weiss L, editor. Fundamental Aspects of Metastasis. Netherlands. North Holland Publishing Co. 1976:385-405.
14 Feliberti EC, Wagman LD. Radiofrequency ablation of liver metastases from colorectal carcinoma. Cancer Control. Jan. 2006;13(1):48-51. [pmid: 16508626].
15 Abdalla EK, Vauthey JN, Ellis LM, et al. Recurrence and outcomes following hepatic resection, radiofrequency ablation, and combined resection/ablation for colorectal liver metastases. Ann Surg. Jun. 2004;239(6):818-25. discussion 25–7. [pmid: 15166961].
16 Choti MA, Sitzmann JV, Tiburi MF, et al. Trends in long-term survival following liver resection for hepatic colorectal metastases. Ann Surg. Jun. 2002;235(6):759-66. [pmid: 12035031].
17 de Jong MC, Pulitano C, Ribero D, et al. Rates and patterns of recurrence following curative intent surgery for colorectal liver metastasis: An international multi-institutional analysis of 1669 patients. Ann Surg. Sep. 2009;250(3):440-8. [pmid: 19730175].
18 Fernandez FG, Drebin JA, Linehan DC, et al. Five-year survival after resection of hepatic metastases from colorectal cancer in patients screened by positron emission tomography with F-18 fluorodeoxyglucose (FDG-PET). Ann Surg. Sep. 2004;240(3):438-47. discussion 47–50. [pmid: 15319715].
19 Fong Y, Blumgart LH, Cohen AM. Surgical treatment of colorectal metastases to the liver. CA Cancer J Clin. Jan–Feb. 1995;45(1):50-62. [pmid: 7804899].
20 Morris EJ, Forman D, Thomas JD, et al. Surgical management and outcomes of colorectal cancer liver metastases. Br J Surg. Jul. 2010;97(7):1110-8. [pmid: 20632280].
21 Nordlinger B, Guiguet M, Vaillant JC, et al. Surgical resection of colorectal carcinoma metastases to the liver. A prognostic scoring system to improve case selection, based on 1568 patients. Association Francaise de Chirurgie. Cancer. Apr. 1. 1996;77(7):1254-62. [pmid: 8608500].
22 Vauthey JN, Pawlik TM, Abdalla EK, et al. Is extended hepatectomy for hepatobiliary malignancy justified?. Ann Surg. May. 2004;239(5):722-30. discussion 30–2. [pmid: 15082977].
23 Padma S, Martinie JB, Iannitti DA. Liver tumor ablation: Percutaneous and open approaches. J Surg Oncol. 2009;100(8):619-34. [pmid: 20017157].
24 Kopetz S, Chang GJ, Overman MJ, et al. Improved survival in metastatic colorectal cancer is associated with adoption of hepatic resection and improved chemotherapy. J Clin Oncol. Aug. 1. 2009;27(22):3677-83. [pmid: 19470929].
25 Burak KW. Candidacy for sorafenib in HCC patients: is there a slippery slope beyond a SHARP edge?. Oncology (Williston Park). Mar. 2011;25(3):296. 8. 300. [pmid: 21548474].
26 Evans J. Ablative and catheter-delivered therapies for colorectal liver metastases (CRLM). Eur J Surg Oncol. 2007;33(Suppl 2):S64-75. [pmid: 18061390].
27 Abdalla EK, Barnett CC, Doherty D, et al. Extended hepatectomy in patients with hepatobiliary malignancies with and without preoperative portal vein embolization. Arch Surg. June. 1. 2002. 2002;137(6):675-81. [pmid: 12049538].
28 Alsina J, Choti MA. Liver-Directed Therapies in Colorectal Cancer. Semin Oncol. 2011;38(4):561-7. [pmid: 21810515].
29 Benson AB, Engstrom P, Venook A, et al. National Comprehensive Cancer Network Guidelines Colon Cancer Version 3.2012. 2012.
30 Hendlisz A, Van den Eynde M, Peeters M, et al. Phase III trial comparing protracted intravenous fluorouracil infusion alone or with yttrium-90 resin microspheres radioembolization for liver-limited metastatic colorectal cancer refractory to standard chemotherapy. J Clin Oncol. Aug. 10. 2010;28(23):3687-94. [pmid: 20567019].
31 Wong SL, Mangu PB, Choti MA, et al. American Society of Clinical Oncology 2009 clinical evidence review on radiofrequency ablation of hepatic metastases from colorectal cancer. J Clin Oncol. Jan. 20. 2010;28(3):493-508. [pmid: 19841322].
32 Gage AA, Baust J. Mechanisms of tissue injury in cryosurgery. Cryobiology. 1998;37(3):171-86. [pmid: 9787063].
33 Gage AA, Guest K, Montes M, et al. Effect of varying freezing and thawing rates in experimental cryosurgery. Cryobiology. 1985;22(2):175-82. [pmid: 3979086].
34 Gueorguiev AL, Mackey R, Kowdley GC, et al. Minimally invasive evaluation and treatment of colorectal liver metastases. Int J Surg Oncol. 2011;2011:686030. [pmid: 22312518].
35 Blazer DG, Anaya DA, Abdalla EK. Destructive therapies for colorectal cancer metastastes. Vauthey JN, Audisio RA, Hoff PM, Poston G, editors. Liver Metastases. London. Springer-Verlag. 2009:39-49.
36 Nguyen KT, Geller DA. Radiofrequency ablation of hepatocellular carcinoma. Carr BI, editor. Hepatocellular Carcinoma, Diagnosis and Treatment. New York, New York. Humana Press. 2010:421-51.
37 Radiologyinfo. Radiofrequency Abalation (RFA) of Liver Tumors. 2011. www.radiologyinfo.org/en/info.cfm?pg=rfaliver. Accessed on May, 10 2012.
38 Rahbari NN, Mehrabi A, Mollberg NM, et al. Hepatocellular carcinoma: current management and perspectives for the future. Ann Surg. 2011;253(3):453-69. [pmid: 21263310].
39 American Cancer Society. Embolization therapy for liver cancer. 2012. www.cancer.org/Cancer/LiverCancer/DetailedGuide/liver-cancer-treating-embolization-therapy. Accessed on May 10 2012.
40 Leonard GD, Kemeny NE. Hepatic Directed Therapy. Cassidy J, Johnston P, Van Cutsem E, editors. Colorectal Cancer. Informa Healthcare. 2007:253-85.
41 Kennedy AS, Nutting C, Coldwell D, et al. Pathologic response and microdosimetry of 90Y microspheres in man: review of four explanted whole livers. Int J Radiat Oncol Biol Phys. 2004;60(5):1552-63. [pmid: 15590187].
42 Campbell AM, Bailey IH, MAB. Tumour dosimetry in human liver following hepatic yttrium-90 microsphere therapy. Phys Med Biol. 2001;46(2):487-98. [pmid: 11229728].
43 Lau WY, Leung T, Ho S, et al. Diagnostic pharmaco-scintigraphy with hepatic intraarterial technetium-99m macroaggregated albumin in the determination of tumour to non-tumour uptake ratio in hepatocellular carcinoma. Br J Radiol. 1994;67(794):136-9. [pmid: 8130973].
44 Coldwell DM, Kennedy AS. Internal radiation for the treatment of liver metastases. Vauthey JN, Audisio RA, Hoff PM, Poston G, editors. Liver Metastases. London. Springer-Verlag. 2009:98-109.
45 Meza-Junco J, Montano-Loza AJ, Liu DM, et al. Locoregional radiological treatment for hepatocellular carcinoma; Which, when and how?. Cancer Treat Rev. 2011. In Press, Corrected Proof. [pmid: 21726960].
46 Radiologyinfo. External Beat Therapy (EBT). American College of Radiology and the Radiological Society of North America. 2012. www.radiologyinfo.org/en/info.cfm?pg=ebt. Accessed on May 10 2012.
47 American Cancer Society. Radiation therapy for liver cancer. 2012. www.cancer.org/Cancer/LiverCancer/DetailedGuide/liver-cancer-treating-radiation-therapy. Accessed on May 10 2012.
48 Blazer DG, Anaya DA, Abdalla EK. Destructive therapies for colorectal cancer metastases. Vauthey JN, editor. Liver Metastases. London. Springer-Verlag. 2009:39-50.
49 Radiologyinfo. Intensity-Modulated Radiation Therapy (IMRT). American College of Radiology and the Radiological Society of North America. 2012. www.radiologyinfo.org/en/info.cfm?pg=imrt. Accessed on May 10 2012.
50 Vezali E, Aghemo A, Colombo M. A review of the treatment of chronic hepatitis C virus infection in cirrhosis. Clin Ther. Dec. 2010;32(13):2117-38. [pmid: 21316532].
51 Radiologyinfo. Stereotactic Radiosurgery (SRS) and Stereotactic Body Radiotherapy (SBRT). American College of Radiology and the Radiological Society of North America. 2012. www.radiologyinfo.org/en/info.cfm?pg=stereotactic. Accessed on May 10 2012.
52 Chua TC, Liauw W, Koong H-N, et al. Surgical therapies in metastatic colorectal cancer with a potential for cure. Am J Clin Oncol. 2011;34(3):326-31. [pmid: 20498587].
53 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
54 Moher D, Pham B, Lawson ML, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
55 Pham B, Klassen TP, Lawson ML, et al. Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. Aug. 2005;58(8):769-76. [pmid: 16086467].
56 Adam R, Wicherts DA, de Haas RJ, et al. Patients with initially unresectable colorectal liver metastases: is there a possibility of cure?. J Clin Oncol. Apr. 10. 2009;27(11):1829-35. [pmid: 19273699].
57 Kemeny N, Gonen M, Sullivan D, et al. Phase I study of hepatic arterial infusion of floxuridine and dexamethasone with systemic irinotecan for unresectable hepatic metastases from colorectal cancer. J Clin Oncol. May. 15. 2001;19(10):2687-95. [pmid: 11352961].
58 Kern W, Beckert B, Lang N, et al. Phase I and pharmacokinetic study of hepatic arterial infusion with oxaliplatin in combination with folinic acid and 5-fluorouracil in patients with hepatic metastases from colorectal cancer. Ann Oncol. May. 2001;12(5):599-603. [pmid: 11432616].
59 Meyers MO, Sasson AR, Sigurdson ER. Locoregional strategies for colorectal hepatic metastases. Clin Colorectal Cancer. May. 2003;3(1):34-44. [pmid: 12777190].
60 Carey TS, SD B. A critical guide to case series reports. Spine. 2003;28:1631-4. [pmid: 12897483].
61 Baba Y, Nosho K, Shima K, et al. HIF1A overexpression is associated with poor prognosis in a cohort of 731 colorectal cancers. American Journal of Pathology. May. 2010;176(5):2292-301. [pmid: 20363910].
62 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
63 Albert M, Kiefer MV, Sun W, et al. Chemoembolization of colorectal liver metastases with cisplatin, doxorubicin, mitomycin C, ethiodol, and polyvinyl alcohol. Cancer. Jan. 15. 2011;117(2):343-52. [pmid: 20830766].
64 Chua TC, Bester L, Saxena A, et al. Radioembolization and systemic chemotherapy improves response and survival for unresectable colorectal liver metastases. J Cancer Res Clin Oncol. May. 2011;137(5):865-73. [pmid: 20859640].
65 Cianni R, Urigo C, Notarianni E, et al. Selective internal radiation therapy with SIR-spheres for the treatment of unresectable colorectal hepatic metastases. Cardiovasc Intervent Radiol. Nov. 2009;32(6):1179-86. [pmid: 19680720].
66 Cosimelli M, Golfieri R, Cagol PP, et al. Multi-centre phase II clinical trial of yttrium-90 resin microspheres alone in unresectable, chemotherapy refractory colorectal liver metastases. Br J Cancer. Jul. 27. 2010;103(3):324-31. [pmid: 20628388].
67 Fiorentini G, Aliberti C, Turrisi G, et al. Intraarterial hepatic chemoembolization of liver metastases from colorectal cancer adopting irinotecan-eluting beads: Results of a phase II clinical study. In Vivo. 2007;21(6):1085-92. [pmid: 18210761].
68 Hong K, McBride JD, Georgiades CS, et al. Salvage therapy for liver-dominant colorectal metastatic adenocarcinoma: comparison between transcatheter arterial chemoembolization versus yttrium-90 radioembolization. J Vasc Interv Radiol. Mar. 2009;20(3):360-7. [pmid: 19167245].
69 Jakobs TF, Hoffmann RT, Trumm C, et al. Radiofrequency ablation of colorectal liver metastases: Mid-term results in 68 patients. Anticancer Research. 2006;26(1 B):671-80. [pmid: 16739337].
70 Jiao LR, Szyszko T, Al-Nahhas A, et al. Clinical and imaging experience with yttrium-90 microspheres in the management of unresectable liver tumours. Eur J Surg Oncol. Jun. 2007;33(5):597-602. [pmid: 17433608].
71 Kim MS, Kang JK, Cho CK, et al. Three-fraction stereotactic body radiation therapy for isolated liver recurrence from colorectal cancer. Tumori. Jul–Aug. 2009;95(4):449-54. [pmid: 19856655].
72 Kosmider S, Tan TH, Yip D, et al. Radioembolization in combination with systemic chemotherapy as first-line therapy for liver metastases from colorectal cancer. J Vasc Interv Radiol. Jun. 2011;22(6):780-6. [pmid: 21515072].
73 Lewandowski RJ, Thurston KG, Goin JE, et al. 90Y microsphere (TheraSphere) treatment for unresectable colorectal cancer metastases of the liver: response to treatment at targeted doses of 135–150Gy as measured by [18F]fluorodeoxyglucose positron emission tomography and computed tomographic imaging. J Vasc Interv Radiol. Dec. 2005;16(12):1641-51. [pmid: 16371530].
74 Lim L, Gibbs P, Yip D, et al. A prospective evaluation of treatment with Selective Internal Radiation Therapy (SIR-spheres) in patients with unresectable liver metastases from colorectal cancer previously treated with 5-FU based chemotherapy. BMC Cancer. 2005;5:132. [pmid: 16225697].
75 Martin RC, Joshi J, Robbins K, et al. Hepatic intra-arterial injection of drug-eluting bead, irinotecan (DEBIRI) in unresectable colorectal liver metastases refractory to systemic chemotherapy: results of multi-institutional study. Ann Surg Oncol. Jan. 2011;18(1):192-8. [pmid: 20740319].
76 Mulcahy MF, Lewandowski RJ, Ibrahim SM, et al. Radioembolization of colorectal hepatic metastases using yttrium-90 microspheres. Cancer. May. 1. 2009;115(9):1849-58. [pmid: 19267416].
77 Rowe BP, Weiner R. Foster J, et al. 90Yttrium microspheres for nonresectable liver cancer: the University of Connecticut Health Center experience. Conn Med. Oct. 2007;71(9):523-8. [pmid: 17966721].
78 Sato KT, Lewandowski RJ, Mulcahy MF, et al. Unresectable chemorefractory liver metastases: radioembolization with 90Y microspheres--safety, efficacy, and survival. Radiology. May. 2008;247(2):507-15. [pmid: 18349311].
79 Seki H, Ozaki T, Shiina M. Hepatic arterial infusion chemotherapy using fluorouracil followed by systemic therapy using oxaliplatin plus fluorouracil and leucovorin for patients with unresectable liver metastases from colorectal cancer. Cardiovasc Intervent Radiol. Jul. 2009;32(4):679-86. [pmid: 19296157].
80 Sgouros J, Cast J, Garadi KK, et al. Chemotherapy plus percutaneous radiofrequency ablation in patients with inoperable colorectal liver metastases. World J Gastrointest Oncol. Apr. 15. 2011;3(4):60-6. [pmid: 21528091].
81 Tsutsumi S, Yamaguchi S, Tsuboi K, et al. Hepatic arterial infusion combined with oral UFT/UZEL systemic chemotherapy for unresectable liver metastasis of colorectal cancer. Hepatogastroenterology. Jul–Aug. 2008;55(85):1419-22. [pmid: 18795703].
82 Vautravers-Dewas C, Dewas S, Bonodeau F, et al. Image-guided robotic stereotactic body radiation therapy for liver metastases: Is there a dose response relationship?. Int J Radiat Oncol Biol Phys. 2011. Mar. 4. [pmid: 21377292].
83 Vogl TJ, Zangos S, Eichler K, et al. Palliative hepatic intraarterial chemotherapy (HIC) using a novel combination of gemcitabine and mitomycin C: results in hepatic metastases. Eur Radiol. Mar. 2008;18(3):468-76. [pmid: 17938935].
84 Kucuk ON, Soydal C, Lacin S, et al. Selective intraarterial radionuclide therapy with Yttrium-90 (Y-90) microspheres for unresectable primary and metastatic liver tumors. World J Surg Oncol. 2011;9:86. [pmid: 21819613].
85 Lee KH, Kim HO, Yoo CH, et al. Comparison of radiofrequency ablation and resection for hepatic metastasis from colorectal cancer. Korean J Gastroenterol. Mar. 2012;59(3):218-23. [pmid: 22460570].
86 Martin LK, Cucci A, Wei L, et al. Yttrium-90 radioembolization as salvage therapy for colorectal cancer with liver metastases. Clin Colorectal Cancer. 2012. Jan. 23. [pmid: 22277350].
87 Ruers T, Punt C, Van Coevorden F, et al. Radiofrequency ablation combined with systemic treatment versus systemic treatment alone in patients with nonresectable colorectal liver metastases: a randomized EORTC Intergroup phase II study (EORTC 40004). Ann Oncol. 2012. Mar. 19. [pmid: 22431703].
88 Stintzing S, Hoffmann RT, Heinemann V, et al. Frameless single-session robotic radiosurgery of liver metastases in colorectal cancer patients. Eur J Cancer. Apr. 2010;46(6):1026-32. [pmid: 20153959].
89 Nace GW, Steel JL, Amesur N, et al. Yttrium-90 radioembolization for colorectal cancer liver metastases: A single institution experience. Int J Surg Oncol. 2011;2011:571261. [pmid: 22312513].
90 Aliberti C, Fiorentini G, Muzzio PC, et al. Trans-arterial chemoembolization of metastatic colorectal carcinoma to the liver adopting DC Bead(R), drug-eluting bead loaded with irinotecan: results of a phase II clinical study. Anticancer Res. Dec. 2011;31(12):4581-7. [pmid: 22199334].
91 Jakobs TF, Hoffmann RT, Dehm K, et al. Hepatic yttrium-90 radioembolization of chemotherapy-refractory colorectal cancer liver metastases. J Vasc Interv Radiol. Aug. 2008;19(8):1187-95. [pmid: 18656012].
92 Nishiofuku H, Tanaka T, Aramaki T, et al. Hepatic arterial infusion of 5-fluorouracil for patients with liver metastases from colorectal cancer refractory to standard systemic chemotherapy: a multicenter, retrospective analysis. Clin Colorectal Cancer. Dec. 2010;9(5):305-10. [pmid: 21208845].
93 Lim L, Gibbs P, Yip D, et al. Prospective study of treatment with selective internal radiation therapy spheres in patients with unresectable primary or secondary hepatic malignancies. Intern Med J. Apr. 2005;35(4):222-7. [pmid: 15836500].
94 Veltri A, Sacchetto P, Tosetti I, et al. Radiofrequency ablation of colorectal liver metastases: small size favorably predicts technique effectiveness and survival. Cardiovasc Intervent Radiol. Sep–Oct. 2008;31(5):948-56. [pmid: 18506519].
95 Pasetto LM, Merenda R, Pilati P, et al. Hepatic metastases of colorectal cancer: locoregional intra-arterial treatment. Anticancer Res. Nov–Dec. 2006;26(6C):4785-92. [pmid: 17214342].
96 Skitzki JJ, Chang AE. Hepatic artery chemotherapy for colorectal liver metastases: technical considerations and review of clinical trials. Surg Oncol. Nov. 2002;11(3):123-35. [pmid: 12356508].
97 Sutherland LM, Williams JA, Padbury RT, et al. Radiofrequency ablation of liver tumors: a systematic review. Arch Surg. Feb. 2006;141(2):181-90. [pmid: 16490897].
98 Vogl TJ, Zangos S, Eichler K, et al. Colorectal liver metastases: regional chemotherapy via transarterial chemoembolization (TACE) and hepatic chemoperfusion: An update. Eur Radiol. Apr. 2007;17(4):1025-34. [pmid: 16944163].
99 Wu YZ, Li B, Wang T, et al. Radiofrequency ablation vs hepatic resection for solitary colorectal liver metastasis: A meta-analysis. World J Gastroenterol. Sep. 28. 2011;17(36):4143-8. [pmid: 22039331].
100 Mocellin S, Pasquali S, Nitti D. Fluoropyrimidine-HAI (hepatic arterial infusion) versus systemic chemotherapy (SCT) for unresectable liver metastases from colorectal cancer. Cochrane Database Syst Rev. 2009;(3):CD007823. [pmid: 19588444].
101 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: Critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. Dec. 22. 2004;4(1):38. [pmid: 15615589].
102 Kennedy A, Nag S, Salem R, et al. Recommendations for radioembolization of hepatic malignancies using Yttrium-90 microsphere brachytherapy: a consensus panel report from the Radioembolization Brachytherapy Oncology Consortium. Int J Radiat Oncol Biol Phys. 2007;68(1):13-23. [pmid: 17448867].
103 Bouchahda M, Levi F, Adam R, et al. Modern insights into hepatic arterial infusion for liver metastases from colorectal cancer. Eur J Cancer. Dec. 2011;47(18):2681-90. [pmid: 21783358].
104 Fong Y. Surgical therapy of hepatic colorectal metastasis. Ca-A Cancer Journal for Clinicians. 1999;49(4):231-55. [pmid: 11198884].
105 Sweet BV, Schwemm AK, Parsons DM. Review of the processes for FDA oversight of drugs, medical devices, and combination products. J Manag Care Pharm. Jan–Feb. 2011;17(1):40-50. [pmid: 21204589].
106 Gliklich RE, Dreyer NA. Registries for evaluating patient outcomes : a user’s guide. Rockville, MD. US Dept of Health and Human Services, Public Health Service, Agency for Healthcare Research and Quality. 2007.