# Introduction

## Background

This report aims to compare the effectiveness and harms of several local hepatic therapies for unresectable colorectal cancer (CRC) metastases to the liver. In the sections that follow, we describe CRC and its diagnosis and treatment to orient the reader to the disease. This is followed by a discussion of the treatment of CRC liver metastasis. The local hepatic therapies included in the review are described in detail.

### Condition

CRC is the third most frequently diagnosed cancer and the second leading cause of cancer death in the United States.1 It is a cancer that forms in the tissues of the colon and the rectum. Most colorectal cancers are adenocarcinomas, meaning that they are a cancer of the epithelium originating from glandular tissue. Adenocarcinomas develop from adenomas, which are noncancerous tumors in the epithelial tissue. Over time, adenomas can become cancerous. This progression from adenoma to adenocarcinoma occurs through a sequential process of accumulating genetic changes.2 Although the most common type of CRC is adenocarcinoma, squamous carcinoma and adenosquamous carcinoma have been reported infrequently.3

An elevated risk of CRC has been associated with obesity, low physical activity, high dietary intake of refined sugars, low dietary intake of fiber, consumption of meat, and consumption of more than two alcoholic drinks per day.4 A reduction in risk has been linked to the intake of dietary calcium and diets high in fiber and potassium.5,6

### Diagnosis and Treatment of Colorectal Cancer

The diagnosis of CRC requires pathologic review to characterize and stage the tumor. The Tumor, Node, and Metastases (TNM) staging system is recommended for the staging of CRC, but other staging systems, such as Dukes and Astler-Coller, are widely used.7

Approximately 39 percent of new cases are diagnosed in the localized state, (i.e., no metastases or spread to regional lymph nodes); 36 percent present with regional spread to lymph nodes; 20 percent present with distant, metastatic cancer; and 5 percent present with unstaged disease.8 The 5-year survival rate estimated by the National Cancer Institute Surveillance Epidemiology and End Results program (SEER) data analysis was found to be 74.1 percent for stage I, 64.5 percent for stage IIA, 51.6 percent for stage IIB, 32.3 percent for stage IIC, 74 percent for IIIA, 45 percent for IIIB, 33.4 percent for IIIC, and 6 percent for stage IV.9 Survival declines with increasing depth of tumor penetration, increasing tumor stage, and patient age. For the 20 percent of patients who are initially diagnosed with distant (i.e., metastatic) disease, the 5-year survival rate is 10 percent or less with treatment. Patients with untreated liver metastases have 5-year survival rate of less than 3 percent.10 Survival differs by the extent of liver metastases. Patients with a solitary metastasis have a median survival of 21 months; those with multiple metastases confined to one lobe have median survival of 15 months; and those with widespread bilobar disease have a median survival of less than 12 months.10

#### Treatment of Localized Disease

For the 39 percent of patients who are diagnosed with localized disease, the cornerstone of treatment is surgery.8 Advances in surgical technique, such as total mesorectal excision (dissection of the entire intact vascular, lymphatic, and fatty tissues) rather than blunt dissection, have improved local recurrence rates. Local recurrence rates have decreased from as high as 50 percent to less than 10 percent in some cases.11 Patients whose disease was entirely removed through surgery may be offered adjuvant (i.e., after surgery) chemotherapy or radiation therapy to lower their risk of cancer recurrence. In the past 20 years, adjuvant therapy has evolved from experimental treatment to standard of care. For example, patients with stage III colon cancer who received postsurgical FOLFOX chemotherapy had a 3-year survival rate of 75 percent compared with 25 percent in the pre-adjuvant chemotherapy era.11 Trials are currently being undertaken to determine if adjuvant treatment also improves overall survival compared with surgery alone.

#### Treatment of Distant Disease

CRC is the most common malignancy that metastasizes to the liver: 25 percent of colon cancer patients present with primary CRC and synchronous liver metastases (i.e., the primary disease and liver metastases are diagnosed at the same time), and another 50 percent develop metachronous disease (i.e., liver metastases develop after the initial diagnosis).12 For some proportion of patients, the liver may be the only site of metastasis. Autopsy studies have shown that 38 percent of patients who died of metastatic CRC had liver-only metastasis.13 Thus, therapies directed at the liver (“local hepatic therapies”) have been used with the goal of extending survival in these patients.14

##### Surgical Resection

Although the prognosis for patients with metastatic CRC to the liver has been historically quite poor, advances in surgical technique have improved outcomes for patients with liver-confined metastases. In some situations, treatment of limited liver-only metastases may be curative. For example, in patients with resectable liver-only metastases, several studies have demonstrated durable long-term survival in selected patients, with 5-year survival estimates ranging between 30 percent and 58 percent.15–21 CRC liver metastases are defined as resectable when it is anticipated that disease can be completely resected with negative margins, two adjacent liver segments can be spared, adequate vascular inflow and outflow and biliary drainage can be preserved, and adequate liver volume (20 to 25 percent) will remain postsurgery.22, 23 Approximately 20 to 30 percent of patients with CRC liver metastases are candidates for this approach. Some patients with lesions not well suited for resection may also receive radiofrequency ablation at the time of surgery.

In cases where patients may not have resectable liver metastases at diagnosis, systemic chemotherapy may be used to shrink the tumor and “convert” it to resectable disease.24 Similar to patients with initially resectable liver metastases, these patients may also experience promising 5-year survival rates or approximately 30 percent. Hepatotoxicity from preoperative chemotherapy (e.g., steatohepatitis, sinusoidal injury) is an important concern in these patients.

##### Local Nonsurgical Treatment Strategies

Despite improved surgical techniques and systemic chemotherapy options, many patients may remain ineligible for resection because of anatomic constraints (tumor location or extent of metastatic lesions), inadequate hepatic functional reserve, or concurrent medical comorbidities such as poor performance status (functional impairment typically defined by a higher Eastern Cooperative Oncology Group [ECOG] grade or a lower Karnofsky score) and cardiac insufficiency.25

For patients with unresectable metastatic disease, local hepatic therapy may be used in an attempt to prolong survival or to palliate symptoms (e.g., pain) in patients for whom a cure is no longer within reach. Local hepatic therapy may be used for the following care scenarios:

1. Patients with unresectable, liver-dominant metastases (i.e., majority of disease located in the liver) who are not eligible for continued systemic chemotherapy because their disease is refractory (i.e., they have experienced disease progression while on therapy). These patients generally have large-volume disease and may be offered treatment to debulk the tumor and palliate symptoms when present.26 Regardless of the local hepatic therapy, patients should have liver-only metastases or liver-dominant metastases. In general, it is acceptable to have minimal extrahepatic disease (e.g., a single lung nodule) and remain a treatment candidate.
2. Patients with unresectable liver metastases at diagnosis or with limited unresectable hepatic recurrence after previous resection and who are candidates for local hepatic therapy.27 In these patients, local hepatic therapies can be used as an adjunct to systemic chemotherapy with curative intent. The volume of disease in these patients is small, either in terms of lesion size or number of lesions.28 These treatments are only appropriate when the entire tumor can be ablated with clear margins. To be considered a candidate for ablation or radiation therapy, patients treated in this setting should have no extrahepatic spread.

Several local hepatic therapies have been developed to treat patients with hepatic metastases of CRC. In the continuum of care, use of a local hepatic therapy may occur before or after the use of systemic chemotherapy, but it is administered most often in conjunction with systemic chemotherapy. Local hepatic therapies are divided into three groups: (1) ablation (destruction of tissue through procedures involving heating or cooling); (2) embolization (the selective blockage of blood vessels, often with agents that carry a drug to the occluded site); and (3) radiotherapy (directed radiation to destroy abnormal cells). Table 1 presents a list of the 12 interventions and their mechanisms of action, the setting in which treatment is performed, who performs the intervention, and the specific harms reported for each. The table presents these interventions grouped by type of ablation, embolization, and radiotherapy approach.

Table 1 Local nonsurgical therapies for CRC liver metastases reviewed in this report

Therapy | Treatment Strategy | Mechanism of Cell Death | Setting | Performed By | Specific Harms
Ablation | Cryosurgical ablation | The mechanism of action is based on the rapid formation of intracellular ice crystals during the freezing process. The procedure uses repetitive freezing and thawing of the tissue to produce necrosis and irreversible tissue damage, which occurs at temperatures between −20 and −40°C.32,33 | This type of treatment typically does not require a hospital stay if the percutaneous method is used. An open procedure requires an abdominal incision under general anesthesia and results in a longer recovery period. | Interventional Radiologist | Serious complications are uncommon but are possible, and for cryosurgical ablation include cryoshock phenomenon (acute renal failure, acute respiratory distress syndrome, disseminated intravascular coagulation, and liver failure); myoglobinuria leading to renal failure; bile leakage; hepatic abscess; pleural effusion; consumptive coagulopathy; thrombocytopenia; hepatic iceball fracture; organ failure; and biliary fistula.34,35
Ablation | Radiofrequency ablation (RFA) | RFA is performed by generating an alternating current between at least two electrodes in the radiofrequency range that generates heat without muscle contraction. The procedure generates tissue temperatures of 90 to 100°C, which causes protein denaturation and coagulative necrosis.23 | The procedure is performed under intravenous narcotics for the percutaneous awake approach and does not require a hospital stay. For laparoscopic or open RFA, the procedure is performed under general anesthesia and results in a longer recovery period.36 Each RFA takes approximately 10 to 30 minutes, with additional time required if multiple ablations are performed. The entire procedure is usually completed within 1 to 3 hours.37 | Interventional Radiologist, Surgeon | Possible side effects after RFA therapy include abdominal pain, mild fever, increase in liver enzymes due to damage to the bile ducts, abscess, infection in the liver, skin burns, and bleeding into the chest cavity or abdomen. Serious complications are uncommon but are possible, including hepatic failure, hydrothorax, bile duct leaks, intraperitoneal bleeding, and tumor seeding (spill of tumor cells and subsequent growth in an adjacent site).34,37
Ablation | Microwave ablation (MWA) | MWA uses high-frequency electromagnetic radiation to create heat through the excitation of water molecules.23 The heat causes thermal damage that leads to coagulation necrosis. | This type of treatment typically does not require a hospital stay if the percutaneous method is used. An open procedure requires an abdominal incision under general anesthesia and results in a longer recovery period. | Interventional Radiologist | Very little has been published about complications associated with MWA.35 Many patients experience a low-grade fever and pain for a few days following MWA. Major complications include liver abscess, bile duct injury, pleural effusion, intestinal obstruction, infections, bleeding and skin burn, and potential inadvertent injury to adjacent structures.34,35
Embolization and Transarterial Therapy | Transarterial embolization (TAE) | TAE uses an embolizing agent for selective catheterization and obstruction of the arterial vessel that supplies blood to the tumor.38 | Most patients can be discharged several hours after treatment with TAE, but an overnight stay is typically required if postembolization syndrome occurs. | Interventional Radiologist | Side effects differ depending on the type of embolization used. Common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting); infection in the liver; hepatic abscess; gallbladder inflammation; and blood clots in the main blood vessels of the liver. Serious complications are uncommon but possible. Embolization also reduces some of the blood supply to normal liver tissue. This may be dangerous in patients with underlying diseases such as hepatitis or cirrhosis.39
Embolization and Transarterial Therapy | Transarterial chemoembolization (TACE) | TACE involves administering a chemotherapeutic agent directly to the liver tumor to cause ischemia. A chemotherapeutic solution (frequently doxorubicin or cisplatin) is suspended in lipiodol (an oily contrast medium selectively retained within the tumor) and is injected via a catheter into the hepatic arteries that are directly supplying the tumor. Simultaneously, the feeding hepatic arteries are obstructed with an embolizing agent. Tumor ischemia raises the drug concentration, extends retention of the chemotherapeutic agent, and reduces systemic toxicity. | Most patients can be discharged several hours after treatment with TACE, but an overnight stay is typically required if postembolization syndrome occurs. | Interventional Radiologist | Same as above.
Embolization and Transarterial Therapy | Hepatic artery infusion (HAI) | HAI uses a pump to deliver higher doses of chemotherapy to the tumor compared with systemic chemotherapy, while maintaining low levels of toxicity in the normal tissue. This is achieved by exploiting the unique blood supply to the liver: normal hepatocytes are perfused by the portal vein, whereas the metastases derive most of their blood supply via the hepatic artery. The first-pass effect (a phenomenon of drug metabolism whereby the concentration of a drug is greatly reduced before it reaches the systemic circulation) of drugs delivered to the liver is high.12,34 | A surgeon intraoperatively places the hepatic artery pump as an indwelling device. The pump delivers chemotherapeutic agent at a slow, fixed rate over a period of several weeks. The pump drug chamber can be refilled percutaneously. Successful hepatic arterial infusion is dependent on surgeon experience with the procedure.40 | Interventional Radiologist, Surgeon for placement of pump | Complications related to insertion of the pump are rare;40 however, hepatic artery thrombosis, catheter displacement, hematomas, infections, and liver perfusion are all reported as pump-related complications. The side effects will differ depending upon the type of embolization used. The most common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting); infection in the liver; hepatic abscess; chemical hepatitis; biliary sclerosis; peptic ulceration; gallbladder inflammation; and blood clots in the main blood vessels of the liver. Serious complications are uncommon but possible. Embolization also reduces some of the blood supply to normal liver tissue. This may be dangerous in patients with underlying diseases such as hepatitis or cirrhosis.39
Embolization and Transarterial Therapy | Radioembolization or selective internal radiation therapy (SIRT) | SIRT involves loading the radionuclide Yttrium-90 into microspheres, which are then placed within the microvasculature of the liver metastases, thus targeting multiple hepatic metastases in a single procedure.41 The loaded microspheres deliver high localized doses of β-radiation to the tumor while minimizing radiation exposure to the surrounding tissue.41–43 | Patients are required to undergo a ^99m^Tc-macro-aggregated albumin (MAA) scan prior to SIRT to assess eligibility.44 The SIRT procedure takes approximately 90 minutes, and patients can typically return home 4 to 6 hours following treatment. | Interventional Radiologist | The side effects will differ depending on the type of embolization used. The most common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting); infection in the liver; hepatic abscess; gallbladder inflammation; and blood clots in the main blood vessels of the liver. Serious complications are uncommon but possible.39 Acute toxicity events include gastritis, ulceration, or pancreatitis due to microsphere deposition in vessels serving these organs.44 Radiation-induced liver disease (jaundice, weight gain, painful hepatomegaly and elevated liver enzymes); thrombocytopenia; encephalopathy; elevated results of liver function tests; ascites; and hypoalbuminemia.
Embolization and Transarterial Therapy | Drug-eluting beads (DEB) | This transarterial embolization system uses a drug-loaded (typically with doxorubicin or cisplatin), superabsorbent polymer microsphere to release drug gradually into the tumor, allowing longer intratumoral exposure and less systemic exposure to the drug.45 | Most patients can be discharged several hours after treatment, but an overnight stay is typically required if postembolization syndrome occurs. | Interventional Radiologist | The side effects will differ depending on the type of embolization used. The most common complications reported are postembolization syndrome (fever, pain, extreme fatigue, nausea/vomiting); infection in the liver; hepatic abscess; gallbladder inflammation; and blood clots in the main blood vessels of the liver. Serious complications are uncommon but possible.39
Radiotherapy | External-beam three-dimensional conformal radiation therapy (3D-CRT) | This type of radiotherapy uses computer-assisted tomography scans (CT or CAT scans), magnetic resonance imaging scans (MR or MRI scans), or both to create detailed, 3D representations of the tumor and the surrounding organs. The radiation oncologist uses these computer-generated images to shape radiation beams to the exact size and shape of the tumor, which is intended to spare nearby healthy tissues from exposure. | Each treatment lasts only a few minutes, although the setup time usually takes longer. Most often, radiation treatments are given 5 days a week for several weeks. The patient’s diagnosis determines the total duration of treatment.46,47 | Radiation Oncologist, Medical Physicist, Dosimetrist, Radiation Therapist, and Radiation Therapy Nurse | Possible side effects of external radiation therapy include sunburn-like skin problems, nausea, vomiting, and fatigue. These typically subside post-treatment. Radiation might also make the side effects of chemotherapy worse.39 Radiation-induced liver disease is the major dose-limiting toxicity.48
Radiotherapy | External-beam intensity-modulated radiotherapy (IMRT) | This approach to radiotherapy allows the radiation oncologist to vary both the intensity of a radiation beam and the angle at which it is delivered to the patient. This is intended to deliver a high dose of radiation to the tumor while significantly reducing the exposure of surrounding normal tissue. IMRT offers more refined radiation dosing compared with traditional 3D-CRT. | Same as 3D-CRT, but IMRT requires slightly longer daily treatment times and additional planning and safety checks before the patient can start the treatment.49 | Same as 3D-CRT | Same as 3D-CRT
Radiotherapy | Stereotactic body radiation therapy (SBRT) | This type of external-beam radiation therapy delivers a high dose of radiation with high targeting accuracy to an extracranial target within the body, in either a single dose or a small number of fractions.50 | Before treatment, patients may be asked to undergo placement of a fiducial marker (an object used in concert with imaging to provide precise location information), which is commonly performed as an outpatient procedure. SBRT typically consists of one to five treatment sessions over the course of 1 to 2 weeks, and is usually performed as an outpatient procedure.51 | Same as above | Same as above

In patients with unresectable hepatic metastases, local hepatic therapy represents an opportunity to treat the major site of disease without exposing patients to the side effects of chronic systemic chemotherapy. Similarly, patients who have exhausted all palliative chemotherapeutic options may benefit from local hepatic therapy as a means of delaying disease progression and, in turn, delaying or preventing liver function deterioration and liver failure. Although nonsurgical local hepatic therapies are not generally considered to be curative options, selected patients may experience effective symptom palliation and, in some cases, long-term disease control.

Guidelines from the National Comprehensive Cancer Network for metastatic CRC state that ablative therapy for the metastases can be considered when all measurable metastatic disease can in fact be treated.29 However, the group provides no guidance on which ablative therapy is optimal or on the comparative benefits and harms of the various palliative treatments.29 A perception of clinical equipoise and limited RCT data comparing local hepatic therapies30,31 contribute to uncertainty regarding which techniques, either alone or in combination, may be preferable for certain patient groups.

## Scope and Key Questions

### Scope of the Review

The objective of this systematic review is to characterize the comparative effectiveness and harms of various local hepatic therapies for liver metastases from unresectable CRC in two distinct patient populations:

- Patients with unresectable, liver-dominant (i.e., majority of disease located in the liver) metastases who are not eligible for continued systemic chemotherapy because their disease is refractory (i.e., they have experienced disease progression while on therapy).
- Patients who are candidates for local liver therapies as an adjunct to systemic chemotherapy.

Patients whose liver metastases are resectable, who have unresectable liver metastases treated with first-line chemotherapy in combination with local hepatic therapy for downstaging of disease, or who are treated with a first-line local hepatic therapy alone are outside the scope of this review.

Patients with unresectable liver metastasis are a heterogeneous group, in which careful patient selection may offer opportunities for successful treatment. Patient selection criteria are a key issue; the definition of medically or technically inoperable patients is crucial.52 All patients in the studies included in this review have been classified as having unresectable disease based on either the extent of the tumor or patient characteristics (e.g., poor surgical candidate). As noted, we focus on two distinct patient populations that have different underlying prognoses; thus, we make treatment comparisons within, rather than across, these populations. We considered studies with any length of followup and performed in all inpatient and outpatient settings. Table 2 lists the relevant populations, interventions, comparators, outcomes, timing of assessment, and settings (PICOTS) relevant for this review.

Table 2 PICOTS (Population, Intervention, Comparator, Outcome, Timing, and Setting) for the Key Questions

PICOTS | KQs 1 and 2 | KQs 3 and 4
Population | Patients with unresectable liver metastases from primary CRC who are refractory to systemic chemotherapy but are candidates for local hepatic therapy.; - Patients whose hepatic metastases are unresectable due to medical comorbidities, such as low hepatic reserve, cardiac insufficiency, or poor performance status; - Patients whose hepatic metastases are unresectable because of certain characteristics of the metastases; - Patients with no or minimal extrahepatic disease | Patients with unresectable liver metastases from primary CRC who receive systemic chemotherapy with local hepatic therapy.; - Patients whose hepatic metastases are unresectable because of medical comorbidities, such as low hepatic reserve, cardiac insufficiency, or poor performance status; - Patients whose hepatic metastases are unresectable because of certain characteristics of the metastases; - Patients who have synchronous hepatic metastases; - Patients whose hepatic metastases have recurred after resection; - Patients with no extrahepatic disease
Intervention | - Cryosurgical ablation; - Radiofrequency ablation (RFA); - Microwave ablation (MWA); - Transarterial embolization (TAE); - Transarterial chemoembolization (TACE); - Hepatic arterial infusion (HAI); - Radioembolization or selective0internal radiation therapy (SIRT); - Drug-eluting beads (DEB); - External beam with 3D-CRT or IMRT; - Stereotactic body radiation therapy (SBRT) | Same as KQs 1 and 2.
Comparator | All the therapies listed above compared with the intervention in question for patients not eligible for systemic chemotherapy for CRC | All the therapies listed above compared with the intervention in question for patients receive systemic chemotherapy for CRC.
Outcome | KQ1: [underlined: Ultimate outcomes]: Survival and quality of life [underlined: Intermediate outcomes]: Time to progression, and local recurrence, length of stay KQ2: [underlined: Adverse outcomes]: biloma, hepatic abscess, hepatic hemorrhage, elevated alkaline phosphatase, elevated bilirubin, elevated transaminases, injury to adjacent organ(s), liver failure, rare adverse events, and steatohepatitis. | KQ3: [underlined: Ultimate outcomes]: Same as KQs 1 and 2 [underlined: Intermediate outcomes]: Time to recurrence, and local recurrence, length of stay KQ4: [underlined: Adverse outcomes]: Same as KQs 1 and 2
Timing | The relevant periods occur at the time of treatment of CRC hepatic metastases through followup over months or years. | Same as KQs 1 and 2.
Setting | Inpatient and outpatient. | Same as KQs 1 and 2.

3D-CRT = three-dimensional conformal radiotherapy; CRC = colorectal cancer; IMRT = intensity-modulated radiation therapy; KQ = Key Question

### Key Questions

KQ1. What is the comparative effectiveness of the various liver-directed therapies in patients whose disease is refractory to systemic therapy for unresectable CRC metastases to the liver and who have minimal evidence of extrahepatic disease?

KQ2. What are the comparative harms of the various liver-directed therapies in patients whose disease is refractory to systemic therapy for unresectable CRC metastases to the liver and who have minimal evidence of extrahepatic disease?

KQ3. What is the comparative effectiveness of the various liver-directed therapies in patients who are candidates for liver-directed therapy as an adjunct to systemic therapy for unresectable CRC metastases to the liver and have no evidence of extrahepatic disease?

KQ4. What are the comparative harms of the various liver-directed therapies in patients who are candidates for liver-directed therapy as an adjunct to systemic therapy for unresectable CRC metastases to the liver and have no evidence of extrahepatic disease?

#### Analytic Frameworks

We developed the analytic frameworks (Figure 1 and Figure 2) based on clinical expertise and refined it with input from our key informants and technical expert panel (TEP). These diagrams are revised versions of those posted with the review protocol; the revisions are intended to make the core elements of our final analyses clearer, given the actual literature available for the review.

Figure 1 Analytic framework for comparative effectiveness of local hepatic therapies for unresectable CRC metastases to the liver in patients whose metastatic disease is refractory to systemic chemotherapy and who have no or minimal extrahepatic disease

3D-CRT = three-dimensional conformal radiotherapy; KQ = Key Question; IMRT = intensity-modulated radiation therapy

Figure 1 depicts the potential impact of using liver-directed therapies on both intermediate outcomes and final health outcomes for key questions one and two. Direct evidence of the impact of the various therapies on health outcomes, including adverse effects, is shown by solid lines. Intermediate outcomes—such as time to progression and pain—may have an association with the final health outcomes (dotted line).

Figure 2 Analytic framework for comparative effectiveness of local hepatic therapies for unresectable colorectal cancer metastases to the liver in patients receiving local hepatic therapy as an adjunct to systemic chemotherapy and who have no extrahepatic disease

3D-CRT = Three-dimensional conformal radiotherapy; IMRT = Intensity-modulated radiation therapy; KQ = Key Question

Figure 2 depicts the potential impact of using liver-directed therapies on both intermediate outcomes and final health outcomes for key questions three and four. Direct evidence of the impact of the various therapies on health outcomes, including adverse effects, is shown by solid lines. Intermediate outcomes—such as length of stay, time to recurrence, and tumor response—may have an association with final health outcomes (dotted line).

Figure 1 outlines potential areas in which patients who are unable to receive systemic chemotherapy are using local hepatic therapy. These therapies may affect intermediate health outcomes such as time to progression, local recurrence, and length of stay, as well as the ultimate outcomes of quality of life and overall survival (KQ1).

Figure 2 outlines potential areas in which patients receive local hepatic therapy and concomitant systemic chemotherapy. These therapies may affect intermediate health outcomes such as time to recurrence, local recurrence, and length of stay, as well as ultimate outcomes of quality of life and overall survival (KQ3). In both frameworks, we attempted to assess the occurrence of adverse effects due to local hepatic therapies (KQ2 and KQ4).

## Organization of This Evidence Report

The Methods chapter describes our processes, including our search strategy, inclusion and exclusion criteria, approach to abstract and full text review, and methods for extraction of data into evidence tables and then compiling evidence. In addition, we describe the procedures for evaluating bias in individual studies and describing the strength of the body of evidence.

The Results chapter presents the findings of the literature search and the review of the evidence by key question, synthesizing the findings by strategies.

The Discussion chapter presents the key findings and discusses their relationship to other published findings and the applicability of the findings of this report. We also outline challenges for future research in the field.

The report includes a number of appendixes to provide further details about our methods and the studies assessed. The appendixes are as follows:

- Appendix A: Search Strategy
- Appendix B: Contacted Authors
- Appendix C: DistillerSR Screening and Abstraction Forms
- Appendix D: Evidence Tables
- Appendix E: Abbreviations and Acronyms
- Appendix F: Excluded Studies

## Uses of This Evidence Report

We anticipate that this report will be of primary value and interest to health care providers who treat patients with CRC and CRC metastases to the liver. Treatment is generally provided by medical oncologists, radiation oncologists, interventional radiologists, and surgeons. This report can bring providers up to date on the current state of the evidence, and it provides a quality assessment of the risk of bias in individual studies that report the outcomes of treatment for unresectable CRC metastases to the liver. It will also be of interest to patients with unresectable CRC liver metastases and their families who are concerned about their health and are facing treatment choices.

Finally, this presentation of the evidence will be of value to researchers, who can obtain a concise analysis of the current state of knowledge in the field and information about gaps in knowledge. The report will help prepare them to conduct research in areas that are needed to advance research methods, understand patient selection, and optimize the effectiveness and safety of treatment for unresectable CRC metastases to the liver.