# Peer Reviewers

Stephen Alberts, M.D.

Professor of Oncology

Mayo Clinic

Rochester, MN

Cathy Eng, M.D.

Associate Professor, Department of Gastrointestinal Medical Oncology

University of Texas

MD Anderson Cancer Center

Houston, TX

Todd Crocenzi, M.D.

Medical Oncologist

Providence Portland Medical Center

Portland, OR

Michael Soulen, M.D.

Professor of Radiology

The Hospital of the University of Pennsylvania

Philadelphia, PA