# Technical Expert Panel

James Andrews, M.D.

Professor of Radiology

Mayo Clinic

Rochester, MN

Afsaneh Barzi, M.D., Ph.D.

Assistant Professor of Clinical Medicine/Hematology and Oncology

University of Southern California Hospital

Los Angeles, CA

Al Benson, M.D.

Professor of Medicine

Northwestern University

Chicago, IL

Virginia Calega, M.D., M.B.A.

Vice President of Medical Management/Policy

Highmark, Inc.

Camp Hill, PA

Nancy Kemeny, M.D.

Medical Oncology

Memorial Sloan-Kettering Cancer Center

New York, NY

David C. Madoff, M.D.

New York Presbyterian Hospital/Weil Cornell Medical Center

New York, NY

Mark Sands, M.D.

Vice Chair, Clinical Ops, Quality/Section Head, Interventional Radiology

Cleveland Clinic

Cleveland, OH