# Key Informants

James Andrews, M.D.

Professor of Radiology

Mayo Clinic

Rochester, MN

Al Benson, M.D.

Professor of Medicine

Northwestern University

Chicago, IL

Virginia Calega, M.D., M.B.A.

Vice President of Medical Management/Policy

Highmark, Inc. Camp Hill, PA

Suzanne Lindley, M.S.W.

Patient Advocate

YES! Beat Liver Tumors

Canton, TX

Mark Sands, M.D.

Vice Chair, Clinical Ops, Quality/Section Head, Interventional Radiology

Cleveland Clinic

Cleveland, OH