# Abbreviations and Acronyms

3D: three-dimensional
AE: adverse events
AHRQ: Agency for Healthcare Research and Quality
CEA: carcinoembryonic antigen
CER: comparative effectiveness review
CRC: colorectal cancer
CRT: conformal radiotherapy
DEB: drug-eluting beads
DEBIRI: drug-eluting bead, irinotecan
ECOG: Eastern Cooperative Oncology Group
EORTC: European Organization for Research and Treatment of Cancer
EPC: Evidence-based Practice Center
FU: fluorouracil
GRADE: Grading of Recommendations Assessment, Development and Evaluation
Gy: Gray
HAI: hepatic artery infusion
HAM-D: Hamilton rating scale for depression
IMRT: intensity-modulated radiation therapy
KQ(s): Key Question(s)
LDH: lactic dehydrogenase
LDT: liver-directed therapy(ies)
MAA: ^99m^Tc-macro-aggregated albumin scan
MWA: microwave ablation
N: number; no
NA: not available
No: number
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, Setting
PFS: progression free survival
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QOL: quality of life
RCT: randomized, controlled trial
RE: radioembolization
RECIST: Response Evaluation Criteria in Solid Tumors
RFA: radiofrequency ablation
SBRT: stereotactic body radiation
SIRT: selective internal radiotherapy
TACE: transcatheter arterial chemoembolization
TAE: transarterial embolization
TEP: Technical Expert Panel
TTR: Time to recurrence