# Evidence Tables

## Tables Related to Key Questions 1 and 2

Appendix Table D-1 Local therapies for colorectal cancer metastases to the liver, study quality Carey and Boden Case Series quality Assessment

Reference | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Rank^*^
Albert – 2011 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Aliberti – 2011 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Cianni – 2009 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Cosimelli - 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Fiorentini – 2007 | Yes | No | Yes | Yes | Yes | No | Yes | Poor
Hong – 2009 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Jakobs – 2006 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Jakobs – 2008 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Jiao – 2007 | Yes | No | Yes | Yes | Yes | No | Yes | Poor
Kim – 2009 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kucuk – 2011 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Lewandowski – 2005 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Lim – 2005 | Yes | No | Yes | Yes | Yes | No | Yes | Poor
Martin – 2011 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Martin – 2012 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Mulcahy - 2009 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Nace – 2011 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Nishiofuku - 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Rowe - 2007 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Sato - 2008 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Stintzing – 2010 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Vautravers-Dewas - 2011 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Vogl - 2008 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair

* A rank of good indicates that all Carey and Boden critera are fulfilled, a rank of fair indicates that one criterion was unfulfilled or it was not possible to assess a criterion given the published information, a rank of poor indicates that two or more criteria were unfulfilled or it was not possible to assess two or more criteria given the published information.

Table Appendix Table D-2 Local therapies for unresectable colorectal cancer metastases to the liver—Summary of multivariable analyses in single-arm studies

Author - Year | Independent Variable | Model | Age (<64, ≥64) | Gender | ECOG Status (0, ≥1) | Primary Site (Colon, Rectum) | Number of Radioembolization Treatments (1, ≥2) | Extent of liver metastases (0–25%, 26–50%, 51–75%) | Hepatic lobar involvement (unilobar, bilobar) | Prior liver resection (No, Yes) | Prior ablation (No, Yes) | Extrahepatic disease (No, Yes) | Number of lines of chemotherapy (≤2, >2) | Radiation dose (<2, ≥2) | Chemo-SIRT (No, Yes) | Treatment Response (Unfavorable, favorable) | CRC Stage at Liver Metastases Diagnosis (2/3, 4) | Tumor Burden (0%–25%, 26%– 50%, 51%–75%, ≥76%) | Tumor replacement (≤25%, >25%) | Liver Metastases Diameter (≤3cm, >3cm) | ECOG status (0 or 1/≥ 2) | CEA Response (Yes, No) | RECIST Response (PR, SD, PD)
Albert - 2011 | Overall Survival Since Time of First Treatment | Log-rank test (univariate) | - | - | <0.001 | - | - | - | - | - | - | 0.48 | 0.03 | - | - | - | - | - | - | - | - | - | -
Albert - 2011 | Overall Survival Since Time of First Treatment | Hazard Ratio (95% CI) (univariate) | - | - | 0.466 (0.15–0.61) | - | - | - | - | - | - | 0.80 (0.52–1.17) | - | - | - | - | - | - | - | - | - | - | -
Nishiofuku – 2010 | Overall Survival Since Time of First Treatment | Hazard Ratio (95% CI) p value (univariate) | NS | - | - | - | - | - | - | NS | - | 0–1 vs >= 2^*^ 2.6 (1.4 – 4.8) 0.003 | - | - | - | - | - | - | - | - | 7.9 (3.5 – 18.1) 0.000 | - | -
Nishiofuku – 2010 | Overall Survival Since Time of First Treatment | Hazard Ratio (95% CI) p value (multivariate) | - | | | | | | | | | 8.3 (3.6 – 19) 0.000 | | | | | | | | | 2.5 (1.3 – 4.6) 0.005 | - | -
Mulcahy - 2009 | Overall Survival Since Time of First Y90 Treatment | Log-rank test (univariate) | - | - | <0.0001 | - | - | - | 0.0953 | - | - | 0.0004 | - | - | - | <.0001 | 0.1691 | - | <0.0001 | - | - | - | -
Jakobs – 2008 | Overall Survival Since Time of First Treatment | Log-rank test (univariate) | NS | NS | - | - | - | - | - | - | - | - | - | - | - | - | - | - | - | - | - | p=0.0001 | p=0.0001
Sato -2008^*^ | Overall Survival | Log-rank test (univariate) | - | - | <0.001 | - | - | - | - | - | - | - | - | - | - | - | - | 0.001 | - | - | - | - | -
Lewandowski - 2005 | Overall Survival Since First Treatment | Log-rank test (univariate) | - | - | 0.12 | - | - | - | 0.11 | - | - | - | 0.2 | - | - | - | - | - | 0.002 | - | -- | - | -

“-“ indicates not reported or not analyzed

“NS” indicates a non-significant p value of ≥ 0.05, exact p value not reported

• Indicates a p value ≤ 0.05

⋄ indicates a non-significant p value of ≥ 0.05

* Sato et al. report data on a population which contains non-CRC patients. In their multivariate analysis some variables (Age, Gender, Primary Diagnosis, Angiographic vascularity, CT vascularity, and more than four lesions) were aggregated with these non-CRC patients and not presented in this table.

ⱡThis study looked ECOG status categories of 0, 1 and 2

ΔThis study looked at previous lines of chemotherapy categories of 0–1, 2 and 3–5

□This study also reported NS for lymphatic metastasis at diagnosis, metachronous vs. synchronous metastasis, history of other metastases at time of treatment, and solitary lesions vs. multiple lesions

Appendix Table D-3 Follow up assessment for KQ 1 and 2

First Author | Study Design | Group | Followup assessed? | Followup Weeks | Lost to followup
Albert - 2011 | Retrospective case series | TACE | No | NR | 5
Aliberti - 2011 | Retrospective case series | TACE w/DEB | Yes | Median: 166, Range: 28–192 | NR
Cianni - 2009 | Retrospective case series | RE | No | Last survival outcome documented at ~610 days | NR
Cosimelli - 2010 | Prospective case series | RE | Yes | Median: 44, Range: 8–116 | NR
Fiorentini - 2007 | Prospective case series | TACE with DEB | Yes | Median:28.6, range: 12.9–54.3 | NR
Hong - 2008 | Retrospective case series | TACE RE | Yes | Mean: 25.2 Mean: 22.8 | NR
Jakobs - 2006 | Retrospective case series | RFA | Yes | Mean: 85.6, SD: 42.4, Range: 24–152 | NR
Jakobs - 2008 | Retrospective case series | RE | Yes | Median: 31.6, (5.2–153.2) | 2
Jiao - 2007 | Prospective case series | SIRT | Yes | Pts. followed every 3 months for 2 years (from OS curve) | NR
Kim - 2009 | Retrospective case series | SBRT | Yes | Median: 48, Range: 28 - 196 | NR
Kucuk | Retrospective Case Series | RE | No | NR | NR
Kosmider - 2011 | Retrospective case series | RE with concurrent Systemic Chemotherapy | Yes | Median: 74.4, Range: 12.8–314 *These are from all pts. inc extra-hepatic mets | NR
Lewandowski - 2005 | Prospective case series | RE | Yes | All pts. followed through December 12, 2003 | 8
Lim - 2005 | Prospective case series | SIRT | Yes | Median:18.3 | NR
Martin - 2011 | Prospective case series | TACE with DEB | Yes | Median: 72, Range: 48–160 | NR
Martin – 2012 | Retrospective Case Series | RE | No | NR | NR
Mulcahy - 2009 | Prospective case series | RE | Yes | Median: 26.2 | NR
Nace - 2011 | Retrospective case series | RE | Yes | NR | NR
Nishiofuku - 2010 | Retrospective case series | HAI | Yes | Median: 21.4, 2–110 | NR
Rowe - 2007 | Retrospective case series | SIRT | No | NR | NR
Sato - 2008 | Prospective case series | RE | Yes | Mean: 41 (all pts.) | NR
Stintzing - 2010 | Prospective case series | Radiosurgery | Yes | Median: 15.6, Mean: 15.3, Range: 8–20.7 | NR
Vautravers-Dewas - 2011 | Retrospective case control | SBRT | Yes | Median: 57.2, Range: 12–92 *all pts. | NR
Vogl - 2008 | Retrospective case series | HAI | Yes | 108 | 0

DEB: drug eluting bead; HAI: hepatic arterial infusion; NR: not reported; OS: overall survival; RE: radioembolization; RFA: radiofrequency ablation; SBRT: stereotactic body radiation therapy; SD: standard deviation; SIRT: selective internal radiation therapy; TACE: transarterial chemoembolization

## Tables related to Key Question 3 and 4

Appendix Table D-4 Local therapies for colorectal cancer metastases to the liver, study quality Carey and Boden Case Series quality Assessment

Reference | Clearly Defined Question | Well-Described Study Population | Well-Described Intervention | Use of Validated Outcome Measures | Appropriate Statistical Analysis | Well-Described Results | Discussion/Conclusions Supported by Data | Rank^*^
Chua - 2010 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Kosmider - 2011 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Lee – 2012 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Ruers - 2012 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Seki - 2009 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair
Sguoros - 2011 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good
Tsutsumi - 2008 | Yes | No | Yes | Yes | Yes | Yes | Yes | Fair

* A rank of good indicates that all Carey and Boden critera are fulfilled, a rank of fair indicates that one criterion was unfulfilled or it was not possible to assess a criterion given the published information, a rank of poor indicates that two or more criteria were unfulfilled or it was not possible to assess two or more criteria given the published information.

Appendix Table D-5 Local therapies for unresectable colorectal cancer metastases to the liver—Summary of multivariable analyses in single-arm studies

Author - Year | Independent Variable | Model | Age (<64, ≥64) | Gender | ECOG Status (0, ≥1) | Primary Site (Colon, Rectum) | Number of Radioembolization Treatments (1, ≥2) | Extent of liver metastases (0–25%, 26–50%, 51–75%) | Hepatic lobar involvement (unilobar, bilobar) | Prior liver resection (No, Yes) | Prior ablation (No, Yes) | Extrahepatic disease (No, Yes) | Number of lines of chemotherapy (≤2, >2) | Radiation dose (<2, ≥2) | Chemo-SIRT (No, Yes) | Treatment Response (Unfavorable, favorable) | CRC Stage at Liver Metastases Diagnosis (2/3, 4) | Tumor Burden (0%–25%, 26%– 50%, 51%–75%, ≥76%) | Tumor replacement (≤25%, >25%) | Liver Metastases Diameter (≤3cm, >3cm)
Chua - 2011 | Overall Survival | Log-rank test (univariate) | 0.464 | 0.034 | 0.144 | 0.008 | 0.048 | 0.005 | 0.663 | 0.859 | 0.321 | 0.063 | 0.006 | 0.965 | 0.017 | <0.001 | - | - | - | -
Chua - 2011 | Overall Survival | Cox regression (multivariate) | - | 0.275 | - | 0.019 | 0.253 | 0.512 | - | - | - | 0.033 | 0.134 | - | 0.449 | <0.001 | - | - | - | -

CRC: colorectal cancer; ECOG: Eastern cooperative oncology group; SIRT: selective internal radiation therapy

Appendix Table D-6 Follow up assessment for KQ 3 and 4

First Author | Study Design | Group | Followup assessed? | Followup Weeks | Lost to followup
Chua - 2010 | Prospective case series | RE with systemic chemotherapy | Yes | Median: 36, range: 4–172 | NR
Kosmider - 2011 | Retrospective case series | RE with concurrent Systemic Chemotherapy | Yes | Median: 74.4, Range: 12.8–314 *These are from all pts. inc extra-hepatic mets | NR
Lee – 2012 | Retrospective case series | RFA plus systemic chemotherapy | Yes | Median: 92 (4.8 – 248) | NR
Ruers - 2012 | RCT | RFA plus systemic treatment | Yes | 211 weeks | 2
Seki - 2009 | Retrospective case control | HAI followed by systemic chemotherapy | Yes | Mean:111.7, Range:37.3–194.6 | NR
Sguoros - 2011 | Prospective case series | RFA and chemotherapy | No | NR | NR

KQ: Key Question; HAI: hepatic arterial infusion; NR: not reported; RCT: randomized controlled trial; RE: radioembolization; RFA: radiofrequency abalation

Appendix Table D-7 Progression free survival outcomes for KQ 1 and 2

Author, Year | Intervention | Progression Definition | Liver PFS Median (months) (95% CI) | Overall PFS Median (months) (95% CI)
Albert - 2011 | TACE | Study Treatment | 5 | 3
Martin - 2011 | TACE with DEB | Study Treatment | 15 | 11
Vautravers-Dewas - 2011 | SBRT | NR | NR | NR
Nace - 2011 | RE | NR | NR | NR
Aliberti - 2011 | TACE w/DEB | Study Treatment | NR | 23
Cosimelli - 2010 | RE | Study Treatment | NR | 3.7 (2.6 to 4.9)
Stintzing - 2010 | SBRT | NR | NR | NR
Nishiofuku - 2010 | HAI | Study Treatment | 4.6 (2.8 to 6.3) | 2.8 (2 to 3.6)
Kim - 2009 | SBRT | Study Treatment | NR | 10
Cianni - 2009 | RE | Study Treatment | NR | 9.3
Mulcahy - 2009 | RE | NR | NR | NR
Martin – 2012 | RE | Study Treatment | 5.1 (2.4 to 5.9) | NR
Hong - 2009 | TACE | NR | NR | NR
Sato - 2008 | RE | NR | NR | NR
Vogl - 2008 | HAI | NR | NR | NR
Jakobs - 2008 | RE | NR | NR | NR
Rowe - 2007 | SIRT | NR | NR | NR
Jiao - 2007 | SIRT | NR | NR | NR
Fiorentini - 2007 | TACE with DEB | NR | NR | NR
Jakobs - 2006 | RFA | NR | NR | NR
Lewandowski - 2005 | RE | NR | NR | NR
Lim - 2005 | SIRT | Study Treatment | NR | 5.3

CI: confidence interval; DEB: drug eluting bead; KQ: Key Question; HAI: hepatic arterial infusion; NR: not reported; pFS: Progression free survival; RE: radioembolization; RFA: radiofrequency abalation; SBRT: stereotactic body radiation therapy; SIRT: selective internal radiation therapy; TACE: transarterial chemoembolization

Appendix Table D-8 Progression free survival outcomes for KQ 3 and 4

Author, Year | Intervention | Progression Definition | Liver PFS Median (months) (95% CI) | Overall PFS Median (months) (95% CI)
Ruers - 2012 | RFA plus systemic treatment | Randomization | NR | 16.8 (11.7 to 22.1)
Lee – 2012 | RFA plus systemic chemotherapy | NR | NR | NR
Kosmider - 2011 | RE with concurrent Systemic Chemotherapy | Study Treatment | NR | 10.4
Sguoros - 2011 | RFA and chemotherapy | Study enrollment | NR | 13 (3.1 to 22.9)
Chua - 2010 | RE with systemic chemotherapy | NR | NR | NR
Seki - 2009 | HAI followed by systemic chemotherapy | NR | NR | 5.1
Tsutsumi - 2008 | HAI with concurrent systemic chemotherapy | NR | NR | 9.2 (7.9 to 10.5)

CI: confidence interval; PFS: progression free survival; RFA: radiofrequency ablation; RE: adioembolization; HAI: hepatic arterial infusion; NR: not reported

Appendix Table D-9 Recently completed (without results posted) or ongoing clinical trials

Trial Name | NCT Number | Status | Sponsor
Postoperative Folfox4 Only Versus Folfox4 Plus Transhepatic Arterial Chemotherapy (TAC) in the Treatment Unresectable Liver Metastasis of Colorectal Cancer (http://www.clinicaltrials.gov/ct2/show/NCT00869271?term=Colorectal+AND+Liver+Metastases&rank=55) | NCT00869271 | Completed | Fudan University
Combination Chemotherapy With or Without Chemoembolization in Treating Patients With Colorectal Cancer Metastatic to the Liver (http://www.clinicaltrials.gov/ct2/show/NCT00023868?term=Colorectal+AND+Liver+Metastases&rank=181) | NCT00023868 | Completed | American College of Radiology Imaging Network
Hepatic Arterial Infusion With Floxuridine and Dexamethasone Combination With Chemotherapy With/Without Bevacizumab for Hepatic Metastases From Colorectal Cancer (http://www.clinicaltrials.gov/ct2/show/NCT00200200?term=Colorectal+AND+Liver+Metastases&rank=103) | NCT00200200 | Ongoing | Memorial Sloan-Kettering Cancer Center
Transhepatic Arterial Chemotherapy (TAC) Versus Transcatheter Arterial Chemoembolization (TACE) Plus Folfox4 as the Treatment of Unresectable Liver Metastasis of Colorectal Cancer (http://www.clinicaltrials.gov/ct2/show/NCT00868569?term=Colorectal+AND+Liver+Metastases&rank=20) | NCT00868569 | Recruiting | Fudan University
FOLFOX Plus SIR-SPHERES MICROSPHERES Versus FOLFOX Alone in Patients With Liver Mets From Primary Colorectal Cancer (http://www.clinicaltrials.gov/ct2/show/NCT00724503?term=Colorectal+AND+Liver+Metastases&rank=29) | NCT00724503 | Recruiting | Sirtex Medical
A Study of Yttrium-90 Radioactive Resin Microspheres to Treat Colorectal Adenocarcinoma Metastatic to the Liver (http://www.clinicaltrials.gov/ct2/show/NCT01098422?term=Colorectal+AND+Liver+Metastases&rank=192) | NCT01098422 | Recruiting | University of California, San Diego
Intra-arterial Y-90 TheraSpheres for Hepatic Metastases From Solid Tumors (http://www.clinicaltrials.gov/ct2/show/NCT01177007?term=Colorectal+AND+Liver+Metastases&rank=195) | NCT01177007 | Recruiting | Sidney Kimmel Comprehensive Cancer Center
Efficacy Evaluation of TheraSphere Following Failed First Line Chemotherapy in Metastatic Colorectal Cancer (http://www.clinicaltrials.gov/ct2/show/NCT01483027?term=Colorectal+AND+Liver+Metastases&rank=233) | NCT01483027 | Recruiting | Nordion (Canada) Inc.
TheraSphere for the Treatment of Liver Metastases (http://www.clinicaltrials.gov/ct2/show/NCT00511862?term=Colorectal+AND+Liver+Metastases&rank=118) | NCT00511862 | Completed | Nordion (Canada) Inc.
Yttrium-90 Radioembolization Using Glass Microspheres (TheraSphere) for Patients With Liver Metastases (http://www.clinicaltrials.gov/ct2/show/NCT01290536?term=Colorectal+AND+Liver+Metastases&rank=131) | NCT01290536 | Completed | Nicholas Fidelman

Appendix D-10 Previous lines of chemotherapy KQ 1 and KQ 2

Author | Median lines of previous therapy | Range Lines of Previous Chemotherapy
Albert, et al. 2011^2^ 121 (100) Poor | 0–1 | 0 to 5
Aliberti, et al. 2011^15^ 82 (100) Fair | NR | 2+
Cianni, et al. 2009^11^ ^b^ 41 (100) Poor | NR | 3+
Cosimelli, et al. 2010^16^ 50 (100) Fair | 4+ | 3 to 5
Fiorentini, et al. 2007^14^ 20 (100) Poor | 2 | 2
Hong, et al. 2009^12^ 21 (100) Fair | NR | 1+
Jakobs, et al. 2006^17^ 68 (100) Fair | NR | NR
Jakobs, et al. 2008^18^ 41 (100) Poor | Mean: 2.8 | 1 to 5
Jiao, et al. 2007^19^ 21 (47.6) Poor | NR | 2+
Kim, et al. 2009^20^ ^a^ 9 (100) Fair | NR | NR
Kucuk, et al. 2011^21^ 78 (44.9) Poor | NR | 1+
Lewandowski, et al. 2005^22^ 27 (100) Poor | NR | NR
Lim, et al. 2005^13^ 30 (100) Poor | 1 | 1 +
Martin 2011^9^ 55 (100) Good | 2 | 1 to 3
Martin, et al. 2012^23,d^ 24 (100) Poor | 3 | 0–7
Mulcahy, et al. 2009^24^ 72 (100) Fair | 2 | 0–3
Nace, et al. 2011^25^ 51 (100) Fair | 2 | 1 to 4
Nishiofuku, et al. 2010^26^ 55 (100) Fair | 2 | 2+
Rowe, et al. 2007^27^ 24 (29.2) Fair | NR | 1+
Sato, et al. 2008^28^ 137 (37.2) Fair | NR | 1+
Stintzing, et al. 2010^5^ 6 (100) Poor | 1 | 1 to 2
Vautravers-Dewas, et al. 2011^6^ 42 (66.7) Fair | NR | 0 +
Vogl, et al. 2008^29^ ^c^ 55 (21.8) Poor | NR | 1+

NR: not reported