# Contacted Authors

Table D-1 List of authors contacted with questions during this review and the question resolution

Author | Response from Authors Sufficient for Issue Resolution | Question/Resolution
Chua - 2010^1^ | Yes | Time from which survival is measured?/Measured from date of RE to date of death or last FU
Albert – 2011^2^ | No | Need to determine number of patients received 0 lines of previous systemic chemotherapy/None
Hendlisz – 2010^3^ | Yes | Need to clarify why patients were given further chemotherapy/Chemotherapy given for disease progression. Include study and use time to liver progression statistics.
Meijerink - 2011^4^ | No | Uncertain if patients were refractory to chemotherapy./Study excluded due to small sample size and potential contamination.
Stintzing – 2011^5^ | Yes | Did any of the CRC liver mets. Patients refuse treatment?/None of these patients refused treatment
Vautravers-Dewas - 2011^6^ | No | Uncertain about extrahepatic metastases in patients./None
Murthy - 2007^7^ | No | Uncertain about treatment dates for this study/None
Ritz – 2007^8^ | No | Uncertain if patients are refractory/None
Martin – 2011^9^ | No | Do survival statistics correspond to complete responders alone?/No response but study included and assumed that issue resulted from a typographical error in table creation.
Tsutsumi - 2008^10^ | No | Article does not give survival starting point/None
Cianni – 2009^11^ | Yes | Article does not give survival starting point, potential overlap in study populations/Author clarified that this was from time of treatment and that this was not a duplicated patient population.
Hong - 2009^12^ | No | Discrepancy in table statistics/none
Lim - 2005^13^ | Yes | Article does not give survival starting point/Author clarified that this was from study treatment.
Fiorentini – 2007^14^ | No | Article does not give survival starting point/None

1 Chua TC, Bester L, Akther J, et al. Successful right hepatectomy after four treatments of yttrium-90 microspheres (SIR-Spheres) and concomitant FOLFOX as bridging therapy to resection of colorectal liver metastases. Anticancer Res. Jul. 2010;30(7):3005-7. [pmid: 20683046].
2 Albert M, Kiefer MV, Sun W, et al. Chemoembolization of colorectal liver metastases with cisplatin, doxorubicin, mitomycin C, ethiodol, and polyvinyl alcohol. Cancer. Jan. 15. 2011;117(2):343-52. [pmid: 20830766].
3 Hendlisz A, Van den Eynde M, Peeters M, et al. Phase III trial comparing protracted intravenous fluorouracil infusion alone or with yttrium-90 resin microspheres radioembolization for liver-limited metastatic colorectal cancer refractory to standard chemotherapy. J Clin Oncol. Aug. 10. 2010;28(23):3687-94. [pmid: 20567019].
4 Meijerink MR, van den Tol P, van Tilborg AA, et al. Radiofrequency ablation of large size liver tumours using novel plan-parallel expandable bipolar electrodes: initial clinical experience. Eur J Radiol. Jan. 2011;77(1):167-71. [pmid: 19616911].
5 Stintzing S, Hoffmann RT, Heinemann V, et al. Frameless single-session robotic radiosurgery of liver metastases in colorectal cancer patients. Eur J Cancer. Apr. 2010;46(6):1026-32. [pmid: 20153959].
6 Vautravers-Dewas C, Dewas S, Bonodeau F, et al. Image-guided robotic stereotactic body radiation therapy for liver metastases: Is there a dose response relationship?. Int J Radiat Oncol Biol Phys. 2011. Mar. 4. [pmid: 21377292].
7 Murthy R, Eng C, Krishnan S, et al. Hepatic yttrium-90 radioembolotherapy in metastatic colorectal cancer treated with cetuximab or bevacizumab. J Vasc Interv Radiol. Dec. 2007;18(12):1588-91. [pmid: 18057297].
8 Ritz JP, Lehmann KS, Reissfelder C, et al. Bipolar radiofrequency ablation of liver metastases during laparotomy. First clinical experiences with a new multipolar ablation concept. Int J Colorectal Dis. Jan. 2006;21(1):25-32. [pmid: 15875202].
9 Martin RC, Joshi J, Robbins K, et al. Hepatic intra-arterial injection of drug-eluting bead, irinotecan (DEBIRI) in unresectable colorectal liver metastases refractory to systemic chemotherapy: results of multi-institutional study. Ann Surg Oncol. Jan. 2011;18(1):192-8. [pmid: 20740319].
10 Tsutsumi S, Yamaguchi S, Tsuboi K, et al. Hepatic arterial infusion combined with oral UFT/UZEL systemic chemotherapy for unresectable liver metastasis of colorectal cancer. Hepatogastroenterology. Jul-Aug. 2008;55(85):1419-22. [pmid: 18795703].
11 Cianni R, Urigo C, Notarianni E, et al. Selective internal radiation therapy with SIR-spheres for the treatment of unresectable colorectal hepatic metastases. Cardiovasc Intervent Radiol. Nov. 2009;32(6):1179-86. [pmid: 19680720].
12 Hong K, McBride JD, Georgiades CS, et al. Salvage therapy for liver-dominant colorectal metastatic adenocarcinoma: comparison between transcatheter arterial chemoembolization versus yttrium-90 radioembolization. J Vasc Interv Radiol. Mar. 2009;20(3):360-7. [pmid: 19167245].
13 Lim L, Gibbs P, Yip D, et al. A prospective evaluation of treatment with Selective Internal Radiation Therapy (SIR-spheres) in patients with unresectable liver metastases from colorectal cancer previously treated with 5-FU based chemotherapy. BMC Cancer. 2005;5:132. [pmid: 16225697].
14 Fiorentini G, Aliberti C, Turrisi G, et al. Intraarterial hepatic chemoembolization of liver metastases from colorectal cancer adopting irinotecan-eluting beads: Results of a phase II clinical study. In Vivo. 2007;21(6):1085-92. [pmid: 18210761].