# Search Strategy

We searched MEDLINE^®^ for RCTs, nonrandomized comparative studies, and case series by using the following string of search terms:

1. “Liver Neoplasms”[Mesh] OR ((hepatic OR liver) AND (cancer OR cancers OR oncology OR neoplasms))
2. “Colorectal Neoplasms”[Mesh] OR colon OR colorectal OR rectal OR intestinal OR rectum OR intestine*
3. “secondary “[Subheading] OR metastatic OR metastasis OR metastases
4. Unresectable OR nonresectable OR inoperable OR irresectable
5. “Ablation Techniques”[Mesh] OR “Embolization, Therapeutic”[Mesh] OR “Chemoembolization, Therapeutic”[Mesh] OR “Radiotherapy”[Mesh] OR “radiotherapy “[Subheading] OR “drug therapy “[Subheading] OR “Drug Therapy”[Mesh] OR “radiofrequency ablation” OR (radiofrequency AND ablation) OR RFA OR cryoablation OR cryosurgical OR cryosurgery OR “microwave ablation” OR (microwave AND ablation) OR ((percutaneous OR intralesional) AND (ethanol OR acetic acid)) OR embolization OR embolisation OR embolize* OR embolise* OR “transarterial chemoembolization” OR “transarterial chemoembolisation” OR TACE OR “transarterial embolization” OR “transarterial embolisation” OR TAE OR radioembolization OR radioembolisation OR radiotherapy OR radiation OR “external beam” OR “3D conformal” OR “3-D Conformal” OR “intensity modulated radiotherapy” OR IMRT OR “intraluminal brachytherapy” OR “liver-directed chemotherapy” OR “hepatic artery infusion” OR HAI OR chemotherapy OR “drug-eluting beads”

((((1 AND 2) AND 3) AND 4) AND 5)

Limits: Humans, English

We searched Embase^®^ for RCTs, nonrandomized comparative studies, and case series by using the following string of search terms:

1. ((hepatic OR ‘liver’/exp) AND (‘cancer’/exp OR ‘cancers’/exp OR ‘oncology’/exp OR ‘neoplasms’/exp))
2. (‘colorectal neoplasms’/exp OR ((‘colon’/exp OR colorectal OR ‘rectal’/exp OR intestinal OR ‘rectum’/exp OR ‘intestine’/exp OR ‘intestines’/exp) AND (‘cancer’/exp OR ‘carcinoma’/exp OR primary)))
3. secondary OR metastatic OR ‘metastasis’/exp OR ‘metastases’/exp
4. unresectable OR nonresectable OR inoperable OR irresectable
5. ‘ablation techniques’/exp OR ‘therapeutic embolization’ OR ‘therapeutic chemoembolization’ OR ‘drug therapy’/exp OR ‘radiofrequency ablation’/exp OR (‘radiofrequency’/exp AND ablation) OR rfa OR ‘cryoablation’/exp OR cryosurgical OR ‘cryosurgery’/exp OR ‘microwave ablation’/exp OR (‘microwave’/exp AND ablation) OR (percutaneous OR ‘intralesional’/exp AND (‘ethanol’/exp OR acetic) AND ‘acid’/exp) OR ‘embolization’/exp OR ‘embolisation’/exp OR embolize* OR embolise* OR ‘transarterial chemoembolization’ OR ‘transarterial chemoembolisation’ OR ‘tace’/exp OR ‘transarterial embolization’ OR ‘transarterial embolisation’ OR tae OR radioembolization OR radioembolisation OR ‘radiotherapy’/exp OR ‘radiation’/exp OR ‘external beam’ OR ‘3d conformal’ OR ‘3-d conformal’ OR ‘intensity modulated radiotherapy’/exp OR ‘imrt’/exp OR ‘intraluminal brachytherapy’ OR ‘liver-directed chemotherapy’ OR ‘hepatic artery infusion’ OR hai OR ‘chemotherapy’/exp OR ‘drug-eluting beads’

((((1 AND 2) AND 3) AND 4) AND 5)

Limits: Human, English and not MEDLINE.

## Regulatory Information

FDA

Source: www.FDA.gov

Date searched: 4/3/2012

Search strategy: key word “colorectal metastases”

Records: 6

## Clinical trial registries

NIH database

Source: http://clinicaltrials.gov/

Date searched: 4/03/2012

Search strategy: Colorectal AND “Liver metastases”

Records: 259

## Conference papers and abstracts

Specific conferences and association meetings

Source – number of results returned for search strategy:

Annual meeting of American Society of Clinical Oncology (ASCO) - 98

Annual meeting of American Society of Clinical Oncology Gastrointestinal (ASCO GI) - 56

Annual meeting of Surgery Society of Oncology (SSO) - 14

Annual meeting of Radiosurgical Society - 6

Date searched: 4/04/2012

Search strategy: KW: “liver metastases” in the title

Records: 174

## Manufacturer database

Source: Accuray Incorporated

Date posted: 3/19/2012

Date searched:4/05/2012

Search strategy: Not applicable

Records:20

Source: Sirtex SIR-Spheres Pty Limited

Date posted: 3/21/2012

Date searched:4/05/2012

Search strategy: Not applicable

Records:35