# References

1 American Psychiatric Association. Diagnostic and statistical manual of mental disorders: DSM-IV-TR. Text Revision. 4th ed. Washington, DC. American Psychiatric Publishing, Inc. 2000.
2 Committee on Treatment of Posttraumatic Stress Disorder, Institute of Medicine. Treatment of Posttraumatic Stress Disorder: An Assessment of the Evidence. Washington, DC. National Academies Press. 2008.
3 Brady KT, Killeen TK, Brewerton T, et al. Comorbidity of psychiatric disorders and posttraumatic stress disorder. J Clin Psychiatry. 2000;61:22-32. WOS:000086916100004. [pmid: 10795606].
4 Norris F, Sloane LB. The epidemiology of trauma and PTSD. Friedman MJ, Keane TM, Resick PA, editors. Handbook of PTSD: Science and practice. New York, NY. Guilford Press. 2007:78-98.
5 Fletcher S, Creamer M, Forbes D. Preventing post traumatic stress disorder: are drugs the answer?. Aust N Z J Psychiatry. Dec. 2010;44(12):1064-71. WOS:000284114100002. [pmid: 21070102].
6 Dohrenwend BP, Turner JB, Turse NA, et al. The psychological risks of Vietnam for U.S. veterans: a revisit with new data and methods. Science. Aug. 18. 2006;313(5789):979-82. [pmid: 16917066].
7 Seal KH, Bertenthal D, Miner CR, et al. Bringing the war back home: mental health disorders among 103,788 US veterans returning from Iraq and Afghanistan seen at Department of Veterans Affairs facilities. Arch Intern Med. Mar. 12. 2007;167(5):476-82. [pmid: 17353495].
8 Krysinska K, Lester D. Post-traumatic stress disorder and suicide risk: a systematic review. Arch Suicide Res. 2010;14(1):1-23. [pmid: 20112140].
9 Tanielian T, Jaycox LH, editors. Invisible wounds of war: psychological and cognitive injuries, their consequences, and services to assist recovery. Santa Monica, CA. RAND Corporation. 2008.
10 Wood DP, Murphy J, McLay R, et al. Cost effectiveness of Virtual Reality Graded Exposure Therapy with physiological monitoring for the treatment of combat related post traumatic stress disorder. Annual Review of CyberTherapy and Telemedicine. 2009;7:223. 2009-17266-051.
11 Kessler RC. Posttraumatic stress disorder: the burden to the individual and to society. J Clin Psychiatry. Suppl 5. 2000;61:4-12. discussion 3–4. [pmid: 10761674].
12 Forbes D, Creamer M, Bisson JI, et al. A guide to guidelines for the treatment of PTSD and related conditions. J Trauma Stress. Oct. 2010;23(5):537-52. [pmid: 20839310].
13 VA/DoD Clinical Practice Guideline Working Group. Management of post-traumatic stress. Washington DC. VA Office of Quality and Performance. 2003.
14 American Psychiatric Association. Practice guideline for the treatment of patients with acute stress disorder and posttraumatic stress disorder. Arlington. American Psychiatrica Publishing. 2004. http://psychiatryonline.org/content.aspx?bookid=28&sectionid=1670530#52282. Accessed on December 12, 2011.
15 National Institute for Health and Clinical Excellence. Post-traumatic stress disorder. NICE Clinical Guidelines, No. 26. London. RCPsych Publications. 2005.
16 Australian National Health and Medical Research Council (NHMRC) Guidelines, Australian Centre for Posttraumatic Mental Health. Australian Guidelines for the Treatment of Adults with Acute Stress Disorder and Posttraumatic Stress Disorder. Melbourne. 2007. http://www.nhmrc.gov.au/publications/synopses/mh13syn.htm. Accessed on December 12, 2011.
17 Foa EB, Keane TM, Friedman MJ, et al., editors. Effective treatments for PTSD: practice guidelines from the International Society for Traumatic Stress Studies. 2nd ed. New York, NY. Guilford Press. 2008.
18 Yalom ID. The Theory and Practice of Group Psychotherapy. 4th ed. New York, NY. Basic Books. 1995.
19 Klein RH, Schermer VL. Group Psychotherapy for Psychological Trauma. New York, NY. The Guilford Press. 2000.
20 Gersons BPR, Carlier IVE, Olff M. Manual brief eclectic psychotherapy (BEP) for posttraumatic stress disorder. Amsterdam. Academic Medical Centre. 2004.
21 Gersons BP, Carlier IV, Lamberts RD, et al. Randomized clinical trial of brief eclectic psychotherapy for police officers with posttraumatic stress disorder. J Trauma Stress. Apr. 2000;13(2):333-47. [pmid: 10838679].
22 Friedman MJ. Post traumatic stress disorder: the latest assessment and treatment strategies. 3rd ed. Kansas City, MO. Compact Clinicals. 2003.
23 Harvey AG, Bryant RA, Tarrier N. Cognitive behaviour therapy for posttraumatic stress disorder. Clin Psychol Rev. 2003;23(3):501-22. [pmid: 12729682].
24 Resick P, Schnicke M. Cognitive processing therapy for rape victims: A treatment manual. Thousand Oaks, CA. Sage Publications. 1993.
25 Foa EB, Hembree EA, Cahill SP, et al. Randomized trial of prolonged exposure for posttraumatic stress disorder with and without cognitive restructuring: outcome at academic and community clinics. J Consult Clin Psychol. Oct. 2005;73(5):953-64. [pmid: 16287395].
26 Stuart S. Interpersonal psychotherapy: a guide to the basics. Psychiatr Ann. 2006;36(8):542-50.
27 American Psychiatric Association. Diagnostic and statistical manual of mental disorders: DSM-III. 3rd ed. Washington, DC. American Psychiatric Publishing, Inc. 1980.
28 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/.
29 Davis LL, Jewell ME, Ambrose S, et al. A placebo-controlled study of nefazodone for the treatment of chronic posttraumatic stress disorder: a preliminary study. J Clin Psychopharmacol. Jun. 2004;24(3):291-7. [pmid: 15118483].
30 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity Methods Research Report. (Prepared by RTI International -- University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No 10-EHC070-EF. Rockville, MD. Agency for Healthcare Research and Quality. Sep. 2010. http://www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=21433337.
31 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research. (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
32 Lewis S, Clarke M. Forest plots: trying to see the wood and the trees. BMJ. Jun. 16. 2001;322(7300):1479-80. [pmid: 11408310].
33 Zlotnick C, Johnson J, Najavits LM. Randomized controlled pilot study of cognitive-behavioral therapy in a sample of incarcerated women with substance use disorder and PTSD. Behav Ther. Dec. 2009;40(4):325-36. [pmid: 19892078].
34 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
35 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
36 Higgins JPT, Green ST, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011 ]. The Cochrane Collaboration. 2011.
37 Dias S, Welton NJ, Sutton AJ, et al. NICE DSU Technical Support Document 2: A Generalised Linear Modelling Framework for Pairwise and Network Meta-Analysis of Randomised Controlled Trials. 2011. http://www.nicedsu.org.uk. Accessed on April 24, 2012.
38 Owens DK, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
39 Atkins D, Chang S, Gartlehner G, et al. Assessing the applicability of studies when comparing medical interventions. Methods guide for effectiveness and comparative effectiveness reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
40 Weathers FW, Keane TM, Davidson JRT. Clinician-administered PTSD scale: A review of the first ten years of research. Depress Anxiety. 2001;13(3):132-56. [pmid: 11387733].
41 Oxman TE, Dietrich AJ, Williams JJW, et al. RESPECT-Mil Primary Care Clinicians Manual. THREE COMPONENT MODEL For Primary Care Management of Depression and PTSD (Military Version). 2008.
42 National Collaborating Centre for Mental Health. Depression: Management of depression in primary and secondary care Commissioned by the National Institute for Clinical Excellence. National Clinical Practice Guideline Number 23. The British Psychological Society and Gaskell. 2004.
43 Cohen J. Statistical Power Analysis for the Behavioral Sciences. Hillsdale. L. Erlbaum Associates. 1988.
44 Carlson JG, Chemtob CM, Rusnak K, et al. Eye movement desensitization and reprocessing (EDMR) treatment for combat-related posttraumatic stress disorder. J Trauma Stress. Jan. 1998;11(1):3-24. [pmid: 9479673].
45 Taylor S, Thordarson DS, Maxfield L, et al. Comparative efficacy, speed, and adverse effects of three PTSD treatments: exposure therapy, EMDR, and relaxation training. J Consult Clin Psychol. Apr. 2003;71(2):330-8. [pmid: 12699027].
46 Marks I, Lovell K, Noshirvani H, et al. Treatment of posttraumatic stress disorder by exposure and/or cognitive restructuring: a controlled study. Arch Gen Psychiatry. Apr. 1998;55(4):317-25. [pmid: 9554427].
47 Hinton DE, Hofmann SG, Rivera E, et al. Culturally adapted CBT (CA-CBT) for Latino women with treatment-resistant PTSD: a pilot study comparing CA-CBT to applied muscle relaxation. Behav Res Ther. Apr. 2011;49(4):275-80. [pmid: 21333272].
48 Nijdam MJ, Gersons BPR, Reitsma JB, et al. Brief eclectic psychotherapy v. eye movement desensitisation and reprocessing therapy for post-traumatic stress disorder: randomised controlled trial. Br J Psychiatry. Mar. 2012;200(3):224-31. WOS:000301829700011. [pmid: 22322458].
49 Foa EB, Dancu CV, Hembree EA, et al. A comparison of exposure therapy, stress inoculation training, and their combination for reducing posttraumatic stress disorder in female assault victims. J Consult Clin Psychol. Apr. 1999;67(2):194-200. [pmid: 10224729].
50 Blanchard EB, Hickling EJ, Devineni T, et al. A controlled evaluation of cognitive behavioural therapy for posttraumatic stress in motor vehicle accident survivors. Behav Res Ther. Jan. 2003;41(1):79-96. [pmid: 12488121].
51 Cloitre M, Koenen KC, Cohen LR, et al. Skills training in affective and interpersonal regulation followed by exposure: a phase-based treatment for PTSD related to childhood abuse. J Consult Clin Psychol. Oct. 2002;70(5):1067-74. [pmid: 12362957].
52 Ehlers A, Clark DM, Hackmann A, et al. Cognitive therapy for post-traumatic stress disorder: development and evaluation. Behav Res Ther. Apr. 2005;43(4):413-31. [pmid: 15701354].
53 Fecteau G, Nicki R. Cognitive behavioural treatment of post traumatic stress disorder after motor vehicle accident. Behavioural and Cognitive Psychotherapy. 1999;27(3):201-14.
54 Hinton DE, Chhean D, Pich V, et al. A randomized controlled trial of cognitive-behavior therapy for Cambodian refugees with treatment-resistant PTSD and panic attacks: a cross-over design. J Trauma Stress. Dec. 2005;18(6):617-29. [pmid: 16382423].
55 Hollifield M, Sinclair-Lian N, Warner TD, et al. Acupuncture for posttraumatic stress disorder: a randomized controlled pilot trial. J Nerv Ment Dis. Jun. 2007;195(6):504-13. [pmid: 17568299].
56 Kubany ES, Hill EE, Owens JA. Cognitive trauma therapy for battered women with PTSD: preliminary findings. J Trauma Stress. Feb. 2003;16(1):81-91. [pmid: 12602656].
57 Liedl A, Muller J, Morina N, et al. Physical activity within a CBT intervention improves coping with pain in traumatized refugees: results of a randomized controlled design. Pain Med. Feb. 2011;12(2):234-45. [pmid: 21223501].
58 McDonagh A, Friedman M, McHugo G, et al. Randomized trial of cognitive-behavioral therapy for chronic posttraumatic stress disorder in adult female survivors of childhood sexual abuse. J Consult Clin Psychol. Jun. 2005;73(3):515-24. [pmid: 15982149].
59 Spence J, Titov N, Dear BF, et al. Randomized controlled trial of Internet-delivered cognitive behavioral therapy for posttraumatic stress disorder. Depress Anxiety. Jul. 2011;28(7):541-50. [pmid: 21721073].
60 van Emmerik AA, Kamphuis JH, Emmelkamp PM. Treating acute stress disorder and posttraumatic stress disorder with cognitive behavioral therapy or structured writing therapy: a randomized controlled trial. Psychother Psychosom. 2008;77(2):93-100. [pmid: 18230942].
61 Johnson DM, Zlotnick C, Perez S. Cognitive behavioral treatment of ptsd in residents of battered women’s shelters: Results of a randomized clinical trial. J Consult Clin Psychol. 2011;79(4):542-51. [pmid: 21787052].
62 Kruse J, Joksimovic L, Cavka M, et al. Effects of trauma-focused psychotherapy upon war refugees. J Trauma Stress. Dec. 2009;22(6):585-92. [pmid: 19960519].
63 Bryant RA, Moulds ML, Guthrie RM, et al. Imaginal exposure alone and imaginal exposure with cognitive restructuring in treatment of posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2003;71(4):706-12. [pmid: 12924676].
64 Cottraux J, Note I, Yao SN, et al. Randomized controlled comparison of cognitive behavior therapy with Rogerian supportive therapy in chronic post-traumatic stress disorder: a 2-year follow-up. Psychother Psychosom. 2008;77(2):101-10. [pmid: 18230943].
65 Litz BT, Engel CC, Bryant RA, et al. A randomized, controlled proof-of-concept trial of an Internet-based, therapist-assisted self-management treatment for posttraumatic stress disorder. Am J Psychiatry. Nov. 2007;164(11):1676-83. [pmid: 17974932].
66 Bryant RA, Moulds ML, Guthrie RM, et al. A randomized controlled trial of exposure therapy and cognitive restructuring for posttraumatic stress disorder. J Consult Clin Psychol. Aug. 2008;76(4):695-703. [pmid: 18665697].
67 Cloitre M, Stovall-McClough KC, Nooner K, et al. Treatment for PTSD related to childhood abuse: a randomized controlled trial. Am J Psychiatry. Aug. 2010;167(8):915-24. [pmid: 20595411].
68 Hinton DE, Hofmann SG, Pollack MH, et al. Mechanisms of efficacy of CBT for Cambodian refugees with PTSD: improvement in emotion regulation and orthostatic blood pressure response. CNS Neurosci Ther. Fall. 2009;15(3):255-63. [pmid: 19691545].
69 Kubany ES, Hill EE, Owens JA, et al. Cognitive trauma therapy for battered women with PTSD (CTT-BW). J Consult Clin Psychol. Feb. 2004;72(1):3-18. [pmid: 14756610].
70 Monson CM, Schnurr PP, Resick PA, et al. Cognitive processing therapy for veterans with military-related posttraumatic stress disorder. J Consult Clin Psychol. Oct. 2006;74(5):898-907. [pmid: 17032094].
71 Chard KM. An evaluation of cognitive processing therapy for the treatment of posttraumatic stress disorder related to childhood sexual abuse. J Consult Clin Psychol. Oct. 2005;73(5):965-71. [pmid: 16287396].
72 Resick PA, Nishith P, Weaver TL, et al. A comparison of cognitive-processing therapy with prolonged exposure and a waiting condition for the treatment of chronic posttraumatic stress disorder in female rape victims. J Consult Clin Psychol. Aug. 2002;70(4):867-79. [pmid: 12182270].
73 Ehlers A, Clark DM, Hackmann A, et al. A randomized controlled trial of cognitive therapy, a self-help booklet, and repeated assessments as early interventions for posttraumatic stress disorder. Arch Gen Psychiatry. 2003;60(10):1024-32. [pmid: 14557148].
74 Forbes D, Lloyd D, Nixon RDV, et al. A multisite randomized controlled effectiveness trial of cognitive processing therapy for military-related posttraumatic stress disorder. J Anxiety Disord. 2012;26(3):442-52. [pmid: 22366446].
75 Mueser KT, Rosenberg SD, Xie H, et al. A randomized controlled trial of cognitive-behavioral treatment for posttraumatic stress disorder in severe mental illness. J Consult Clin Psychol. Apr. 2008;76(2):259-71. [pmid: 18377122].
76 Tarrier N, Pilgrim H, Sommerfield C, et al. A randomized trial of cognitive therapy and imaginal exposure in the treatment of chronic posttraumatic stress disorder. J Consult Clin Psychol. Feb. 1999;67(1):13-8. [pmid: 10028204].
77 Resick PA, Nishith P, Griffin MG. How well does cognitive-behavioral therapy treat symptoms of complex PTSD? An examination of child sexual abuse survivors within a clinical trial. CNS Spectr. May. 2003;8(5):340-55. [pmid: 12766690].
78 Resick PA, Williams LF, Suvak MK, et al. Long-term outcomes of cognitive-behavioral treatments for posttraumatic stress disorder among female rape survivors. J Consult Clin Psychol. 2012;80(2):201-10. [pmid: 22182261].
79 Lovell K, Marks IM, Noshirvani H, et al. Do cognitive and exposure treatments improve various PTSD symptoms differently?: a randomized controlled trial. Behavioural and Cognitive Psychotherapy. 2001;29(1):107-12.
80 Tarrier N, Sommerfield C, Pilgrim H, et al. Cognitive therapy or imaginal exposure in the treatment of post-traumatic stress disorder. Twelve-month follow-up. Br J Psychiatry. Dec. 1999;175:571-5. [pmid: 10789356].
81 Zoellner LA, Feeny NC, Fitzgibbons LA, et al. Response of African American and Caucasian women to cognitive behavioral therapy for PTSD. Behavior Therapy. 1999;30(4):581-95.
82 Zlotnick C, Shea TM, Rosen K, et al. An affect-management group for women with posttraumatic stress disorder and histories of childhood sexual abuse. J Trauma Stress. 1997;10(3):425-36. [pmid: 9246650].
83 Echeburua E, De Corral P, Sarasua B, et al. Treatment of acute posttraumatic stress disorder in rape victims: An experimental study. J Anxiety Disord. 1996;10(3):185-99.
84 Echeburua E, de Corral P, Zubizarreta I, et al. Psychological treatment of chronic posttraumatic stress disorder in victims of sexual aggression. Behav Modif. Oct. 1997;21(4):433-56. [pmid: 9337600].
85 Foa EB, Rothbaum BO, Riggs DS, et al. Treatment of posttraumatic stress disorder in rape victims: a comparison between cognitive-behavioral procedures and counseling. J Consult Clin Psychol. Oct. 1991;59(5):715-23. [pmid: 1955605].
86 Hensel-Dittmann D, Schauer M, Ruf M, et al. Treatment of traumatized victims of war and torture: A randomized controlled comparison of narrative exposure therapy and stress inoculation training. Psychother Psychosom. 2011;80(6):345-52. 2011-29267-004. First Author & Affiliation: Hensel-Dittmann, D. [pmid: 21829046].
87 Rothbaum BO, Astin MC, Marsteller F. Prolonged Exposure versus Eye Movement Desensitization and Reprocessing (EMDR) for PTSD rape victims. J Trauma Stress. Dec. 2005;18(6):607-16. [pmid: 16382428].
88 Basoglu M, Salcioglu E, Livanou M. A randomized controlled study of single-session behavioural treatment of earthquake-related post-traumatic stress disorder using an earthquake simulator. Psychol Med. Feb. 2007;37(2):203-13. [pmid: 17254365].
89 Asukai N, Saito A, Tsuruta N, et al. Efficacy of exposure therapy for Japanese patients with posttraumatic stress disorder due to mixed traumatic events: A randomized controlled study. J Trauma Stress. Dec. 2010;23(6):744-50. [pmid: 21171135].
90 Nacasch N, Foa EB, Huppert JD, et al. Prolonged exposure therapy for combat- and terror-related posttraumatic stress disorder: a randomized control comparison with treatment as usual. J Clin Psychiatry. Sep. 2011;72(9):1174-80. [pmid: 21208581].
91 Schnurr PP, Friedman MJ, Engel CC, et al. Cognitive behavioral therapy for posttraumatic stress disorder in women - A randomized controlled trial. J Am Med Assn. Feb. 2007;297(8):820-30. WOS:000244485000025.
92 Schnurr PP, Friedman MJ, Foy DW, et al. Randomized trial of trauma-focused group therapy for posttraumatic stress disorder - Results from a Department of Veterans Affairs Cooperative Study. Arch Gen Psychiatry. May. 2003;60(5):481-9. [pmid: 12742869].
93 Gamito P, Oliveira J, Rosa P, et al. PTSD elderly war veterans: a clinical controlled pilot study. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):43-8. [pmid: 20528292].
94 Difede J, Cukor J, Jayasinghe N, et al. Virtual reality exposure therapy for the treatment of posttraumatic stress disorder following September 11, 2001. J Clin Psychiatry. Nov. 2007;68(11):1639-47. [pmid: 18052556].
95 Johnson DR, Lubin H. The Counting Method: applying the rule of parsimony to the treatment of posttraumatic stress disorder. Traumatology. 2006;12(1):83-99.
96 Keane TM, Fairbank JA, Caddell JM, et al. Implosive (flooding) therapy reduces symptoms of PTSD in Vietnam combat veterans. Behavior Therapy. 1989;20(2):245-60.
97 Feske U. Treating low-income and minority women with posttraumatic stress disorder: a pilot study comparing prolonged exposure and treatment as usual conducted by community therapists. J Interpers Violence. Aug. 2008;23(8):1027-40. [pmid: 18292398].
98 McLay RN, Wood DP, Webb-Murphy JA, et al. A randomized, controlled trial of virtual reality-graded exposure therapy for post-traumatic stress disorder in active duty service members with combat-related post-traumatic stress disorder. Cyberpsychol Behav Soc Netw. Apr. 2011;14(4):223-9. [pmid: 21332375].
99 Ready DJ, Gerardi RJ, Backscheider AG, et al. Comparing virtual reality exposure therapy to present-centered therapy with 11 U.S. Vietnam veterans with PTSD. Cyberpsychol Behav Soc Netw. Feb. 2010;13(1):49-54. [pmid: 20528293].
100 Arntz A, Tiesema M, Kindt M. Treatment of PTSD: a comparison of imaginal exposure with and without imagery rescripting. J Behav Ther Exp Psychiatry. Dec. 2007;38(4):345-70. [pmid: 18005935].
101 Brom D, Kleber RJ, Defares PB. Brief psychotherapy for posttraumatic stress disorders. J Consult Clin Psychol. Oct. 1989;57(5):607-12. [pmid: 2571625].
102 Beidel DC, Frueh BC, Uhde TW, et al. Multicomponent behavioral treatment for chronic combat-related posttraumatic stress disorder: A randomized controlled trial. J Anxiety Disord. 2011;25(2):224. 2011-01965-008. [pmid: 20951543].
103 Ironson G, Freund B, Strauss JL, et al. Comparison of two treatments for traumatic stress: A community-based study of EMDR and prolonged exposure. J Clin Psychol. 2002;58(1):113-28. [pmid: 11748600].
104 Paunovic N, Ost LG. Cognitive-behavior therapy vs exposure therapy in the treatment of PTSD in refugees. Behav Res Ther. Oct. 2001;39(10):1183-97. [pmid: 11579988].
105 Beck JG, Coffey SF, Foy DW, et al. Group cognitive behavior therapy for chronic posttraumatic stress disorder: an initial randomized pilot study. Behavior Therapy. 2009;40(1):82-92. [pmid: 19187819].
106 Power K, McGoldrick T, Brown K, et al. A controlled comparison of eye movement desensitization and reprocessing versus exposure plus cognitive restructuring versus waiting list in the treatment of post-traumatic stress disorder. Clinical Psychology & Psychotherapy. Sep–Oct. 2002;9(5):299-318. WOS:000178998300001.
107 Difede J, Malta LS, Best S, et al. A randomized controlled clinical treatment trial for World Trade Center attack-related PTSD in disaster workers. J Nerv Ment Dis. Oct. 2007;195(10):861-5. [pmid: 18043528].
108 Ulmer CS, Edinger JD, Calhoun PS. A multi-component cognitive-behavioral intervention for sleep disturbance in veterans with PTSD: a pilot study. J Clin Sleep Med. Feb. 15. 2011;7(1):57-68. [pmid: 21344046].
109 Devilly GJ, Spence SH. The relative efficacy and treatment distress of EMDR and a cognitive-behavior trauma treatment protocol in the amelioration of posttraumatic stress disorder. J Anxiety Disord. Jan–Apr. 1999;13(1–2):131-57. [pmid: 10225505].
110 Lee C, Gavriel H, Drummond P, et al. Treatment of PTSD: stress inoculation training with prolonged exposure compared to EMDR. J Clin Psychol. Sep. 2002;58(9):1071-89. [pmid: 12209866].
111 Hogberg G, Pagani M, Sundin O, et al. On treatment with eye movement desensitization and reprocessing of chronic post-traumatic stress disorder in public transportation workers - A randomized controlled trial. Nordic Journal of Psychiatry. 2007;61(1):54-61. WOS:000245235400009. [pmid: 17365790].
112 Rothbaum BO. A controlled study of eye movement desensitization and reprocessing in the treatment of posttraumatic stress disordered sexual assault victims. Bull Menninger Clin. Summer. 1997;61(3):317-34. [pmid: 9260344].
113 van der Kolk BA, Spinazzola J, Blaustein ME, et al. A randomized clinical trial of eye movement desensitization and reprocessing (EMDR), fluoxetine, and pill placebo in the treatment of posttraumatic stress disorder: treatment effects and long-term maintenance. J Clin Psychiatry. Jan. 2007;68(1):37-46. [pmid: 17284128].
114 Marcus SV, Marquis P, Sakai C. Controlled study of treatment of PTSD using EMDR in an HMO setting. Psychotherapy. Fal. 1997;34(3):307-15. WOS:000071116000010.
115 Zimmermann P, Biesold KH, Barre K, et al. Long-term course of post-traumatic stress disorder (PTSD) in German soldiers: effects of inpatient eye movement desensitization and reprocessing therapy and specific trauma characteristics in patients with non-combat-related PTSD. Mil Med. May. 2007;172(5):456-60. [pmid: 17521089].
116 Karatzias T, Power K, Brown K, et al. A controlled comparison of the effectiveness and efficiency of two psychological therapies for posttraumatic stress disorder: eye movement desensitization and reprocessing vs. emotional freedom techniques. J Nerv Ment Dis. Jun. 2011;199(6):372-8. [pmid: 21629014].
117 Hien DA, Cohen LR, Miele GM, et al. Promising treatments for women with comorbid PTSD and substance use disorders. Am J Psychiatry. Aug. 2004;161(8):1426-32. [pmid: 15285969].
118 Hien DA, Wells EA, Jiang H, et al. Multisite randomized trial of behavioral interventions for women with co-occurring PTSD and substance use disorders. J Consult Clin Psychol. Aug. 2009;77(4):607-19. [pmid: 19634955].
119 Boden MT, Kimerling R, Jacobs-Lentz J, et al. Seeking Safety treatment for male veterans with a substance use disorder and post-traumatic stress disorder symptomatology. Addiction. Mar. 2012;107(3):578-86. [pmid: 21923756].
120 Cook JM, Harb GC, Gehrman PR, et al. Imagery rehearsal for posttraumatic nightmares: a randomized controlled trial. J Trauma Stress. Oct. 2010;23(5):553-63. [pmid: 20839311].
121 Krakow B, Hollifield M, Johnston L, et al. Imagery rehearsal therapy for chronic nightmares in sexual assault survivors with posttraumatic stress disorder: a randomized controlled trial. JAMA. Aug. 1. 2001;286(5):537-45. [pmid: 11476655].
122 Ford JD, Steinberg KL, Zhang W. A randomized clinical trial comparing affect regulation and social problem-solving psychotherapies for mothers with victimization-related PTSD. Behavior therapy. 2011;42(4):560-78. 2011-25130-002. First Author & Affiliation: Ford, Julian D. [pmid: 22035986].
123 Lindauer RJ, Gersons BP, van Meijel EP, et al. Effects of brief eclectic psychotherapy in patients with posttraumatic stress disorder: randomized clinical trial. J Trauma Stress. Jun. 2005;18(3):205-12. [pmid: 16281214].
124 Schnyder U, Muller J, Maercker A, et al. Brief eclectic psychotherapy for PTSD: a randomized controlled trial. J Clin Psychiatry. Apr. 2011;72(4):564-6. [pmid: 21527127].
125 Neuner F, Onyut PL, Ertl V, et al. Treatment of posttraumatic stress disorder by trained lay counselors in an African refugee settlement: a randomized controlled trial. J Consult Clin Psychol. Aug. 2008;76(4):686-94. [pmid: 18665696].
126 Neuner F, Kurreck S, Ruf M, et al. Can asylum-seekers with posttraumatic stress disorder be successfully treated? A randomized controlled pilot study. Cogn Behav Ther. Jun. 2010;39(2):81-91. [pmid: 19816834].
127 Neuner F, Schauer M, Klaschik C, et al. A comparison of narrative exposure therapy, supportive counseling, and psychoeducation for treating posttraumatic stress disorder in an african refugee settlement. J Consult Clin Psychol. Aug. 2004;72(4):579-87. [pmid: 15301642].
128 Hien DA, Morgan-Lopez AA, Campbell ANC, et al. Attendance and substance use outcomes for the Seeking Safety program: sometimes less is more. J Consult Clin Psychol. 2012;80(1):29-42. [pmid: 22182262].
129 Wagner AW, Zatzick DF, Ghesquiere A, et al. Behavioral Activation as an Early Intervention for Posttraumatic Stress Disorder and Depression Among Physically Injured Trauma Survivors. Cognitive and Behavioral Practice. 2007;14(4):341-9.
130 Krupnick JL, Green BL, Stockton P, et al. Group interpersonal psychotherapy for low-income women with posttraumatic stress disorder. Psychother Res. Sep. 2008;18(5):497-507. [pmid: 18816001].
131 Bichescu D, Neuner F, Schauer M, et al. Narrative exposure therapy for political imprisonment-related chronic posttraumatic stress disorder and depression. Behav Res Ther. Sep. 2007;45(9):2212-20. [pmid: 17288990].
132 Petrakis IL, Ralevski E, Desai N, et al. Noradrenergic vs Serotonergic Antidepressant with or without Naltrexone for Veterans with PTSD and Comorbid Alcohol Dependence. Neuropsychopharmacology. Mar. 2012;37(4):996-1004. [pmid: 22089316].
133 Davidson J, Rothbaum BO, Tucker P, et al. Venlafaxine extended release in posttraumatic stress disorder: a sertraline- and placebo-controlled study. J Clin Psychopharmacol. Jun. 2006;26(3):259-67. [pmid: 16702890].
134 Tucker P, Zaninelli R, Yehuda R, et al. Paroxetine in the treatment of chronic posttraumatic stress disorder: results of a placebo-controlled, flexible-dosage trial. J Clin Psychiatry. Nov. 2001;62(11):860-8. [pmid: 11775045].
135 Raskind MA, Peskind ER, Kanter ED, et al. Reduction of nightmares and other PTSD symptoms in combat veterans by prazosin: a placebo-controlled study. Am J Psychiatry. Feb. 2003;160(2):371-3. [pmid: 12562588].
136 Raskind MA, Peskind ER, Hoff DJ, et al. A parallel group placebo controlled study of prazosin for trauma nightmares and sleep disturbance in combat veterans with post-traumatic stress disorder. Biol Psychiatry. Apr. 15. 2007;61(8):928-34. [pmid: 17069768].
137 Akuchekian S, Amanat S. The comparison of topiramate and placebo in the treatment of posttraumatic stress disorder: a randomized, double-blind study. J Res Med Sci. 2004;9(5):240-4.
138 Yeh MS, Mari JJ, Costa MC, et al. A double-blind randomized controlled trial to study the efficacy of topiramate in a civilian sample of PTSD. CNS Neurosci Ther. Oct. 2011;17(5):305-10. [pmid: 21554564].
139 Davis LL, Davidson JR, Ward LC, et al. Divalproex in the treatment of posttraumatic stress disorder: a randomized, double-blind, placebo-controlled trial in a veteran population. J Clin Psychopharmacol. Feb. 2008;28(1):84-8. [pmid: 18204347].
140 Davidson JR, Brady K, Mellman TA, et al. The efficacy and tolerability of tiagabine in adult patients with post-traumatic stress disorder. J Clin Psychopharmacol. Feb. 2007;27(1):85-8. [pmid: 17224720].
141 Tucker P, Trautman RP, Wyatt DB, et al. Efficacy and safety of topiramate monotherapy in civilian posttraumatic stress disorder: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Feb. 2007;68(2):201-6. [pmid: 17335317].
142 Hamner MB, Faldowski RA, Robert S, et al. A preliminary controlled trial of divalproex in posttraumatic stress disorder. Ann Clin Psychiatry. Apr–Jun. 2009;21(2):89-94. [pmid: 19439158].
143 Hertzberg MA, Butterfield MI, Feldman ME, et al. A preliminary study of lamotrigine for the treatment of posttraumatic stress disorder. Biol Psychiatry. May. 1. 1999;45(9):1226-9. [pmid: 10331117].
144 Lindley SE, Carlson EB, Hill K. A randomized, double-blind, placebo-controlled trial of augmentation topiramate for chronic combat-related posttraumatic stress disorder. J Clin Psychopharmacol. Dec. 2007;27(6):677-81. [pmid: 18004136].
145 Butterfield MI, Becker ME, Connor KM, et al. Olanzapine in the treatment of post-traumatic stress disorder: a pilot study. Int Clin Psychopharmacol. Jul. 2001;16(4):197-203. [pmid: 11459333].
146 Stein MB, Kline NA, Matloff JL. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. Am J Psychiatry. Oct. 2002;159(10):1777-9. [pmid: 12359687].
147 Bartzokis G, Lu PH, Turner J, et al. Adjunctive risperidone in the treatment of chronic combat-related posttraumatic stress disorder. Biol Psychiatry. Mar. 1. 2005;57(5):474-9. [pmid: 15737661].
148 Hamner MB, Faldowski RA, Ulmer HG, et al. Adjunctive risperidone treatment in post-traumatic stress disorder: a preliminary controlled trial of effects on comorbid psychotic symptoms. Int Clin Psychopharmacol. Jan. 2003;18(1):1-8. [pmid: 12490768].
149 Krystal JH, Rosenheck RA, Cramer JA, et al. Adjunctive risperidone treatment for antidepressant-resistant symptoms of chronic military service-related PTSD: a randomized trial. JAMA. Aug. 3. 2011;306(5):493-502. [pmid: 21813427].
150 Monnelly EP, Ciraulo DA, Knapp C, et al. Low-dose risperidone as adjunctive therapy for irritable aggression in posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2003;23(2):193-6. [pmid: 12640221].
151 Reich DB, Winternitz S, Hennen J, et al. A preliminary study of risperidone in the treatment of posttraumatic stress disorder related to childhood abuse in women. J Clin Psychiatry. Dec. 2004;65(12):1601-6. [pmid: 15641864].
152 Rothbaum BO, Killeen TK, Davidson JR, et al. Placebo-controlled trial of risperidone augmentation for selective serotonin reuptake inhibitor-resistant civilian posttraumatic stress disorder. J Clin Psychiatry. Apr. 2008;69(4):520-5. [pmid: 18278987].
153 Padala PR, Madison J, Monnahan M, et al. Risperidone monotherapy for post-traumatic stress disorder related to sexual assault and domestic abuse in women. Int Clin Psychopharmacol. Sep. 2006;21(5):275-80. [pmid: 16877898].
154 Braun P, Greenberg D, Dasberg H, et al. Core symptoms of posttraumatic stress disorder unimproved by alprazolam treatment. J Clin Psychiatry. Jun. 1990;51(6):236-8. [pmid: 2189869].
155 Tucker P, Potter-Kimball R, Wyatt DB, et al. Can physiologic assessment and side effects tease out differences in PTSD trials? A double-blind comparison of citalopram, sertraline, and placebo. Psychopharmacol Bull. Summer. 2003;37(3):135-49. [pmid: 14608246].
156 Tucker P, Ruwe WD, Masters B, et al. Neuroimmune and cortisol changes in selective serotonin reuptake inhibitor and placebo treatment of chronic posttraumatic stress disorder. Biol Psychiatry. Jul. 15. 2004;56(2):121-8. [pmid: 15231444].
157 Connor KM, Sutherland SM, Tupler LA, et al. Fluoxetine in post-traumatic stress disorder. Randomised, double-blind study. Br J Psychiatry. Jul. 1999;175:17-22. [pmid: 10621763].
158 Meltzer-Brody S, Connor KM, Churchill E, et al. Symptom-specific effects of fluoxetine in post-traumatic stress disorder. Int Clin Psychopharmacol. Jul. 2000;15(4):227-31. [pmid: 10954063].
159 Martenyi F, Brown EB, Zhang H, et al. Fluoxetine versus placebo in posttraumatic stress disorder. J Clin Psychiatry. Mar. 2002;63(3):199-206. [pmid: 11926718].
160 Martenyi F, Soldatenkova V. Fluoxetine in the acute treatment and relapse prevention of combat-related post-traumatic stress disorder: Analysis of the veteran group of a placebo-controlled, randomized clinical trial. Eur Neuropsychopharmacol. Jul. 2006;16(5):340-9. [pmid: 16356696].
161 Martenyi F, Brown EB, Caldwell CD. Failed efficacy of fluoxetine in the treatment of posttraumatic stress disorder: results of a fixed-dose, placebo-controlled study. J Clin Psychopharmacol. Apr. 2007;27(2):166-70. [pmid: 17414240].
162 van der Kolk BA, Dreyfuss D, Michaels M, et al. Fluoxetine in posttraumatic stress disorder. J Clin Psychiatry. Dec. 1994;55(12):517-22. [pmid: 7814344].
163 Marshall RD, Beebe KL, Oldham M, et al. Efficacy and safety of paroxetine treatment for chronic PTSD: a fixed-dose, placebo-controlled study. Am J Psychiatry. Dec. 2001;158(12):1982-8. [pmid: 11729013].
164 Simon NM, Connor KM, Lang AJ, et al. Paroxetine CR augmentation for posttraumatic stress disorder refractory to prolonged exposure therapy. J Clin Psychiatry. Mar. 2008;69(3):400-5. [pmid: 18348595].
165 Brady K, Pearlstein T, Asnis GM, et al. Efficacy and safety of sertraline treatment of posttraumatic stress disorder: a randomized controlled trial. JAMA. Apr. 12. 2000;283(14):1837-44. [pmid: 10770145].
166 Brady KT, Sonne S, Anton RF, et al. Sertraline in the treatment of co-occurring alcohol dependence and posttraumatic stress disorder. Alcohol Clin Exp Res. Mar. 2005;29(3):395-401. [pmid: 15770115].
167 Davidson JR, Rothbaum BO, van der Kolk BA, et al. Multicenter, double-blind comparison of sertraline and placebo in the treatment of posttraumatic stress disorder. Arch Gen Psychiatry. May. 2001;58(5):485-92. [pmid: 11343529].
168 Friedman MJ, Marmar CR, Baker DG, et al. Randomized, double-blind comparison of sertraline and placebo for posttraumatic stress disorder in a Department of Veterans Affairs setting. J Clin Psychiatry. May. 2007;68(5):711-20. [pmid: 17503980].
169 Panahi Y, Moghaddam BR, Sahebkar A, et al. A randomized, double-blind, placebo-controlled trial on the efficacy and tolerability of sertraline in Iranian veterans with post-traumatic stress disorder. Psychol Med. Oct. 2011;41(10):2159-66. [pmid: 21349225].
170 Zohar J, Amital D, Miodownik C, et al. Double-blind placebo-controlled pilot study of sertraline in military veterans with posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2002;22(2):190-5. [pmid: 11910265].
171 Hertzberg MA, Feldman ME, Beckham JC, et al. Lack of efficacy for fluoxetine in PTSD: a placebo controlled trial in combat veterans. Ann Clin Psychiatry. Jun. 2000;12(2):101-5. [pmid: 10907802].
172 Marshall RD, Lewis-Fernandez R, Blanco C, et al. A controlled trial of paroxetine for chronic PTSD, dissociation, and interpersonal problems in mostly minority adults. Depress Anxiety. 2007;24(2):77-84. [pmid: 16892419].
173 Davidson J, Baldwin D, Stein DJ, et al. Treatment of posttraumatic stress disorder with venlafaxine extended release: a 6-month randomized controlled triale. Arch Gen Psychiatry. Oct. 2006;63(10):1158-65. [pmid: 17015818].
174 Davidson J, Kudler H, Smith R, et al. Treatment of posttraumatic stress disorder with amitriptyline and placebo. Arch Gen Psychiatry. 1990;47(3):259. 1990-17938-001. [pmid: 2407208].
175 Davidson JR, Kudler HS, Saunders WB, et al. Predicting response to amitriptyline in posttraumatic stress disorder. Am J Psychiatry. Jul. 1993;150(7):1024-9. [pmid: 8317571].
176 Reist C, Kauffmann CD, Haier RJ, et al. A controlled trial of desipramine in 18 men with posttraumatic stress disorder. Am J Psychiatry. Apr. 1989;146(4):513-6. [pmid: 2648867].
177 Kosten TR, Frank JB, Dan E, et al. Pharmacotherapy for posttraumatic stress disorder using phenelzine or imipramine. J Nerv Ment Dis. Jun. 1991;179(6):366-70. [pmid: 2051152].
178 Becker ME, Hertzberg MA, Moore SD, et al. A placebo-controlled trial of bupropion SR in the treatment of chronic posttraumatic stress disorder. J Clin Psychopharmacol. Apr. 2007;27(2):193-7. [pmid: 17414245].
179 Davidson JR, Weisler RH, Butterfield MI, et al. Mirtazapine vs. placebo in posttraumatic stress disorder: a pilot trial. Biol Psychiatry. Jan. 15. 2003;53(2):188-91. [pmid: 12547477].
180 Spivak B, Strous RD, Shaked G, et al. Reboxetine versus fluvoxamine in the treatment of motor vehicle accident-related posttraumatic stress disorder: a double-blind, fixed-dosage, controlled trial. J Clin Psychopharmacol. Apr. 2006;26(2):152-6. [pmid: 16633143].
181 McRae AL, Brady KT, Mellman TA, et al. Comparison of nefazodone and sertraline for the treatment of posttraumatic stress disorder. Depress Anxiety. 2004;19(3):190-6. [pmid: 15129422].
182 Frommberger U, Stieglitz RD, Nyberg E, et al. Comparison between paroxetine and behaviour therapy in patients with posttraumatic stress disorder (PTSD): A pilot study. International Journal of Psychiatry in Clinical Practice. 2004;8(1):19-23.
183 Schneier FR, Neria Y, Pavlicova M, et al. Combined prolonged exposure therapy and paroxetine for PTSD related to the World Trade Center attack: a randomized controlled trial. Am J Psychiatry. Jan. 2012;169(1):80-8. [pmid: 21908494].
184 Rothbaum BO, Cahill SP, Foa EB, et al. Augmentation of sertraline with prolonged exposure in the treatment of posttraumatic stress disorder. J Trauma Stress. Oct. 2006;19(5):625-38. [pmid: 17075912].
185 Otto MW, Hinton D, Korbly NB, et al. Treatment of pharmacotherapy-refractory posttraumatic stress disorder among Cambodian refugees: a pilot study of combination treatment with cognitive-behavior therapy vs sertraline alone. Behav Res Ther. Nov. 2003;41(11):1271-6. [pmid: 14527527].
186 Gartlehner G, Hansen RA, Morgan LC, et al. Comparative benefits and harms of second-generation antidepressants for treating major depressive disorder: an updated meta-analysis. Ann Intern Med. Dec. 6. 2011;155(11):772-85. [pmid: 22147715].
187 Gartlehner G, Hansen RA, Morgan LC, et al. Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review. Rockville (MD). 2011.
188 Ben-Menachem E, Sander JW, Stefan H, et al. Topiramate monotherapy in the treatment of newly or recently diagnosed epilepsy. Clin Ther. Jul. 2008;30(7):1180-95. [pmid: 18691980].
189 Silberstein SD. Preventive migraine treatment. Neurol Clin. May. 2009;27(2):429-43. [pmid: 19289224].
190 American Psychiatric Association. Practice Guideline for the Treatment of Patients With Schizophrenia Second Edition. Psychiatrica. http://psychiatryonline.org/guidelines.aspx. Accessed on May 18, 2012.
191 Komossa K, Rummel-Kluge C, Schwarz S, et al. Risperidone versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2011;(1):CD006626. [pmid: 21249678].
192 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2005;(2):CD003388. [pmid: 15846661].
193 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD). Cochrane Database Syst Rev. 2007;(3):CD003388. [pmid: 17636720].
194 Stein DJ, Ipser JC, Seedat S. Pharmacotherapy for post traumatic stress disorder (PTSD). Cochrane Database of Systematic Reviews. 2006;(1). WOS:000234978200105.
195 Hembree EA, Foa EB. Posttraumatic stress disorder: psychological factors and psychosocial interventions. J Clin Psychiatry. Suppl 7. 2000;61(suppl 7):33-9. [pmid: 10795607].
196 Resick PA, Jordan CG, Girelli SA, et al. A comparative outcome study of behavioral group therapy for sexual assault victims. Behavior Therapy. 1988;19:385-401.
197 National Center for PTSD. Treatment of PTSD. http://www.ptsd.va.gov. Accessed on April 27, 2012.
198 Hoge CW, Castro CA, Messer SC, et al. Combat duty in Iraq and Afghanistan, mental health problems, and barriers to care. N Engl J Med. Jul. 1. 2004;351(1):13-22. [pmid: 15229303].
199 Davis RG, Ressler KJ, Schwartz AC, et al. Treatment barriers for low-income, urban African Americans with undiagnosed posttraumatic stress disorder. J Trauma Stress. Apr. 2008;21(2):218-22. [pmid: 18404649].
200 Koenen KC, Goodwin R, Struening E, et al. Posttraumatic stress disorder and treatment seeking in a national screening sample. J Trauma Stress. Feb. 2003;16(1):5-16. [pmid: 12602647].
201 Forman-Hoffman V, Knauer S, McKeeman J, et al. Child and Adolescent Exposure to Trauma: Comparative Effectiveness of Interventions Addressing Post-Traumatic Stress Comparative Effectiveness Review No. xx. (Prepared by the RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. xx-EHCxxx. Rockville, MD. Agency for Healthcare Research and Quality. in press.
202 Khan A, Khan SR, Leventhal RM, et al. Symptom reduction and suicide risk in patients treated with placebo in antidepressant clinical trials: a replication analysis of the Food and Drug Administration Database. Int J Neuropsychopharmacol. Jun. 2001;4(2):113-8. [pmid: 11466159].
203 Khan A, Khan SR, Leventhal RM, et al. Symptom reduction and suicide risk among patients treated with placebo in antipsychotic clinical trials: an analysis of the food and drug administration database. Am J Psychiatry. Sep. 2001;158(9):1449-54. [pmid: 11532730].
204 Luborsky L, Diguer L, Seligman DA, et al. The Researcher’s Own Therapy Allegiances: A “Wild Card” in Comparisons of Treatment Efficacy. Clin Psychol Sci Prac. 1999;6:95-106.
205 Scott CK, Sonis J, Creamer M, et al. Maximizing follow-up in longitudinal studies of traumatized populations. J Trauma Stress. Dec. 2006;19(6):757-69. [pmid: 17195975].